# Results: Narrative Review Key Questions

## Introduction

For ease of presentation and use of our findings, we have divided our results into two chapters, one focused on the five narrative questions and one (which follows) on the six systematic questions. In this chapter, we present our findings sequentially by Key Question (KQ)—namely KQs 1 through 5. Generally, we deal with treatment-resistant depression (TRD) first for its presence in patients with major depressive disorder (MDD) and then TRD in patients with bipolar disorder.

As noted in Methods, we present interpretative text and summary tables documenting our findings. All main sections are introduced by a set of bulleted key points.

## Results of Literature Searches

Figure 1 documents the literature searches for all KQs. It also records the yields from our efforts to identify other sources of information, including handsearching grey and other literature sources. We received materials containing 30 suggested articles via the SEADS process. Twentythree were already included in our database. Seven were screened during title/abstract review. Two moved forward to full text review, resulting in one article added to the included pool of studies for this review.

Figure 1 Literature searches for treatment-resistant depression

^a^We handsearched 191 records from a search of ClinicalTrials.gov, 31 records from a search of the National Guideline Clearinghouse, 2 records from a search of HSRProj, 5 websites (NIMH, UpToDate, AHRQ EHC, SAMHSA, FDA), the 4/27/2016 MEDCAC Panel Proceedings, records from the TRD proposal and protocol, 30 records received from a SEADs/FRN request, and articles included for KQs 1 through 5 for additional relevant records. Relevant records were checked against the database for duplication and 154 relevant records were moved forward to dual full-text review.

AHRQ = Agency for Healthcare Research and Quality; CCTR = Central Register of Controlled Trials; DARE = Database of Abstracts of Reviews of Effects; EHC = Effective Health Care; EMBASE = Excerpta Medica Database; FDA = Food and Drug Administration; FRN = Future Research Needs; HSRProj = Health Services Research Projects in Progress; KQ = Key Question; MEDCAC = Medicare Evidence Development and Coverage Advisory; NIMH = National Institute of Mental Health; PsycINFO = Psychological Information Database; SAMHSA = Substance Abuse and Mental Health Services Administration; SEADs = Supplemental Evidence and Data Request.

We screened 2,337 potentially relevant articles. The two most common reasons for exclusion at the full-text level were ineligible population (89 exclusions) and ineligible study design (45 exclusions). Across all 11 KQs, we included 235 articles (38 for KQs 1 through 5, reported in this chapter, and 197 for KQs 6 through 11, reported in the next chapter). Appendix A presents the literature search strategies; Appendix B lists the articles excluded at the full-text stage of review.

For our analyses, we used three general categories of publications: systematic reviews, nonsystematic reviews, and guidelines or consensus statements.

## Key Question 1 Definitions of Treatment-Resistant Depression in This Literature Base

### Description of Included Studies

We identified 38 publications that directly addressed definitions of TRD (see Table 2). 14 publications were systematic reviews;^31-36,^ ^39-41,^ ^44,^ ^58,^ ^64-66^ six publications were reviews that were not systematic.^5,^ ^18,^ ^30,^ ^37,^ ^45,^ ^46^ In addition, 18 publications reported on 13 different guidelines or consensus statements.^19,^ ^21,^ ^23,38,^ ^42,^ ^67-79^ All but two addressed only MDD; the exceptions addressed TRD in both MDD and bipolar disorder.^41,^ ^42^

Table 2 Types and numbers of publications addressing definitions of TRD

Types of Publications Addressing TRD | Number of Publications | MDD Only | Both MDD and Bipolar
Systematic reviews | 14 | 9 | 1
Non-systematic reviews | 6 | 9 | 0
Guidelines and consensus statements | 18 | 18 | 1
Total | 38 | 36 | 2

MDD = major depressive disorder; TRD = treatment resistant depression.

We sort our findings for KQ 1 into three categories:

1. Definitions of TRD: We identify the various definitions of TRD and how they differ by key components such as numbers of depression treatment failures.
2. Staging models of TRD (which classify patients by level of treatment resistance): We cover issues relating to adequacy of treatment duration, dosage, and other factors noted in the Introduction.
3. Consensus statements or guidelines involving TRD: We identify what best practices or guidelines appear to be highly relevant to definitions of TRD.

### Key Points

1. TRD has been defined as both a dichotomous term (i.e., someone either has it or does not) and a continuous term that falls along a spectrum (i.e., people have different degrees, or stages, of severity).
2. Defined dichotomously, we identified four distinct definitions of TRD, distinguished primarily by the number of prior treatment failures.
3. Since 2005, definitions have emphasized failure to achieve remission as the preferred definition of treatment failure.
4. Nearly all definitions have addressed TRD as a part of MDD; the few definitions that have considered bipolar TRD have noted that TRD within bipolar disorder is a distinct entity from MDD.
5. The five TRD staging models we identified had only limited research addressing reliability and validity (particularly predictive validity); these models appeared to be equally valid for documenting treatment failure in depressed patients, but their applicability and feasibility in clinical practice are unclear.
6. No widely acknowledged consensus exists on the best definition of TRD. However, the majority of systematic reviews and guidelines or consensus statements reported that the commonly used definitions were based on patients whose depression failed to respond (a decrease in depressive severity of at least half) or did not go into remission (complete recovery as measured by a score on a depressive severity instrument below a threshold) following two or more treatment attempts of an adequate dose and duration.
  a. Whether the treatment attempts require different classes of antidepressants is not a settled matter.
  b. Experts do not agree on how to define adequate dose and duration, although the minimum duration cited is 4 weeks.

### Detailed Synthesis

TRD has no established definition. We identified two general approaches to defining it. The first and more common approach considers TRD as a dichotomous term—patients either have or do not have this diagnosis—based on whether they meet a set of threshold criteria. The second approach considers TRD an illness that falls along a spectrum, with different degrees, or stages, of severity. In this latter scheme, either patients do not have TRD at all or they have different degrees of TRD severity (e.g., Stage 1, Stage 2, as described later).

Use of one or the other of these basic definitions—and more importantly what specific elements are included in them—has challenged researchers, clinicians, and policymakers for years. Uppermost is the need to agree on a “proper” definition of TRD. Accordingly, below we discuss the evidence in three sections: the variety of dichotomous TRD definitions, the staging models of TRD, and what the consensus definition appears to be.

#### Dichotomous Definitions of Treatment-Resistant Depression

TRD is defined most commonly by the number of prior antidepressant failures of treating depression (in either MDD or, less often, bipolar disorder). These failures can range from a single treatment failure (relating to any drug) to three or more failures using three different classes of antidepressants.

Further, most definitions consider additional variables. One is how failure is defined (i.e., as an inadequate reduction in depressive severity, a lack of response [typically a 50% decrease in severity], or failure to remit [understood to mean complete recovery from a depressive episode and typically indicated by a reduction of depressive severity below a threshold]). Others include whether the failure occurred in the current episode, whether the individual received an adequate dose of the medication, and whether the duration of treatment was considered adequate. Definitions for these additional variables often differed as well.^41^

Of note, since 2005, a consensus has been developing that the proper definition of failure is the inability to achieve remission (sometimes “to remit”). Other agreement among experts appears to be that an adequate trial is, at a minimum, 4 weeks at an adequate dose,^31,^ ^41^ although some argue that 6 weeks should be the minimum. Most studies did not present information requirements for prior treatment length. Durations of psychotherapy treatments tended to be longer, six or more weeks. Agreement is less clear whether an adequate dose means a minimum effective therapeutic dose or a maximum tolerated dose.

We had initially identified seven currently used definitions of TRD, but we condensed them into four possible categories because some distinctions did not appear to be easy to explain or useful for primary care clinicians or researchers. Table 3 groups them according to the numbers of failures. Specifically, for failures of MDD therapies, these are (1) one for more failures; (2) two or more failures; and (3) three or more failures. For failures of bipolar I or II depression, TRD is defined as failure of one prior trial, although this failure has been variably identified as following a single antidepressant attempt of 10 to 12 weeks^41^ or following a single adequate trial of lithium, or a mood-stabilizing medication and lamotrigine, or quetiapine monotherapy for at least 4 weeks.^42^

Table 3 Four categories of definitions of treatment-resistant depression by number of treatment failures

Number of Treatment Failures | Type of Publication on TRD Treatments, Date | Ways to Define Failure | Specify Current Episode? | Define Adequate Dose? | Define Adequate Duration?
1 or more | Seminal article on defining TRD, 2003^45^ | Nonresponse (<25%), partial response (≥25% to <50%), response without remission (50% or greater symptom reduction) | During current episode | Within therapeutic range but conflicting dosages recommended for same drug by different authors | ≥6 weeks
1 or more | International Workshop on “Present and Future of TMS:Safety and Ethical Guideline” Rossi et al., 2009^68^ | Not described | Not described | Not described | Not described
1 or more | SR - lamotrigine augmentation. 2010^32^ | Nonresponse (<50% decrease in HAM-D after 1 failed treatment or equivalent) | Not described | Not described | 4 weeks
1 or more | SR - psychotherapy, 2011^33^ | Nonresponse, partial response, or no remission (not further defined) | Not described | Most studies in the review provided the accepted dose range | ≥6 weeks
1 or more | Nonsystematic review defining TRD, 2014^18^ | Nonresponse, partial response, or no remission (not further defined) | Not described | Majority of studies in the review referred to adequacy as therapeutic levels | 6 to 8 weeks
1 or more | SR - rTMS, 2015^35^ | Nonresponse, inadequate response, insufficient response (not further defined) | During current episode | Not described | 4 to 6 weeks
1 or more | SR - predictors of nonresponse, 2016^36^ | Nonresponse, no remission (not further defined) | Not described | Not described | Not described
1 or more | SR and MA of olanzapine/fluoxetine combination, Luan et al., 2017^66^ | Nonresponse, no remission (not further defined) | Not described | Not described | Not described
2 or more | Seminal article on definition of TRD, 2001^37^ | Nonresponse or lack of remission (not further defined) | During current episode | At least two thirds of the maximal PDR dose | ≥4 weeks
2 or more | SR - pharmacologic treatments, 2007^31^ | Majority of studies in the review using 2 or more failures incorporated nonresponse or remission in the definition | Majority of studies in the review did not specifically indicate whether the failed trials were during the current MDD episode or part of previous episodes as well | Majority of studies in this review refer to adequacy in a general manner: standard minimum effective doses, maximum tolerated doses within the therapeutic range, acceptable therapeutic doses | ≥4 or ≥6 or ≥8 weeks
2 or more | Unipolar Depression Guideline Harter et al., 2010^70^ | Nonresponse in terms of insufficient change in patients’ symptoms | Not described | Not described | 3 to 4 weeks
2 or more | Institute for Clinical and Economic Review (ICER) Coverage Policy Analysis, 2012^38^ | Lack of clinically meaningful response or remission or lack of decrease in symptom severity in HAM-D of less than 5 points (a 3-point difference is considered clinically meaningful) | In the current episode | At least one of the treatment trials must have been administered at an adequate course of mono- or poly–drug therapy | Not described for TRD
2 or more | Report from European Medicines Agency consensus meeting in 2009—Improving outcome in TRD, Schlaepfer et al., 2012^69^ | Failure to respond (not further defined) | Not described | Minimum dosage that will produce the expected effect or the maximum dosage within the therapeutic range that the patient can tolerate until the expected effect is achieved | 4–6 weeks is considered an adequate trial period to see clinical response, although recent research suggests that longer periods (up to 8 or 12 weeks) may be needed to achieve remission
2 or more | SR - lithium or atypical antipsychotics, 2013^39^ | Failure to respond (not further defined) | Few studies in the review specified in the current episode of depression | Not described | ≥4 weeks for augmentation
2 or more | SR - rTMS, 2014^40^ | Defines nonresponse (≤50% improvement on HAM-D) | Few studies in the review specified in the current episode of depression | Variably defined by individual study authors in the review | ≥4 weeks
2 or more | SR - nonpharmacological, 2014^41^ | No standard definition of AD failure, but a variety of TRD staging tools provide different ways of assessing the adequacy of prior treatment so that the clinician can determine treatment failure | Few studies in the review specified in the current episode of depression | Most common definition: maximum tolerated dose | ≥4 to 8 weeks
2 or more | Australian/New Zealand Clinical Practice Guideline, 2015^42^ | Failure to respond (not further defined) | Not described | Maximal dosage (or blood level achieved) | ≥4 weeks
2 or more | British Association for Psychopharmacology Guidelines for all depressive orders, revision based on 2012 consensus meeting, Cleare et al., 2015^79^ | Lack of improvement (defined as at least a 20% to 30% reduction in HAM-D in different studies) at 4 and 6 weeks; only 20% and 10%, respectively, will go on to eventual response (≥50% improvement) at 8 weeks | Important to consider the current episode in the context of the overall history of depression and the nature of previous episodes when considering treatment options | Adequate treatment, defined as “recommended therapeutic dose” | 4 to 8 weeks
2 or more | CANMAT Guidelines, 2016 Kennedy et al., 201 6^74^ Pharmacological treatments | Partial response (25%-49% reduction in symptom scores) or no response (<25% reduction) | Not described | Not described | 2 to 4 weeks
2 or more | VA/DoD Clinical Practice Guideline, 2016^23^ | Failure to respond (not further defined) | Not described | Appropriate dose titration and target dose range | ≥4 to 6 weeks
2 or more | SR and MA of pharmacological and somatic interventions, Papadimitropoulou et al., 2017^65^ | Nonresponse: MADRS scores from baseline less than 50% at study endpoint Nonremission mostly defined as a MADRS score greater than 7 at study endpoint | At least one failure in the current episode | Not described | Not described
3 or more | ICSI Adult Depression in Primary Care Guideline, 2016^21^ | Failure to achieve remission with an adequate trial of therapy and three different classes of ADs at adequate duration and dosage True treatment resistance was seen as occurring on a continuum, from failure to reach remission after an adequate trial of a single AD to failure to achieve remission despite several trials of ADs, augmentation strategies, electroconvulsive therapy (ECT), and psychotherapy | Not described for TRD | Not described for TRD | Not described for TRD
For bipolar TRD: 1 failure | Washington State Health Care Authority, 2014^41^ | Definition couched as lack of significant reduction in score on a depression symptom scale rather than in terms of the number of treatment failures International Society for Bipolar Disorders recommends using no significant [eduction in Montgomery-Asberg Depression Rating Scale (MADRS) or Hamilton Rating Scale for Depression (HAM-D) score | Not described for bipolar TRD | Not described for bipolar TRD | Time frame required for an adequate trial of AD may need to be longer than with unipolar depression because of the greater natural fluctuation of the disease, which suggests that the clinician may need to observe a patient 2 to 4 weeks beyond the time frame usually considered adequate for an AD trial International Society for Bipolar Disorders recommends an ideal trial duration of 10 to 12 weeks
For bipolar TRD: 1 failure (continued) | Australian/New Zealand Clinical Practice Guideline, 2015^42^ | Failure to remit (not further defined) | Does not clarify but implies current episode | Bipolar I TRD: lithium (blood level 0.6-0.8 mMol/L) or two other adequate ongoing mood-stabilizing treatment, plus lamotrigine (50–200 mg/day) or with full dose quetiapine (≥ 600 mg/day) as monotherapy Bipolar II TRD: lithium (blood level 0.6–0.8 mMol/L) or two other adequate ongoing mood-stabilizing treatment, plus lamotrigine (50–200 mg/day) or with full dose quetiapine (defined for Bipolar II as 300–600 mg/day) as monotherapy | Does not clarify but implies as least 3 weeks for Bipolar I and II TRD

AD = antidepressant; ECT = electroconvulsive therapy; HAM-D = Hamilton Rating Scale For Depression; MA = meta-analysis; MADRS = Montgomery-Asberg Depression Rating Scale; MDD = major depressive disorder; PDR = Physician’s Desk Reference; RCT = randomized controlled trial; SR = systematic review; TRD = treatment-resistant depression; VA\DoD = Veterans Administration\Department of Defense.

Within these four main categories, the various sources are listed in chronological order. The columns represent the four recommended components of a TRD definition. The separate rows and citations can include individual studies, systematic reviews, or guidelines and similar documents. No review compared the utility of applying one versus any other definition.

The applicability and feasibility of these staging tools in clinical practice are not known. The current evidence cannot yet confirm that staging of TRD is going to improve clinical practice.^44^

#### Components of Different Models for Staging Treatment-Resistant Depression

##### Five Basic Staging Models

Staging models acknowledge the dimensional nature of TRD, classifying patients along a spectrum according to their level of resistance to treatment. Several clinical variables, distinct from the components of the dichotomous definition, might affect the development or level of TRD. These variables include the duration of the episode, the depression subtype, depressive severity, and psychiatric or medical comorbidity.^31,^ ^44^

We identified five staging models of TRD. Table 4 delineates key components of these models.

The Antidepressant Treatment History Form (ATHF)80 is a scale extending from 1 to 5; it ranks medication resistance according to the adequacy of prior antidepressant treatment (as indicated by medication dose, treatment duration, and patient adherence). Prediction of treatment response is limited to studies with electroconvulsive therapy (ECT); three prospective studies showed an association between a high score on the ATHF and worse patient outcome. Reliability has been good in two studies.^44^ This tool appears to be intended primarily for use in research settings.^41^

The Thase and Rush staging model (TRSM)^5^ proposes a 5-part categorical scale in which patients are staged according to the number of classes of antidepressants that have failed to provide a response. Treatment resistance moves from more frequently used antidepressants (such as selective serotonin reuptake inhibitors or tricyclic antidepressants [TCAs]) to less frequently used drugs (e.g., monoamine oxidase inhibitors) or ECT. The predictive value of the TRSM has not been systematically assessed, and reliability has not been tested.^44^

Table 4 Staging models For Treatment-Resistent Depression To Define The Spectrum Of Illness

Models Authors and Year of Publication | How Is Severity Scored? | How Is Failure Defined? Specify Current Episode? | Define Adequate Dose? Define Adequate Duration? | Staging Schema | Predictive Validity and Reliability Tested? Correspondence With ≥2 Treatment Failures Other Comments
Antidepressant Treatment History Form (ATHF) Ruhé et al.,2012^44^ | Classification of 0 to 5 per treatment with a possible sum score for all treatments; ranks medication resistance according to adequacy of most potent previous trial | Not defined Yes | Yes, part of 5 stages on form Yes, part of 5 stages on form | 5 stages; - Stage 0: no treatment; - Stage I: Any drug <4 weeks or less than minimum adequate daily dose; for ECT 1–3 sessions; - Stage 2: Any drug ≥4 weeks at less than minimum adequate daily dose; for ECT 4–6 sessions; - Stage 3: Any drug ≥4 weeks at minimum adequate daily dose; for ECT 7–9 unilateral sessions; - Stage 4: Any drug ≥4 weeks at higher than minimum adequate daily dose; for ECT 10–12 unilateral/7–9 bilateral ECT sessions; - Stage 5: Any drug at level 4 augmented with lithium ≥2 weeks; for ECT ≥13 unilateral/≥10 bilateral ECT sessions | Reliability studies done in the 90s showed good interrater reliability (intraclass correlation coefficient=0.94) Prediction of response limited to ECT, with the highest ATHF score associated with increased relapse time or lower response to ECT; however, this did not hold true for the total ATHF score. Does not correspond directly with 2 or more failures First developed in 1990, then updated in 1999; differentiates between MDD with or without psychotic features, but does not include psychotherapy treatments Used to determine the adequacy of prior pharmacotherapy and ECT trials (dosage and duration) but does not account for combination strategies Stages 1 and 2 indicate inadequate treatment
Thase and Rush Staging Model (TRSM) Thase et al., 1997^5^ Fava et al., 2003^45^ Berlim et al., 2007^31^ Ruhé et al.,2012^44^ | Categorized as a particular stage, with higher-numbered stages indicating a greater degree of treatment resistance | Failure to respond Not mentioned | No ≥4 weeks | 5 stages; - Stage I: Failure of at least one adequate trial of one major class of AD; - Stage II: Stage 1 + failure of an adequate trial of an AD in a distinctly different class from Stage 1; - Stage III: Stage II plus failure of adequate trial of a TCA; - Stage IV: Stage III plus failure of an adequate trial of an MAOI; - Stage V: Stage IV plus failure of a course of bilateral ECT | The predictive value has not been systematically assessed and reliability has not been tested. Stage II corresponds with two treatment failures Looks at number of classes of ADs that have failed to provide a response; does not count psychotherapy in count of failed trials
European Staging Model Fekadu et al., 2009^46^ Ruhé et al., 2012^44^ | Determined by the number of weeks with treatment resistance to adequate dose of at least 2 different classes of ADs Treatment resistance for more than 12 months is designated as a distinct staging category: CRD | Poor response to a second (adequate) trial with a different class of AD (for 6–8 weeks); does not emphasize remission “Clinically relevant” TRD is a current episode of depressive disorder that has not benefited from at least two adequate trials of AD compounds of different mechanism of action” | Not found Nonresponder: 6–8 weeks TRD: From Level 1 of 12–16 weeks to Level 5 of 26 weeks to 1 year CRD: at least 12 months | Three general categories: Nonresponder: Nonresponse to 1 adequate trial of TCA, SSRI, MAOI, SNRI, or other AD, or ECT TRD: Resistance to 2 or more adequate AD trials of different classes; - TRD1: 12–16 weeks; - TRD2: 18–24 weeks; - TRD3: 24–32 weeks; - TRD4: 30–40 weeks; - TRD5: 36 weeks–1 year; CRD: Resistant to several AD trials, including augmentation strategy, for at least 12 months | The predictive value has not been systematically assessed, and reliability has not been tested All of the TRD stages are consistent with two treatment failures
Massachusetts General Hospital Staging model (MGH-s) Fava et al., 2003^45^ Ruhé et al., 2012^44^ | This tool provides points for the number of prior AD failures and considers other treatment-related factors to provide a continuous score. Higher scores indicate a greater degree of resistance to treatment | Failure to achieve remission (refers to “inadequate response” but defines it as HAM-D ≤7, which indicates remission) Not considered | Optimization per MGH or ATR Questionnaire ≥6 weeks | Stages:; - Stage 1: Nonresponse to each adequate trial; - Stage 2: Optimization of dose, duration, and augmentation/ combination; - Stage 3: ECT increases overall score by 3 points; Staging is primarily based on the number of AD medications used and gives a special weight for failure of treatment with ECT (i.e., score of 3) | A retrospective chart review showed an association between higher MGH-s score and worse outcome; reliability has not been studied In a retrospective comparative study, the MGH-s model better predicted nonremission compared with the TRSM. Reliability for these models was not reported. No direct correspondence with ≥2 treatment failures Considers both the number of failed trials and the intensity/optimization of each trial but does not make assumptions regarding a hierarchy of AD classes
Maudsley Staging Model (MSM) Fekadu et al., 2009^46^ Ruhé et al., 2012^44^ | Not dichotomous; gives points per number of prior attempts, duration, symptoms severity, augmentation use, ECT; single score can vary from 3 to 1 | Failure to achieve remission (HAM-D_21_ ≤10) Yes | Maudsley Prescribing Guidelines for estimating minimum effective doses of ADs Augmenting agents: at least 6 weeks ECT: 8-session course Psychotherapy: unable to determine adequacy | Parameters include:; - Duration (1–3 points); - Symptom severity (1–5); - Number of treatment failures (1–7); - Augmentation strategy use (0/1); - ECT use (0/1); Scores:; - Mild (scores=3–6),; - Moderate (scores=7–10); - Severe (scores=11–15) | Only tool with prospective testing showing good prospective validity. Reliability testing has not been reported. In two prospective studies, the MSM score predicted future nonresponse significantly better than the TRSM. The studies did not report reliability. No direct correspondence with ≥2 treatment failures

AD = antidepressant; ATHF = Antidepressant Treatment History Form; ATR = Antidepressant Treatment Response (Questionnaire); CRD = chronic resistant depression; ECT = electroconvulsive therapy: HAM-D = Hamilton Rating Scale for Depression; MAOI = monoamine oxidase inhibitors; MDD = major depressive disorder; MGH-s = Massachusetts General Hospital Staging; MSM = Maudsley Staging Model; SNRI = serotonin-norepinephrine reuptake inhibitors; SSRI = selective serotonin reuptake inhibitors; TCA = tricyclic antidepressant; TRD = treatment-resistant depression; TRSM = Thase and Rush staging model.

Two models are variations on TRSM. The European Staging Model^81^ distinguishes between nonresponse, TRD, and chronic resistant depression. “Nonresponders” are patients who do not respond to one form of treatment; patients are considered treatment resistant after they have a poor response to a second trial with a different class of antidepressant. Further staging depends on the duration of treatment with adequate medication trials. TRD staging ranges from 1 to 5, with resistance beyond 12 months indicating a distinct category—chronic resistant depression. No studies tested the reliability or predictive utility or reliability of this model.

Another model related to the TRSM is the Massachusetts General Hospital Staging model (MGH-s). It is a function primarily of the number of prior antidepressant failures (with no hierarchy of antidepressant classes).^45^ It also considers optimization of treatments, augmentation and combination strategies, and prior failed ECT. Patients receive certain points for these components. The MGH-s produces a continuous score, reflecting the level of treatment resistance. A retrospective chart review showed an association between a higher MGH-s score and worse outcome.^44^ No study has assessed reliability.

The fifth staging model, the Maudsley Staging Method (MSM),^46^ summarizes the TRD stage into a single score, ranging from 3 to 15. Like the other models, MSM considers the number of treatment failures, and it considers augmentation strategies and ECT treatment (as does the MGH-s). Unlike the TRSM, European Staging Model, and MGH-s, however, the MSM includes. two disease characteristics, namely, duration and symptom severity at baseline. This model is the only one with validity assessed with prospective data.^46^ Higher scores for patients were associated with failure to achieve remission; the model correctly predicted treatment resistance in more than 85 percent of cases. Reliability testing has not been reported.

##### Predictive Validity of Staging Models

A recent systematic review compared the predictive utility and reliability of these models. The review noted an evolution from single antidepressant adequacy ratings toward a multidimensional and more continuous, scored staging model that also introduced TRD characteristics (severity and duration). The operationalization criteria improved, and the scoring of different treatment strategies (between/within class switching and augmentation/combination) changed as evidence accumulated. Over time, efforts to validate models improved slightly.

The review identified six studies that had examined the predictive utility of four models: ATHF, TRSM, MGH-s, and MSM. Comparative predictive utility information existed for three models. In a retrospective study, the MGH-s model predicted nonremission better than the TRSM.^44,^ ^82^ The comparative predictive utility evidence has been best assessed for the MSM. In two prospective studies,^44,^ ^46^ the MSM score predicted nonresponse significantly better than the TRSM.

Overall, predictive validity has been assessed best for the MSM model. Still, the evidence base is limited, and the superiority of one model over any other model for use in a clinical setting is uncertain. A recent review of these methods, however, reported that they appear equally valid for documenting treatment failure in depressed patients.^41^

#### Consensus Definition of Treatment-Resistant Depression

##### Determining Consensus

A consensus can be identified in several ways. One approach is to have the strongest evidence base identifying the preferred definition. The limited evidence base available to us, however, precludes this approach. A second way is to have a preponderance of best practice guidelines or consensus statements clearly identify a preferred definition. Most of the available guidelines and consensus statements, however, clearly stated that no widely acknowledged consensus exists about a preferred best definition of TRD, thus precluding this approach too.

A third way is to indicate the approach most frequently reported in the literature or by the guidelines or consensus statements. This approach appears the most feasible given the current state of the evidence. Below, we present the most frequently used definitions employed in systematic reviews addressing TRD and the most frequently reported definitions in guidelines and consensus statements.

##### Finding Consensus in Systematic Reviews

Of the eight systematic reviews since 2005 that directly addressed TRD (Table 5), four defined it as two or more previous treatment failures,^31,^ ^41,^ ^43,^ ^58^ and four defined it as one or more previous treatment failures.^33,^ ^35,^ ^36,^ ^83^ Notably, those systematic reviews considering more invasive or expensive interventions (or both), such as ECT, repetitive transcranial magnetic stimulation (rTMS), or other nonpharmacologic interventions, tended to use the cut-off of two or more failures. By contrast, less invasive interventions, such as medications or psychotherapy, were more likely to use a more stringent cut-off of one or more failures.

Table 5 Definitions of treatment-resistant depression by number of treatment failures and level of consensus: Systematic reviews as source

Number of Treatment Failures | Focus of Systematic Review, Author, Date | Definition of Treatment-Resistant Depression | Consensus of Definition Specifically Stated as Consensus or Was the Most Frequently Used Definition
1 or more | Lamotrigine augmentation, Thomas et al., 2010^32^ | After at least one failed AD trial; patients had not responded to at least a 4-week course of a recommended dose of an AD | Not addressed
1 or more | Psychotherapy, Trivedi et al., 2011^33^ | If patients reported partial or no remission following treatment with an adequate AD dose for ≥6 weeks | No consensus Noted the significant heterogeneity in the definition of TRD as well as in the measures used to determine MDD
1 or more | rTMS, Zhang et al., 2015^35^ | Failure to respond to at least one course of adequate treatment for MDD during the current illness episode | Not addressed Included studies in the meta-analysis had TRD definitions that ranged from failed one or more to four ADs with a duration ranging from 4 to 6 weeks
1 or more | Predictors of nonresponse, De Carlo et al., 2016^36^ | Failure to respond/remit after at least one AD treatment in subjects with a primary diagnosis of MDD; noted that lack of efficacy of the first AD reliably identifies TRD subjects | No consensus
1 or more | Olanzapine/fluoxetine combination, Luan et al., 2017^66^ | Failure of one or more documented historical AD treatments | No consensus Noted the significant heterogeneity in the definition of TRD as well as in the characteristics of patients, duration of treatment, definition of response, and dosage of fluoxetine and olanzapine.
2 or more | Pharmacologic treatments, Berlim et al., 2007^31^ | Six different definitions of TRD were identified. Studies varied from one previous failed AD trial (n=5) to at least two previous trials with medications from different classes (n=8). Also, two studies explicitly included augmenting strategies in their definitions of TRD. The majority of studies did not specifically indicate which AD trials were considered in their definitions of TRD (i.e., those administered only during the current MDE or those given as part of previous episodes too) General consensus (55.3% of studies) was at least two adequate trials of different classes | Yes, a consensus: clinically significant TRD was defined as an episode of major depression that has not improved after at least two adequate trials of different classes of ADs, reflected by the majority of the retrieved studies using this definition (n=26 or 55.3%)
2 or more | Lithium or atypical antipsychotics, Edwards et al., 2013^39^ | Patients with unipolar MDD who have not responded adequately to two or more AD drugs in the current episode | Authors acknowledge “there is much uncertainty regarding what constitutes the definition of TRD and whether or not, for example, a patient with a failure to respond to two antidepressants from the same class could be defined as treatment resistant”
2 or more | Nonpharmacologic interventions for TRD, Gaynes et al., 2011^58^ rTMS, Gaynes et al., 2014^40^ | An episode of MDD for patients who have not recovered following two or more adequate AD medication treatments (at least 4 weeks at an adequate dose per authors), regardless of the class of AD used or whether the treatment failures were required to be in the current episode | Yes, a consensus: two or more treatment failures in the current episode. Recovery is remission. Noted that TRD is a complex phenomenon that encompasses the number of treatment failures, the adequacy of prior treatments, depressive severity, comorbidities (both psychiatric and medical), symptom subtypes, and chronicity
2 or more | Nonpharmacologic treatments for TRD^*^ Washington State Health Care Authority, 2014^41^ | No standard definition of AD failure, but a variety of TRD staging tools provide different ways of assessing the adequacy of prior treatment so that the clinician can determine treatment failure | Majority of studies enrolled patients whose depression had had ≥ 2 AD prior treatment attempts, or reported that patients depression had experienced ≥ 2 AD failures, or reported that the mean number of prior AD failures was > 2
2 or more | Pharmacologic and somatic interventions, Papdimitropoulou et al., 2017^65^ | Failure to respond to ≥2 AD treatment regimens prescribed at adequate dose and duration. | Interventions (and comparators) included in review: SSRIs, SNRIs, TCAs, tetracyclic antidepressants, MAOIs, atypical antidepressants, antipsychotics, OFC, adjunctive use of lithium, triiodothyronine (T3), lamotrigine, ketamine, ECT, and rTMS

* Relevant Systematic Review that did not meet quality criteria but was part of the MEDCAC meeting materials.

AD = antidepressant; ECT = electroconvulsive therapy; MAOI = monoamine oxidase inhibitor; MDD = major depressive disorder; MDE = major depressive episode; OFC = olanzapine/fluoxetine combination; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SSRI = selective serotonin reuptake inhibitor; SNRI = serotonin-norepinephrine reuptake inhibitor; TCA = tricyclic antidepressant; TRD = treatment-resistant depression.

Three of the systematic reviews identified a similar consensus definition of MDD. It involved patients depression who had not achieved remission following two or more adequate antidepressant medication treatments (at least 4 weeks at an adequate dose per authors).^31,^ ^40,^ ^41,^ ^58^ The requirement for failure to occur following medication from two different antidepressant classes, as opposed to merely two different antidepressants, varies by systematic review.

##### Finding Consensus in Guidelines or Other Materials

Of the 13 guidelines or consensus statements that directly addressed TRD, 8 defined it as two or more previous treatment failures,^23,^ ^38,^ ^42,^ ^67,^ ^69,^ ^70,^ ^74,^ ^79^ 1 defined is as a single failure,^68^ and 1 defined it as three or more failures.^21^ Details are in Table 6, which is ordered by the number of required treatment failures and then chronologically by source.

Three guidelines did not provide a definition. One referred to TRD but never defined it.^19^ One considered stages of treatment resistance (rather than a dichotomous definition) based on the number of prior treatment failures. For example, Stage 1 indicates failure to achieve response after one course of adequate treatment, and Stage 2 indicates failure to achieve response after two courses of adequate treatment, and so on.^64^ One concluded that the concept of TRD should not be used.^72^ The latter guideline had previously used a dichotomous definition of two or more failures. However, the authors explained that because of the absence of evidence indicating a natural distinction between patients with one or two treatment failures and those without, as well as the pejorative nature of the term “treatment-resistant depression” for patients, they recommended a model addressing inadequate response by considering sequenced treatment options.

##### Summary of Consensus Findings

In summary, the majority of systematic reviews and guidelines or consensus statements reported that the most commonly used definition is patients whose depression does not remit following two or more treatment attempts of an adequate dose and duration. We found no agreement as to whether the treatment attempts require different classes of antidepressants. Similarly, the literature produces no agreement of how to define adequate dose and duration, although minimum duration tends to be cited as 4 weeks.

Table 6 Definitions Of Treatment-Resistant Depression And Level Of Consensus By Number Of Treatment Failures: Guidelines And Consensus Statements As Source

Number of Treatment Failures as a Consensus | Focus of Guideline or Consensus Statement, Author, Date | Definition of Treatment-Resistant Depression | Define Failure | Current Episode? | Define Adequate Dose? | Define Adequate Duration? | Consensus? | Specifically Stated or Most Frequently Used Definition?
1 or more | International Workshop on “Present and Future of TMS: Safety and Ethical Guideline” Rossi et al., 2009^68^ | Patients with medication-refractory unipolar depression who failed one good (but not more than one) pharmacological trial | Not found | Not found | Not found | Not found | Yes | Report is from a consensus conference for TRD about when rTMS should be offered
2 or more | World Federation of Societies of Biological Psychiatry Guidelines for Unipolar Depression Bauer et al., 2009^67^ | Patients who remain depressed and do not achieve adequate relief and a satisfactory level of functioning even after two or more adequate courses of treatment. Having failed to improve after two adequately performed trials of AD drug; these no-responders are considered “treatment resistant.” | Patient is not showing any improvement after 4 weeks of treatment with an AD drug at an appropriate dose | Not found | Not found | At least 6 weeks, and 8 to 10 weeks | No | Reports the most commonly used definition. Notes that there is no clear consensus which strategy should be favored for the non-responding patient since to date no rigorous trial with a randomized, double-blind design has been conducted to answer this question.
2 or more | Unipolar Depression Guideline Harter et al., 2010^70^ | In therapy-resistant depression (where pharmacotherapy has been administered adequately, with at least two drugs, one after the other, at a sufficiently high dosage and given for a long enough time interval), patients should be offered appropriate psychotherapy | Not found | Not found | Not found | Not found | Yes | Proposed a definition for when psychotherapy should be offered
2 or more | Institute for Clinical and Economic Review ICER) Coverage Policy Analysis, 2012^38^ | Notes that definitions of so-called “treatment-resistant” depression vary; this generally refers to patients with persistent depression after attempted management with two or more medications | Failure to evoke a clinically significant and lasting response | Not found | Not found | Not found | No | Reports the most commonly used definition
2 or more | Report from European Medicines Agency consensus meeting in 2009—Improving outcomes in TRD Schlaepfer et al., 2012^69^ | CHMP has stated that a patient is considered to be therapy resistant when consecutive treatment with two antidepressants of different classes (different mechanism of action), used for a sufficient length of time and at an adequate dose, fail to induce an acceptable effect. CHMP also notes that the definition of TRD itself is not always consistent between studies or treatment guidelines, and a clear definition would go some way to refining treatment options. | Not found | Not found | Not defined and consensus from the wider psychiatric community is still required | Not defined and consensus from the wider psychiatric community is still required | Yes | Cites the CHMP (EMA) definition. Some staging models have been used to define TRD, but further clinical validation is needed. In addition, true pharmacological resistance needs to be distinguished from resistance attributable to ongoing somatic or psychosocial problems
2 or more | British Association for Psycho-pharmacology Guidelines for all depressive orders, revision based on 2012 consensus meeting Cleare et al., 2015^79^ | Most describe it as a failure to respond to two or more adequate AD treatment trials | Lack of improvement (defined as at least a 20% to 30% reduction in HAM-D in different studies) at 4 and 6 weeks; only 20% and 10%, respectively, will go on to eventual response (≥50% improvement) at 8 weeks | Important to consider the current episode in the context of the overall history of depression and the nature of previous episodes when considering treatment options | Adequate treatment, defined as “recommend ed therapeutic dose” | 4–8 weeks | No | Reports the most commonly used definition. Notes that problems arise in defining what comprises an adequate treatment trial, which drugs are to be included and in taking account of psychological treatments.
2 or more | VA/DoD Clinical Practice Guidelines for Management of MDD, 2016^23^ | Lack of full response despite at least two adequate treatment trials | Lack of full response to an adequate treatment trial | Not found | Not found | Not found | Yes | Guideline says there is consensus
2 or more | CANMAT Guidelines, 2016 Kennedy et al., 2016^74^ Pharmacological treatments Psychological treatments Parikh et al., 2016^75^ Neuro-stimulation treatments Milevet al., 2016^76^ CAM treatments Ravindran et al., 2016^77^ Special populations: youth, women, and the elderly MacQueen et al., 2016^78^ | Notes that the most commonly employed definition is inadequate response to 2 or more AD drugs | Inadequate response (e.g., 25%-49% reduction in symptom scores) or no response (e.g., <25% reduction) | Not found | Not found | Not found | No | Reports the most commonly used definition Notes that the commonly applied definition does not take into account adjunctive strategies and does not differentiate between patients who have had partial response versus those who have had no response
2 or more (MDD: ≥2; Bipolar I: ≥2 [specific treatments specified], Bipolar II: ≥2 [specific treatments specified]) | Australian and New Zealand clinical practice guidelines for mood disorders Malhiet al., 2015^42^ | MDD: Lack of improvement following adequate trials of two or more ADs Bipolar I depression: Failure to reach remission with adequately dosed lithium or to other adequate ongoing mood-stabilizing treatment, plus lamotrigine or with full-dose quetiapine as monotherapy Bipolar II depression: Failure to reach remission with adequately dosed lithium or other adequate ongoing mood-stabilizing treatment, plus lamotrigine or with full-dose quetiapine as monotherapy | Failure to reach remission with adequate dose | Not found | Not found | 6 weeks of treatment | Ye | Provides several definitions depending on the underlying mood disorder
3 or more, 3 different classes | ICSI, Guidelines for adult depression in primary care Trangle et al., 2016^21^ | Defines true treatment resistance Failure to as failure to achieve remission achieve with an adequate trial of therapy remission and three different classes of AD drugs at adequate duration and dosage | Failure to achieve remission | Not found | Not found | Not found | No | Identifies a definition for primary care clinicians “True treatment resistance is seen as occurring on a continuum, from failure to reach remission after an adequate trial of a single [AD drug] to failure to achieve remission despite several trials of [AD drugs] augmentation strategies, ECT and psychotherapy.”
Did not specifically address | American Psychiatric Association guideline for the treatment of MDD Gelenberg et al., 2010^19^ | Frequently uses the term “treatment-resistant” but never defines it; refers to “next steps” in treatment | Not found | For rTMS, FDA says individuals with MDD who have not had a satisfactory response to at least one AD trial in the current episode of illness | Not found | Not addressed for TRD; generally, adequate treatment with an AD medication for at least 4–6 weeks For psychotherapy, a few months | No | Not found
Did not specifically address | NICE Depression Guidance, 2009^71^ NICE VNS Guidance, 2009^73^ NICE rTMS Guidance 2015^71^ Various guidelines concerning depression, use of vagal nerve stimulation, and use of rTMS | Did not define Earlier NICE guidelines had referred to TRD defined as depression that had not responded adequately to two courses of AD drugs (of adequate dose and length) The current guideline groups preferred to approach the problem of inadequate response by considering sequenced treatment options rather than by a category of patient | Does not clearly define; refers to Inadequate response, which could reflect both lack of response and lack of remission, and considers both patient and clinician perspectives | Not found | Not found | Not found | No. NICE eschews use of the term “treatment-resistant depression” | Previous versions of the guidelines stated that the most commonly used definition was nonresponse to two or more adequate trials of ADs. Due to this definition not including psychotherapeutic treatment, non-antidepressant augmenting agents and psychosocial factors, the new guidelines use a sequence of treatment options rather than number of failures.
Did not specifically address | Unipolar depression Ontario Health Association, 2016^64^ | Considers stages of treatment resistance (e.g., Stage 1 indicates failure to achieve response after one course of adequate treatment; Stage 2 indicates failure to achieve response after two courses of adequate treatment) | Cannot achieve remission | Cites FDA definition for rTMS: Treatment of adult patients with unipolar depression whose current episode did not respond to one adequate dose of AD medication | Not found | Long enough to take effect, at least 2 weeks or 10 sessions | No | Does not identify the most commonly used definition Notes that definition of adequate response ranges from failure to achieve response to failure to achieve full symptom remission and that most experts agree that inadequate response is the failure to achieve full symptom remission

AD = antidepressant; CAM = complementary and alternative medicine; CANMAT = Canadian Network for Mood and Anxiety Treatments; CHMP = Committee for Medicinal Products for Human Use; ECT = electroconvulsive therapy; EMA = European Medicines Agency; FDA = Food and Drug Administration; HAM-D = Hamilton Depression Rating Scale; ICER = Institute for Clinical and Economic Review; ICSI = Institute for Clinical Systems Improvement; MDD = major depressive disorder; NICE = National Institute for Health and Clinical Excellence; rTMS = repetitive transcranial magnetic stimulation; TMS = transcranial magnetic stimulation; TRD = treatment-resistant depression; VA/DoD = Department of Veterans Affairs and Department of Defense; VNS = vagus nerve stimulation.

## Key Question 2 Diagnostic Tools to Identify TreatmentResistant Depression in Clinical Research

Drawing from the same sources used in KQ 1, we address three questions below:

- What methods do investigators use to diagnose this condition in clinical research?
- What consensus, if any, exists about the best measure(s) to use?
- Does the setting of the medical visit influence the choices that investigators make about the diagnostic tool they use?

### Key Points

1. Methods used to diagnose TRD in clinical research
  a. Emphasize careful, structured clinical confirmation of a current major depressive episode as a part of MDD or bipolar disorder based on the Diagnostic and Statistical Manual of Mental Disorders (DSM), International Classification of Diseases (ICD), or Research Diagnostic Criteria (RDC) criteria; this diagnosis could be through a standard clinical evaluation or a through a more-structured clinical assessment (Mini International Neuropsychiatric Interview, Structured Clinical Interview for the DSM, or Schedule for Affective Disorders and Schizophrenia)
  b. Further entail collecting a careful history before treatments (e.g., the number of prior pharmacologic attempts of adequate dose and duration that did not produce remission) or administering a structured, staging tool (Antidepressant Treatment History Form [ATHF], TRSM, MGH-s, or MSM) to confirm treatment resistance.
  c. Differ by how structured the assessment is (from standard clinical assessment to highly structured research tool); this factor affects feasibility
  d. Have a limited evidence base for validity and reliability
2. No consensus on or any preferred tool exists for making the diagnosis for various reasons:
  a. No validation of the standard clinical assessment of TRD (as compared with a more in-depth evaluation)
  b. Limited evidence base for structured tools
  c. Available tools (from standard clinical assessment to highly structured research tool) appear equally valid for diagnosing TRD
  d. No direct comparison of careful history with structured tool
  e. The clinical setting (e.g., psychiatric vs. primary care) has no influence on choice of diagnostic tool, although some issues of feasibility arise; no direct comparison exists of a careful history versus use of a structured tool.

### Detailed Synthesis

Table 7 shows the variety of methods that clinical researchers have used to diagnose TRD. We relied for this analyses on all types of source publications. Some publications focused on TRD without clarifying how the investigators defined the condition. We discuss below the publications or materials that did provide some information about approaches to diagnosing TRD.

Table 7 Diagnostic Approaches to Treatment-Resistant Depression

Topic; Authors and Year of Publication Topic | Methods Used to Diagnose Treatment-Resistant Depression | Comments
Diagnosis and definition of TRD Fava et al., 2003^45^ | Recommended using clinician-rated instruments, ideally a structured clinical interview Prospective assessment better than retrospective. No preferred specific instruments for diagnosing TRD prospectively. If retrospective, recommend either the clinician-rated ATHF, the clinician-rated HATH, or the self-rated ATRQ. Of these three instruments, only one, the ATHF, has been empirically validated via prospective treatment outcome reports. | Not a systematic review
SR of RCTs on “the meaning of TRD” Berlim et al., 2007^31^ | Clinical confirmation by mental health professional using DSM, ICD, or RDC criteria; structured interviews involving MINI, SCID, or SADS Most studies did not describe how they confirmed the degree of treatment resistance; 10 of 46 studies (22%) described how they determined resistance, and 4 of 46 (9%) used a formal tool | Emphasis is on use for research setting
Bauer et al., 2009^67^ World Federation of Societies of Biological Psychiatry Guidelines for Unipolar Depression | None listed; emphasizes thorough clinical assessment | Does not directly address TRD issues for these components
Maudsley Staging Method (MSM) Fekadu et al., 2009^46^ | ICD-10 or DSM-IV, plus MSM to determine resistance | Notes that a key shortcoming of staging models is reliance on a single criterion, mainly treatment response. This is the explanation of the MSM.
Consensus Statement from the International Workshop on “Present and Future of TMS: Safety and Ethical Guideline,” Siena, Italy Rossi et al., 2009^68^ | None listed | Consensus statement about using rTMS
American Psychiatric Association guideline Gelenberg et al., 2010^19^ | Does not directly address diagnosis of TRD; emphasizes diagnosis with thorough clinical examination based on standard guidelines (DSM) | A guideline for MDD, not TRD, but description of next step management approaches to depression overlaps some with TRD
Guidelines on unipolar depression Harter et al., 2010^70^ | Does not directly address diagnosis of TRD; emphasizes diagnosis with thorough clinical examination based on standard guidelines (ICD) | None
SR on lamotrigine augmentation in MDD Thomas et al., 2010^32^ | MDD diagnosed by DSM, ICD, or RDC criteria; did not specify how treatment resistance was determined, accepted what study authors reported as TRD | The SR included only one RCT. Subjects were inpatients who became outpatients.
SR on TRD Gaynes et al., 2011^58^; rTMS article from SR TRD Gaynes et al., 2014^40^ | Clinical diagnosis of MDD with failure to achieve remission after 2 AD treatments; no specific diagnostic tools described | SR of psychopharmacologic and nonpsychopharmacologic interventions
SR of psychotherapy Trivedi et al., 2011^33^ | Clinical assessment of MDD per DSM and HAM-D_17_ ≥14, or HAM-D_17_≥16, or MDD per Schedule for Affective Disorder, or BDI ≥15 + 1 failed AD trial (defined as HAM-D_17_≥14, or HAM-D_17_≥11, or HAM-D_17_≥8, or BDI ≥9; or MDD on Structured Clinical Interview for DSM or on Revised Clinical Interview Schedule) | Significant heterogeneity in the definition of TRD and the measures used to determine MDD Involved patients from both a psychiatric and a medical clinic, with an emphasis on providing information relevant to primary care patients
ICER Coverage Policy Analysis, 2012^38^ | Clinical diagnosis per DSM of MDD that persists after two or more AD treatment attempts | Coverage policy compared rTMS with ECT
Report from European Medicines Agency consensus meeting in 2009—Improving outcome in TRD Schlaepfer et al., 2012^69^ | Emphasizes clinical confirmation of MDD, describes a variety of TRD definitions, noting that CHMP (of the EMA) has stated that a patient is considered to be therapy resistant when consecutive treatment with two ADs of different classes (different mechanism of action), used for a sufficient length of time and at an adequate dose, fail to induce an acceptable effect | Mentions that often the first depression treatment is in primary care and the patient does not get to a psychiatrist until TRD Another important question is the definition of an adequate AD trial, defined as an appropriate drug given in a dosage and duration sufficient to produce a response
SR on staging methods for TRD Ruhé et al., 2012^44^ | Five staging models were considered: ATHF, TRSM, ESM, MGH-s, and MSM. | Emphasizes the need for careful assessment to include assessing psychiatric comorbidity
SR on lithium or atypical antipsychotics in management of TRD Edwards et al., 2013^39^ | Used DSM for clinical diagnoses and defined as failure to respond to two or more ADs in the current episode of depression | SR of lithium or antipsychotics
Review of literature on defining TRD Trevino et al., 2014^18^ | A comprehensive diagnostic evaluation for MDD, possibly including a standardized measure, used before a patient is classified as having TRD | Authors distinguished between resistance and pseudo-resistance
Nonpharmacologic treatments for TRD Washington State Health Care Authority, 2014^41^ | Emphasizes clinical assessment and confirmation of failure to remit Notes that several formal staging systems have been developed for systematically quantifying treatment resistance in terms of not only the number of prior failures but also whether previous treatment was adequate. These include the Antidepressant Treatment History Form (ATHF), the Maudsley Staging Method (MSM), the Massachusetts General Hospital Scale, and the Thase and Rush Scale. | Notes scores for TRD in staging models lower in primary care settings, suggesting a lower likelihood of TRD there SR of nonpharmacologic interventions for TRD (does not meet quality criteria)
Australian and New Zealand Clinical Practice Guidelines for Mood Disorders Malhiet al., 2015^42^ | Implies clinical diagnosis using accepted diagnostic criteria (DSM, ICD) + failure to respond to at least one course of adequate treatment for MDD during the current illness episode | Implies importance of clinical diagnosis
British Association for Psychopharmacology Guidelines for all depressive orders, revision based on 2012 consensus meeting Cleare et al., 2015^79^ | Implied clinical diagnosis using accepted diagnostic criteria (DSM, ICD), plus clinical assessment to determine degree of resistance | Guideline for psychopharmacology in MDD directly addresses TRD
NICE rTMS Guidance, 2015^71^ NICE Depression Guidance, 2010^72^ NICE VNS Guidance, 2009^73^ | Emphasizes clinical assessment and monitoring | Does not support use of TRD term
SR and meta-analysis of use or TMS Zhang et al., 2015^35^ | Diagnosis of adult MDD based on the DSM-IV, DSM-III, or DSM-III-R or the ICD-9 or ICD-10 criteria, plus either a HAM-D or MADRS score exceeding a threshold | None
CANMAT Guidelines, 2016: Kennedy et al., 2016^74^ Pharmacological Treatments Parikh et al., 2016^75^ Psychological Treatments Milev et al., 2016^76^ Neurostimulation Treatments Ravindran et al., 2016^77^ Complementary and Alternative Medicine Treatments MacQueen et al., 2016^78^ Special Populations: Youth, Women, and the Elderly | Implied importance of clinical diagnosis by experts plus (most commonly) inadequate response to trials of two or more AD drugs | Did not directly address diagnosis for TRD
SR of predictors of nonresponse De Carlo et al., 2016^36^ | A primary MDD diagnosis according to DSM or ICD criteria, plus a failure of at least one previous AD trial | The association between presence of psychiatric comorbidities and increased risk of TRD suggests the importance of a thorough psychiatric assessment to include comorbid anxiety, anxiety disorders, substance use disorders, and personality disorders
SR on rTMS for unipolar depression Ontario Health Association, 2016^64^ | Implied clinical assessment of MDD, plus not achieving remission after at least one course of AD treatment | Compared rTMS and ECT
ICSI, Adult Depression in Primary Care (Guideline) Tranger et al., 2016^21^ | Clinical assessment per DSM plus failure to achieve remission with an adequate trial of therapy and three different classes of AD drugs at adequate duration and dose | Referral or co-management with mental health specialty clinician if patient has inadequate treatment response; inadequate treatment not defined
Clinical practice guidelines for management of MDD VA/DoD, 2016^23^ | Emphasized clinical assessment plus at least two adequate treatment trials and lack of full response to each | Consider referral to mental health specialist if more severe symptoms or if no remission after 8 to 12 weeks of second treatment using a first-line AD drug
SR and MA of olanzapine/fluoxetine combination Luan et al., 2017 (#2603) | Accepted individual study authors determination that patients were diagnosed with TRD | None
SR of pharmacologic and somatic interventions Papadimitropoulou et al., 2017^65^ | Did not clarify any tool; required adult MDD patient who failed to respond to ≥2 AD treatment regimens prescribed at adequate dose and duration | Used network meta-analysis

AD = antidepressant; ATHF = Antidepressant Treatment History Form; ATRQ = Antidepressant Treatment Response Questionnaire; BDI = Beck Depression Inventory; CANMAT = Canadian Network for Mood and Anxiety Treatments; CER = comparative effectiveness review; CHMP = Committee for Medicinal Products for Human Use; DSM = Diagnostic and Statistical Manual of Mental Disorders; ECT = electroconvulsive therapy; EMA = European Medicines Agency; ESM = European Staging Model; HAM-D = Hamilton Rating Scale for Depression; HATH = Harvard Antidepressant Treatment History; ICD = International Classification of Diseases; ICER = Institute for Clinical and Economic Review; MA = meta-analysis; MADRS = Montgomery-Asberg Depression Rating Scale; MDD = major depressive disorder; MGH-s = Massachusetts General Hospital Staging model; MINI = Mini International Neuropsychiatric Interview; MSM = Maudsley Staging Model; NICE = National Institute of Health and Clinical Evidence; RCT = randomized controlled trial; RDC = Research Diagnostic Criteria; rTMS = repetitive transcranial magnetic stimulation; SADS = Schedule for Affective Disorders and Schizophrenia;; SCID = Structured Clinical Interview for the DSM; SR = systematic review; TRD = treatment-resistant depression; TRSM = Thase and Rush Staging Model; VA/DoD = Department of Veterans Affairs and Department of Defense.

#### Methods Used to Diagnose Treatment-Resistant Depression in Clinical Research

Diagnosing TRD is a three-step process: (1) confirmation of MDD (or, less commonly, a bipolar disorder diagnosis), (2) subsequent determination of a degree of resistance meeting threshold criteria for TRD definition, and (3) confirmation that the patient is currently depressed. The tools used to diagnose TRD in clinical research involve the same approaches as outlined for KQ 1 (see Table 7).

For confirmation of an MDD, the literature emphasizes careful, structured clinical assessment and diagnosis of MDD. Nearly all reviews used a clinical confirmation based on widely accepted diagnostic criteria (DSM, ICD, or RDC) or a structured diagnostic assessment (Mini International Neuropsychiatric Interview, Structured Clinical Interview for the DSM, or Schedule for Affective Disorders and Schizophrenia). A single review addressing psychotherapy for TRD accepted a Hamilton Rating Scale for Depression-17 item version (HAM-D_17_) ≥16 or a Beck Depression Inventory ≥9 for a diagnosis.^33^ All guidelines and consensus statements described clinical confirmation using diagnostic criteria.

Determining whether the depressive illness met criteria for TRD involved two main steps. The first entails collecting a careful history before treatments (e.g., the number of prior pharmacologic attempts of adequate dose and duration that did not produce remission). The second or alternative tactic involves administering a structured, staging tool (ATHF, TRSM, MGH-s, or MSM) to assess the spectrum of resistance. The systematic and nonsystematic reviews generally did not describe or did not use formal instruments to clarify treatment resistance, although some reviews recommended using a structured instrument to confirm.^44,^ ^45^

Confirming that a patient was currently depressed in systematic or nonsystematic reviews involved primarily scoring above a particular threshold on a validated depression monitoring tool, such as the HAM-D or the Montgomery-Åsberg Depression Rating Scale (MADRS). In consensus statements or guidelines, clinical confirmation of a current depressive episode was based on standard clinical assessments.

As noted in KQ 1, the evidence base for validity and reliability of these diagnostic tools is limited.

#### Consensus on Best Measure for Diagnosing Treatment-Resistant Depression in Clinical Research

No consensus exists on the best measure for diagnosing TRD; the limited evidence does not provide much guidance. As noted in KQ 1, the MSM has evidence supporting its prospective predictive validity in TRD populations in general;^46^ the ATHF has evidence of prospective predictive validity but only in populations having received ECT.^44^ The MGH-s has retrospective chart review evidence of an association between higher resistance and worse outcomes.^44^

A systematic review of the staging models described for KQ 1 noted that, despite validation of the MSM, further investigation of the reliability and predictive utility of TRD staging models and additional disease characteristics is required.^44^ Correct staging of TRD might improve generalizability of results from clinical studies and improve delivery of care to TRD patients. Limitations of the current validation studies are small sample sizes, the use of chart review methodology, and the potential nongeneralizability of their findings to less severe or outpatient populations.^44^

At present, no staging model for TRD seems to be both applicable in clinical practice and valid for research purposes; using such models would facilitate the generalization of research findings from studies addressing TRD and next-step strategies. An effective staging model must be user-friendly for busy clinicians, clear, and able to predict the likelihood of remission in an objective manner. Such a model would help clinicians plan treatment, inform their patients adequately, and judge the merits of new therapies for TRD.

#### Influence of Setting on Choice of Diagnostic Tool

The available evidence does not indicate a preferred or recommended tool for diagnosing TRD in primary care settings. One systematic review looking at the use of psychotherapy in TRD considered trials in both psychiatric and primary care settings, with an aim of providing evidence for primary care clinicians and patients.^33^ The authors did not, however, distinguish between diagnosing TRD in those two settings. A second TRD systematic review noted that scores for TRD in staging models were lower in primary care settings, suggesting a lower likelihood of TRD there.^41^

Two guidelines addressed management of TRD in primary care settings.^21,^ ^69^ Both indicated that TRD can be confirmed in primary care or mental health settings but that mental health settings may be indicated for subsequent TRD management.

## Key Question 3 Success or Failure of Treatment in Clinical Studies of Treatment-Resistant Depression

This is a complex question for this chapter. It entails synthesizing information on the measures that researchers might use to determine the success and failure of treatment for TRD patients. Of particular interest is assessing the severity of depression. Among the questions are whether experts agree about such measures, whether they are reported by patients or clinicians (typically, physicians), and whether we can document their psychometric properties and find information about minimally significant clinical differences. Also of concern is whether and, if so, how well such measures describe a wide array of clinical, quality-of-life, or behavioral variables.

### Key Points

1. No consensus exists regarding the best measures to use.
  a. Tools have not been created specifically for TRD measurement.
  b. Both patient-reported and clinician-administered measures are available for each category of outcomes; we found no stated preference for one type over the other, although patient-reported tools are more feasible to use.
  c. The most commonly reported depression-specific measure is the HAM-D. Although we detected no strong consensus on a preferred instrument, experts appear to agree that the preferred outcome is remission (complete recovery as measured by a score below a threshold) using a standardized and validated measure (regardless of the tool).
  d. General psychiatric status measures were infrequently described; most commonly reported was the Clinical Global Impression (CGI).
  e. Various functionality scales have been reported, but none is the most commonly used.
2. Most measures have adequate psychometric properties.
  a. All depressive-specific measures have been validated and have acceptable psychometric properties.
  b. For general psychiatric measures, the CGI has clinical utility and has been validated, but disagreement exists about its degree of validity.
  c. Functional impairment tools have been validated and have acceptable psychometric properties.
3. The minimum significant clinical difference (minimally clinically important difference, or MCID) has been defined for many of these measures. Experts disagree about which measure is preferred and, for a specific measure, which difference best accounts for a minimum clinically significant change.

### Detailed Synthesis

Tables 8^,^9, and 10 show the variety of depressive-specific, general psychiatric, and functioning or quality-of-life measures, respectively, described in our eligible sources. This review is not meant to be comprehensive, and it reflects what reviews generally report about the instruments. For example, we did not assess the evidence base for the range of scores reported on particular instruments (e.g., what is a mild vs. moderate vs. severe depressive severity) or the quality of the evidence base for the instruments’ psychometric characteristics. Rather, we list what prior summaries or articles have reported. Below, we review the outcomes identified in our search for the three main issues for this question.

#### Assessing Depression (or Treatment-Resistant Depression) and Severity of Symptoms

Table 8 documents several key variables or descriptors for assessing depression, including severity, in TRD patients. (The distinction here is with KQ 2, which is concerned more with diagnosis per se.) In all, we identified seven different types. These methods are grouped, first, as all patient-reported measures (e.g., Beck Depression Inventory [BDI], with two versions, through the Patient Health Questionnaire. These are followed by measures that are either clinician-reported (i.e., HAM-D and the MADRS) or can be both clinician reported and patient self-report (Quick Inventory of Depressive Symptomatology [QIDS-CR and QIDS-SR, respectively]).

Table 8 Measures to Test Depressive Severity in Treatment-Resistant Depression

Brief Description | Physician or Patient Reported Scale Scores | Psychometric Properties | Minimally Important Clinical Differences | Comments
BDI Beck Depression Inventory Assesses severity of depressive symptoms; not appropriate for diagnosis 21 items Two major revisions since 1961 origin: BDI-IA in 1979 and the BDI-II, in 1996, which replaced 4 items to align with DSM-IV MDD^84^ | Patient reported BDI-II Scale:; - 0–13: no depression; - 14–19: mild depression; - 20–28: moderate depression; - 29–63: severe depression^85,^ ^86^ | BDI: Convergent validity—with clinical ratings: 0.72; with HAM-D: 0.73^87^ BDI (based on 4 studies); - Sensitivity: 0.85 (95% Cl, 0.79 to 0.90); - Specificity: 0.83 (95% Cl, 0.70 to 0.91)^72^; BDI-II: Internal consistency: 0.9 (range 0.83 to 0.96)^85^ BDI-II: Retest reliability: ranged from 0.73 to 0.96^85^ | BDI-II: Change of >5 is clinically significant, although smaller changes should be considered for MCID^88^ (anchor based) BDI-II sensitive to change in depression in cross-cultural studies (anchor based):; - 5-point = MCID; - 10–19 points = moderate change; - ≥20 points to a large change^86^ | High reliability, capacity to discriminate between depressed and nondepressed subjects Improved concurrent, content, and structural validity BDI-II: endorsed by NICE for use in primary care for measuring baseline depression severity and responsiveness to treatment^89^ BDI and MADRS similar in differentiating between different Axis-I diagnoses and sensitivity to change during antidepressive treatment (MADRS-S focuses on core depressive symptoms, whereas BDI is more sensitive to maladaptive personality traits)^90^ BDI and MADRS highly intercorrelated (r=0.869), note tested in samples of psychiatric patients with prominent psychiatric symptomatology and has not been evaluated in those with milder symptoms^90^
CES-D Center for Epidemiological Study—Depression Scale Assesses severity of depressive symptoms in community populations; not appropriate for diagnosis Developed by NIMH in 1977 20-item tool most commonly used, although other versions range from 4 to 16 items | Patient self-report Score: Scores range from 0 to 60, with high scores indicating greater depressive symptoms; - ≥16 is cutoff for clinical depression^91^; - Optimal cutoff score for clinically relevant depression: 22^92^ | Based on 8 studies: Sensitivity: 0.84 (95% Cl, 0.78 to 0.89) Specificity: 0.74 (95% Cl, 0.65 to 0.81)^72^ High internal consistency: coefficient a: range from 0.85 in general population to 0.90 in a psychiatric population^84^ Moderate correlation (0.49) between CES-D and clinical interview ratings of depression^93^ | None reported^94^ | None
GDS Geriatric Depression Scale Screening test for depression in elderly patients Long version: 30 items; short version: 15 items | Patient self-report Score:; - 0: no depression; - 30: severe depression for long form, 15 for short form; Scores; - 1–10 normal; - ≥11 possible depression or ≥14 avoids false-positives^95^; GDS website:; - 0–9 = normal,; - 10–19 = mild depression,; - 20–30 = severe depression; Short form:; - >5 suggests depression; - >10 indicates highly likely depression; Other studies of medical patients suggest cutoffs at 5–7^96-100^ | High internal consistency (reliability): Cronbach’s α: 0.94^101^ but others have reported 0.87 for long form and 9.76 for short form^102^ From multiple studies:; - Long form: range from 0.69–0.99^103^; - Short form: 0.74–0.86^100,102^; Short form: Using a cutoff score of 6 differentiates between depressed and nondepressed elderly primary care patients:; - Sensitivity = 0.81; - Specificity = 0.75^100^; Based on analysis of 11 studies:; - Sensitivity = 0.87 (95% Cl, 0.80 to 0.91); - Specificity = 0.75 (95% Cl, 0.69 to 0.80)^72^; Meta-analysis of primary care patients for diagnostic accuracy: Long form:; - Sensitivity = 77.4%; - Specificity = 65.4%; Short form:; - Sensitivity = 81.3%; - Specificity = 78.4%; Percentage correctly identified:; - GDS30: 71.2%; - GDS15: 77.6%; a significant difference (chi^2^= 24.8; p<0.0001)^104^ Correlation between GDS and HAM-D: 0.83^84^ | None reported^94^ | Distinguishes symptoms of depression and dementia
HAM-D Hamilton Rating Scale for Depression Assesses symptom severity; Not designed as a diagnostic instrument but is used to assess efficacy of treatment Multiple versions: Originally 21 items; Reduced to 17 when 4 items dropped owing to lack of construct validity. 17-item version most commonly used (maximum score is 54) Subsequently expanded to 24 or 28 items | Clinician rating Reported ranges of severity vary. For 17-item version:; - 0–6: no depression; - 7–17: mild depression; - 18–24: moderate depression; - 24: severe depression^105^; or:; - <8:none; - 8–13: mild; - 14–19: moderate; - 20–25: severe; - >25: very severe; Score ranges for other versions of the HAM-D:; - HAM-D_21_:0 to 64; - HAM-D_24_: 0 to 75^58^ | Validity: HAM-D_17_ with MADRS^105^ Convergent validity: Adequate Discriminant validity: Adequate.^106^ HAM-D score significantly correlated with each of the 8 SF-36 subscales^107^ Good internal, interrater, and retest reliability estimates for the overall scale across many studies, but weak interrater and retest coefficients at the item level. Convergent, discriminant, and predictive validity were good (other studies found coefficients ranging from 0.83 to 0.94)^108^ Interrater reliability of the scale proved consistent, exceeding 0.85^109^ | In MDD population, MCID (distribution based):; - HAM-D_17_ of ±27.1% ±25.7% change; - HAM-D_21_ of ≥27% ±25.1% change; - HAM-D_24_ of 28% ≥ 25.2% change^110^ | Requires a trained rater with sufficient knowledge of the instrument and the symptoms of the depressive syndrome^108,^ ^111^ Main limitations of HAM-D_17_ include:; - failure to include all symptom domains of MDD; - presence of items measuring different constructs uneven weight attributed to different symptom domains^105^
MADRS Montgomery-Åsberg Depression Rating Scale 10 items | Clinician reported Score; - ≤10 = no depression (or remission); - >30 (or sometimes 35) = severe depression^105^; MADRS ≤ 5 equals complete or symptom-free remission (CGI-S = 1) MADRS ≤11 equals remission (CGI-S <2)^94^ | Very high internal consistency High correlation with HAM-D Did not differ according to sensitivity to change during antidepressant treatment | MCID: Ranges from 1.6 to 1.9 (distribution based, using the standard error of measurement)^112^ | A HAM-D_17_ score of 7 corresponded to an 8 or 9 on the MADRS; the MADRS is said to be superior to the HAM-D17 in the conduct of clinical trials^113^
PHQ, PHQ-9 Patient Health Questionnaire Screening tool, by itself not appropriate for diagnosis Based on PRIME-MD and DSM MDD diagnosis Used in a primary care setting, designed both to indicate the likelihood of a depressive episode and to characterize the severity of depression | Patient reported Scale: 1–4: minimal depression 5n9: mild depression 10–14: moderate depression 15–19: moderately severe depression 20–27: severe depression^114^ | From 11 studies, threshold of ≥10: Sensitivity: 0.82 (95% Cl, 0.77 to 0.86) Specificity: 0.83 (95% Cl, 0.76 to 0.88)^72,115^ Validity: Comparable to the larger, clinician-administered screening instrument PRIME-MD^116^ Internal consistency: Cronbach’s α: 0.89 and 0.86^117^ Based on 11 studies: Sensitivity: 0.82 (95% Cl, 0.77 to 0.86) Specificity: 0.83 (95% Cl, 0.76 to 0.88)^72^ In a sample of 7% prevalence of major depression, interviews with mental health providers demonstrated a positive predictive value ranging from 31% for a PHQ-9 cutoff of 9 to 51% for a cutoff of 15^117^ | Individual change: estimated as 2 standard errors of measurement—5 points on the 0 to 27 point PHQ-9 scale^118^ (distribution based) | Endorsed by the VA and NICE
QIDS-CR16, QIDS-SR16 Quick Inventory of Depressive Symptomatology Based on DSM MDD diagnosis | Clinician rated Patient self-report Score:; - 1–5: no depression; - 6–10: mild; - 11–15: moderate; - 16–20: severe; - 21–27: very severe | Limited study of sensitivity/specificity; ≥13 (in primary care medical patients): Sensitivity: 76.5% Specificity: 81.8%^119^ Cronbach’s α:; - SR: 0.69 to 0.89; - CR: 0.65 to 0.87^120^; Correlated moderately to highly with several depression severity scales: Of 7 pooled studies, QIDS-SR16: correlated with the HAM-Dt_17_(r = 0.76, Cl 0.69 to 0.81) Convergent validity with the QIDS-CR16^120^ | PGI-I minimally improved = QIDS-SR of ≥28.5% ± 28.7% change^110^ (distribution-based) | None

BDI = Beck Depression Inventory; CES-D = Center for Epidemiological Study—Depression Scale; CGI = Clinical Global Impression; CI = confidence interval; DSM = Diagnostic and Statistical Manual; GDS = Geriatric Depression Scale; HAM-D = Hamilton Rating Scale For Depression; MADRS = Montgomery-Åsberg Depression Rating Scale; MCID = minimally clinically important difference; MDD = major depressive disorder; NICE = National Institute of Health and Care Excellence (UK); NIMH = National Institute of Mental Health; PGI-I = Patient Global Impression of Improvement; PHQ = Patient Health Questionnaire; PRIME-MD = Primary Care Evaluation of Mental Disorders; QIDS = Quick Inventory of Depressive Symptomatology; VA = Department of Veterans Affairs.

More questionnaires or measures are patient self-report than otherwise. Several of these have more than one version (typically a traditional “long” version and one or more versions with fewer items). For example, the clinician-reported HAM-D has five versions that differ by numbers of items (17-, 21-, 24-, 25-, and 28 -item versions), of which the HAM-D_17_ is generally the most frequently applied.

Some have a history dating back two decades or more and thus have long histories of use for several purposes but usually not for making a definitive clinical diagnosis. Some assess depression severity, some are used as screening tools, some are based on a DSM definition (usually DSM-IV); and some are described explicitly as not intended to be diagnostic. All are suitable for use in trials or nonexperimental studies for the purposes intended (measuring severity, evaluating outcomes).

Information describing the scales and their psychometric properties is generally reported in the literature in some detail, although such data are often spread over multiple articles. Less is known about MCIDs; when such data have been reported at all, different investigators based their MCIDs on different methods (i.e., anchor based or distribution based). Generally, the reliability and validity statistics (i.e., psychometric properties) for most of these measures are sufficient for group comparisons; some are sufficiently high to permit comparisons of individuals. In the literature we reviewed, no psychometric assessments were assessed in a TRD population.

Although we identified a variety of potential tools for assessing severity or outcomes, investigators and other experts generally agreed that remission was the treatment goal. However this might be measured by a standardized and validated tool, this was the clear preferred outcome.

#### Assessing General Psychiatric Illness and Severity

Two other questionnaires—the CGI and the Brief Psychiatric Rating Scale (BPRS) —qualify as appropriate and adequate measures of the presence or severity of psychiatric illness broadly defined. Both are clinician rated. Table 7 provides information on these, although neither can be said to be “better” than the other. The CGI has two versions: CGI-I relates to improvement (reflecting change in status from an initial assessment), and the CGI-S reflects the severity of the psychiatric condition (reflecting status at each assessment). Both have acceptable psychometric properties. The BPRS can also be used to evaluate suicidality. Scores from the BPRS have been calibrated against those from the CGI, presumably allowing some cross-walk between studies using one or the other.

Table 9 Two measures to assess general psychiatric illness severity

Brief Description | Physician or Patient Reported Scale Scores | Psychometric Properties | Minimally Important Clinical Differences
BPRS Brief Psychiatric Rating Scale | Clinician rated Score: Depressive mood: 1: not present 2: very mild 3: mild 4: moderate 5: moderately severe 6. severe 7: extremely severe Same scores for suicidality | Adequate psychometric properties^121,490-4^ CGI approximately corresponded to BPRS total score; - Mildly ill: 31; - Moderately ill: 41; - Markedly ill: 53; Minimally improved score of 53, CGI score associated with BPRS reductions of 24, 27% and percentage BPRS reductions of 24, 27, and 30% at weeks 1, 2, and 4, respectively. Corresponding numbers for a CGI rating of “much improved”: 44, 53, and 58%^122^ | CGI-I of “minimally improved” = BPRS reduction of 24% at week 1,27% at week 2, and 30% at week 4 (anchor based) CGI rating of “much improved” = BPRS reduction of 44% (week 1), 53% (week 2), and 58% (week 4) (anchor based)^122^
CGI Clinical Global Impression Scale Assesses clinician’s impression of patient’s illness severity; used before and after treatment | Clinician rated Scores range from; - 1 = not ill at all; - to; - 7 = among the most extremely ill^123^ | Improvement ratings strongly related to both concurrent severity of illness and changes in severity of illness ratings from baseline Both CGI ratings positively correlated with both self-report and clinician-administered measures of social anxiety, depression, impairments, and quality of life. | CGI-I of “minimally improved” is considered the clinical gold standard for minimum clinically important difference

BPRS = Brief Psychiatric Rating Scale; CGI = Clinical Global Impression Scale; CGI-I = Clinical Global Impression Scale-Improvement;

#### Assessing Functional Impairment in Treatment-Resistant Depression

The last main concern for KQ 3 involves how to assess functional impairment in TRD patients. Functional impairment tends to be broadly defined: enjoyment of or satisfaction with life, impairments in a wide array of daily activities or relationships, several domains of health status (which can be collapsed into self-reports of physical or mental health), or overall levels of disability. Of the five measures available for this task, four are self-reported and one is clinician reported.

The four patient-reported measures generally have appropriately strong psychometric properties, and one or more produce scores that are calibrated against scores of other measures (chiefly those for evaluating severity of depression). Only two, however, have reported MCIDs specifically for MDD (the Quality of Life Enjoyment and Satisfaction Questionnaire and the SDS).

For the clinician-rated tool, the DSM-IV had advised use of the Global Assessment of Functioning (GAF) scale assessing a patient’s overall psychological functioning (Axis V). The American Psychiatric Association, however, discontinued use of the GAF in the DSM-5, and the American Psychiatric Association now suggests that clinicians use the World Health Organization Disability Assessment Schedule (WHODAS 2.0) as a measure of disability.^124^

#### Examining Minimal Clinically Important Differences

Most measures have adequate psychometric properties. All depressive-specific measures have been validated and have acceptable psychometric properties as reflected in measures of internal consistency, convergent validity, test-retest reliability, and correlation with other instruments to assess depressive severity (Table 6). The idea of an MCID is increasingly salient for addressing these issues. (It is also referred to as “clinically relevant,” “clinically significant,” or “minimum important difference.”) The concept refers to the minimum change in a measurable outcome in which the patient or clinician perceives a difference because of a therapy or intervention. It has evolved as a practical means of giving clinical relevance to changes in standardized instrument scores when no gold standard of meaningful change exists.^125^

Two types of techniques, an anchor-based approach and a distribution-based method, have been used to calculate the MCID. Anchor-based methods use a measure with established or face-value clinical meaning such as the CGI-S to “anchor” scores on the measure of interest; distribution-based methods generally use the statistical characteristics of the sample such as the standard deviation to separate “signal” from “noise.”^125^

In TRD, this concept applies most directly to depressive-specific measures. Although MCIDs have been defined for various depressive measures, no clear agreement exists about what constitutes a minimum clinically significant difference or how to determine it. For example, some users define such a difference as a numerical change in a score reflected by a standardized mean difference (e.g., HAM-D difference of 7 points).^126^ Other researchers define it by how a change on a depressive measure scale (e.g., HAM-D) aligns with a clinician’s perception of improvement (e.g., CGI).^126^ Yet others suggest that a patient’s perception of clinical improvement is the preferred standard.^127^ Finally, some report this difference as a percentage change in score, with varying percentages reported as clinically meaningful.^94^

General psychiatric measures can also be used as a measure of minimum significant clinical difference (Table 7). The CGI-I, for example, has such an assessment built into its scale; a CGI-I rating of 3 indicates that the patient has “minimally improved,” as contrasted with either “no change” or “moderately improved,” This tool often functions as the gold standard against which other measures of a minimal degree of clinical improvement are compared. The Patient Global Impression of Improvement (PGI-I), a patient analogue to the CGI-I, has a similar range and minimal improvement score (e.g., PGI-I = 3 indicates “a little better”). The BPRS does not have a directly analogous score, but percentage of change in BPRS at a particular time (e.g., 24% change at week 1, 27% change at week 2, or 30% change at week 4) has been associated with a CGI-I of 3.^122^ The discrete psychometric properties of these instruments have been less studied, because they often are used as the clinical reference standard against which other measures are compared. Their accuracy is supported primarily by their consistency with each other.^122^

For functionality and quality-of-life measures, psychometric properties appear adequate (Table 9). We could not find reports of MCIDs for GAF, SF-36 Health Survey, or WHODAS tools. We did identify MCID measures for the SDS (~4 points for the overall score and 1 point for each individual item score)^128^ and for the Q-LES-Q (mean percentage score change of 10.69).^129^

Table 10 Five measures to assess functional impairment in treatment-resistant depression

Brief Description | Physician or Patient Reported Scale Scores | Psychometric Properties | Minimally Important Clinical Differences
GAF Global Assessment of Functioning Scale | Clinician reported Scale:; - 0–100; - ≤50 = severe symptoms and/or psychosocial dysfunction; - 51–60 = moderate scores,; - 61–70 = mild scores; - ≥71 = absent or only transient symptoms and/or minimal dysfunction^130^ | Not well validated^131^ 1 validation study identified^132^ | None identified for MDD
Q-LES-Q Quality of Life Enjoyment and Satisfaction Questionnaire Assesses the degree of enjoyment and satisfaction in the past week Regular form: 93 items Short form: 16 items (adults only) | Patient self-report Scale: 1 to 5 Maximum total score across 14 items for short form =70 Higher scores indicate greater enjoyment and satisfaction with specific items in instrument^133,^ ^134^ | Short form significantly correlated with the CGI-S^135^ High test-retest reliability, sensitivity, and responsiveness: Item correlations with total score: 0.41–0.81^135^; - Sensitivity: 80%; - Specificity: 100%; - Internal consistency and test-retest coefficients: 0.9 and 0.93^135^; Remission scores of 6 on the MADRS correlate with the Q-LES-Q SF score of 58+/-10%^136^ | A “minimally improved” assessment on the CGI-I scale = the mean % of the maximum Q-LES-Q short form score change of 10.69 overall (anchor based)^129^
SDS Sheehan Disability Scale Assesses functional impairment in work/school, social, and family life 3 items using a 10-point visual analog scale | Patient self-report Scale:; - 0 = unimpaired; - 1–3 = mild impairment; - 4–6= moderate impairment; - 7–9= marked impairment; - 10= extreme impairment; Maximum summed total measure = 30 highly impaired ^133,137^ Patients who score 5 or greater on any of the 3 scales are associated with significant functional impairment^121^ | Sensitivity: 83% Specificity: 69%^121^ | ~4 points for total score and 1–2 points for an item score (anchor based)^128^
SF-36 Health Survey^138^ 8 scales that can be combined into two summary measures: physical health and mental health 36 generic, self-reported items organized into 8 domains | Patient self-report Each scale is directly transformed into a 0–100 scale, each question carrying equal weight. The higher the score the less disability (0= maximum disability and 100 = disability). | Validated Version 2.0 of the instrument was released in 1996 A shorter version, the 12-Item Short Form Health Survey (SF-12) was developed for the MOS, a multiyear study of patients with chronic conditions | None identified for MDD
WHODAS World Health Organization Disability Assessment Schedule Featured in the new DSM-5, for use in initial patient interview and for monitoring treatment progress. Not intended to be used as the sole basis for a diagnosis Adult self-administered version has 36 items; a shorter version has 12 items | Patient-self report | WHODAS 2 (12 item): Reported to be a reliable, valid, and useful tool for assessing overall disability in primary care patients with depression; showed adequate internal consistency (α = 0.89) and construct validity because is significantly associated with quality of life and depression severity (convergent validity) and able to discriminate between patients on sick leave and those who are working^124^ | None identified for MDD

CGI-I scale = Clinical Global Impression-Improvement; CGI-S = Clinical Global Impression-Severity; GAF = Global Assessment of Functioning Scale; MADRS = Montgomery-Asberg Depression Rating Scale; MDD = major depressive disorder; MOS = Medical Outcomes Study; Q-LES-Q = Quality of Life Enjoyment and Satisfaction Questionnaire; Q-LES-Q SF = Quality of Life Enjoyment and Satisfaction Questionnaire Short form; SDS = Sheehan Disability Scale; SF-12 = 12-Item Short Form Health Survey; SF-36 = 36-Item Short Form Health Survey; WHODAS = World Health Organization Disability Assessment Schedule.

## Key Question 4 Types of Research Designs to Study Treatment-Resistant Depression

### Key Points

1. Most investigators and expert groups preferred randomized designs over nonexperimental ones as a means of minimizing bias.
2. Most of the available literature did not address, or apparently achieve consensus about, designs that might minimize placebo effects.
3. No consensus was seen about the appropriate or necessary length of trials or other studies of TRD. A study length of “at least 6 weeks” was often recommended; however, experts often noted that longer trials or studies would be preferable.
4. Studies also recommended using whole structured clinical interviews to diagnosis depression, because these full assessments could better confirm the MDD (or bipolar) diagnosis and clarify psychiatric comorbidity, seen as a key potential confounder in TRD treatment trials.
5. Getting patients to an adequate dose of a given medication may take a few weeks; for that reason, 6 weeks of adequate dosing may require a trial length longer than 6 weeks.
6. Compliance and consideration of prior psychotherapy use are important to assess and control for in analyses.

### Detailed Synthesis

#### Types of Research Designs Used in Various Types of Studies or Projects

Table 11 records recommendations about research designs from numerous expert panels, groups doing systematic reviews (with or without meta-analyses), and research teams examining definitions of TRD or conducting trials or other studies of treatments for TRD. The table lists sources in chronological order.

Table 11 Summary of research design information

Topic; Authors and Year of Publication | Research Designs Used | Consensus on Study Design to Minimize Bias | Consensus on Study Design to Minimize Placebo Effect | Consensus on Length of Antidepressant Trials
Definition and epidemiology of TRD Fava, 1996^30^ | RCTs (type unspecified) | Preferred randomized design | Did not address | Recommended study duration: at least 6 weeks
Sequential strategies for AD nonresponders Thase and Rush, 1997^5^ | RCTs (double blind) RCTs (open label) RCTs (type unspecified) NRCTs Prospective cohort studies Retrospective cohort studies Cohort studies (type unspecified) | Preferred randomized design | Did not address | Recommended study duration: at least 4 weeks
Definition and meaning of TRD Sackeim, 2001^37^ | Did not address | Preferred randomized design | Did not address | Noted that little consensus exists and that some suggest 8 weeks or longer
Diagnosis and definition of TRD Fava, 2003^45^ | Refers to “studies” but does not specify types | Did not address | Did not address | Recommended study duration: at least 6 weeks, maybe longer
SR of RCTs—what is the meaning of TRD Berlim and Turecki, 2007^31^ | RCTs (type unspecified) | Preferred randomized design Recommended use of prospective study designs and validated instruments | Did not address | Recommended study duration: at least 6 weeks Noted that 4 weeks was likely too short and that ideal duration could be even longer than 6 weeks
Maudsley Staging Method Fekadu et al., 2009^46^ | RCTs (type unspecified) Retrospective cohort studies | Did not address | Did not address | Recommended study duration: at least 6 weeks
World Federation of Societies of Biological Psychiatry guidelines for unipolar depression Bauer et al., 2009^67^ | RCTs (double blind) RCTs (open label) RCTs (type unspecified) | Preferred randomized design | Did not address | Recommended study duration: at least 6 weeks
NICE VNS Guidance, 2009^73^ NICE Depression Guidance, 2010^72^ NICE rTMS Guidance, 2015^71^ | RCTs (double blind) RCTs (open label) RCTs (type unspecified) Prospective cohort studies SRs and meta-analyses | Preferred meta-analysis or randomized design | Did not address, although mentioned that some clinical trials had a placebo effect | Did not directly address TRD
Consensus Statement from the International Workshop on “Present and Future of TMS: Safety and Ethical Guideline”, Siena, Italy Rossi et al., 2009^68^ | RCTs (type unspecified) NOTE: Did not focus on specific study designs or other issues such as blinding or use of cohorts in this review | Preferred randomized design | Did not address | Did not address
American Psychiatric Association guideline MDD Gelenberg, 2010^19^ | Double-blind RCTs, single-blind RCT, open-label RCT, trials—type not specified, prospective cohort, retrospective chart review, cohort not specified, case-control, meta-analysis, systematic review | Preferred randomized design | Did not address | Recommended 4–8 weeks, consistent with a duration of at least 6 weeks
Guidelines on treatment of unipolar depression Harter et al., 2010^70^ | RCTs (type unspecified) | Preferred randomized design | Did not address | Recommended 4–8 weeks, consistent with a duration of at least 6 weeks
SR on use of lamotrigine in MDD Thomas, Nandhra, and Jayaraman, 201 0^32^ | RCTs (double blind) RCTs (single blind) RCTs (open label) RCTs (type unspecified) CRTs NRCTs Prospective cohort studies Retrospective cohort studies Cohort studies (type not specified) Case-control studies Interrupted time series | Preferred randomized design | Did not address | 4 weeks
SR on TRD therapies Gaynes et al., 2011^58^ Article on use of rTMS article for TRD Gaynes et al.. 2014^40^ | RCTs (double blind), RCTs (single blind), RCTs (open label), RCTs (type unspecified), CRTs NRCTs Prospective cohort studies, retrospective cohort studies Cohort studies (type unspecified) Case-control studies SRs and meta-analysis | Preferred meta-analysis or randomized design | Did not address | Did not address for medication
SR on psycho-therapy Trivedi, Nieuwsma, and Williams, 2011^33^ | RCTs (double blind) RCTs (single blind) RCTs (open label) RCTs (type unspecified) CRTs | Preferred randomized design | Did not address | Recommended study duration should be at least 6 weeks
ICER Coverage Policy Analysis, 2012^38^ | RCTs (double blind) RCTs (type unspecified) Prospective cohort studies | Preferred randomized design | Did not address | Did not address
SR on staging methods for TRD Ruhe et al., 2012^44^ | Did not specify; included RCTs, prospective cohorts, and retrospective chart reviews | Preferred randomized design Recommended use of prospective study designs and validated instruments | Did not address | Recommended study duration: at least 6 weeks
Report from European Medicines Agency consensus meeting in 2009—Improving outcome in TRD Schlaepfer et al., 2012^69^ | RCTs (double blind) RCTs (single blind) RCTs (type unspecified) Meta-analyses | Preferred meta-analyses or randomized design | Did not address | Noted that 4 to 6 weeks is considered to be an adequate trial period to see clinical response, although recent research suggests that longer periods (up to 8 or 12 weeks) may be needed to achieve remission
SR on use of lithium or atypical antipsychotics in managing TRD Edwards et al., 2013^39^ | RCTs (double blind) RCTs (single blind) RCTs (open label) RCTs (type unspecified) CRTs | Preferred randomized design | Did not address | Recommended 4 weeks of treatment
Review of literature on definitions of TRD Trevino et al., 2014^18^ | Did not clarify | Did not address | Did not address | Recommended study duration: at least 6 weeks
Nonpharma-cological treatments or TRD Washington State Health Care Authority, 2014^41^ | RCTs (double blind) RCTs (single blind) RCTs (open label) RCTs (type unspecified) NRCTs Prospective cohort studies Retrospective cohort studies SRs and meta-analysis | Preferred meta-analyses or randomized design Adequate dosage of medication should be at maximum tolerated doses (according to prescription recommendations) Recommended that treatment compliance should be assessed | Did not address | Recommended study duration: at least 6 weeks Noted that standard AD trial of ≥6 weeks is most common
Australian and New Zealand clinical practice guidelines for mood disorders Malhi et al., 2015^42^ | RCTs (double blind) RCTs (type unspecified) | Preferred randomized design | Did not address | Did not directly address TRD Noted that before altering any treatment, allowing a trial of appropriate duration, usually 3 weeks at adequate dosage, is important
British Association for Psychopharmacol ogy Guidelines for all depressive orders, revision based on 2012 consensus meeting Cleare et al., 2015^79^ | RCTs (type unspecified), SR, and meta-analyses | Preferred meta-analysis or randomized design | Did not address | Recommended study duration: at least 4 to 6 weeks of treatment
Predictors of response for use of rTMS Silverstein et al., 2015^34^ | Studies of any design (i.e., experimental and observational) even when a study had no placebo comparison group | Did not address | Did not address | Did not address
SR and meta-analysis of use of rTMS Zhang et al., 2015^35^ | RCTs (double blind) RCTs (single blind) RCTs (open label) RCTs (type unspecified) CRTs | Preferred randomized design | Did not address | Allowed study authors to define, but 8 of 10 studies used ≥ 6 weeks as definition of adequate length
CANMAT Guidelines, 2016 Kennedy et al., 201 6^74^ Pharmacological treatments Parikh et al., 2016^75^ Psychological Treatments Milev et al., 2016^76^ Neuro-stimulation treatments Ravindran et al., 2016^77^ CAM treatments MacQueen et al., 2016^78^ Special populations: youth, women, and the elderly | RCTs (open label) RCTs (type unspecified) SRs and meta-analyses | Preferred randomized design | Did not address | Did not directly address for TRD Implied that at least 4 weeks of adequate treatment are needed
De Carlo, Calati, and Serretti, 2016^36^ Predictors of nonresponse | RCTs (double blind) RCTs (open label) RCTs (type unspecified) NRCTs Prospective cohort studies Retrospective studies Cohort studies (type unspecified) | Preferred randomized design | Did not address | Did not address
SR on use of rTMS in unipolar depression Ontario Health Association, 2016^64^ | RCTs (double blind) RCTs (single blind) RCTs (open label) RCTs (type unspecified) CRTs | Preferred randomized design | Did not address | Did not address
ICSI guideline on adult depression in primary care Trangle et al., 2016^21^ | Placebo-controlled studies, other randomized controlled trials (types unspecified) open label, cohort (type unspecified), meta-analyses, systematic reviews | Preferred randomized design | Did not address | Did not address
Clinical practice guidelines for management of MDD VA/DoD, 2016^23^ | RCTs (double blind) RCTs (type unspecified) Cohort studies (type not specified SRs and meta-analyses | Preferred meta-analyses or randomized design | Did not address | Recommended at least 4 to 6 weeks of treatment
SR and MA of olanzapine/fluoxetine combination Luan et al., 2017^66^ | RCTs (type unspecified) | Preferred randomized design | Did not address | Did not address
SR of pharmacologic and somatic interventions Papadimitro-poulou et al., 2017^65^ | RCTs (triple blind) RCTs (double blind) RCTs (single blind) RCTs (type unspecified) SRs and meta-analyses | Preferred meta-analyses or randomized design | Did not address | Dependent upon intervention, ketamine shows superior efficacy at 2 weeks, others at 4, 6, and 8 weeks

AD = antidepressant; CAM = complementary and alternative medicine; CANMAT = Canadian Network for Mood and Anxiety Treatments; CRT = cluster randomized trial; ICSI = Institute for Clinical Systems Improvement; MA = meta-analysis;; MDD = major depressive disorder; NICE = National Institute of Health and Care Excellence; NRCT = nonrandomized controlled trial; RCT = randomized controlled trial; rTMS = repetitive Transcranial Magnetic Stimulation; SR = systematic review; TRD = treatment-resistant depression; VA/DoD = Department of Veterans Affairs and Department of Defense; VNS = vagus nerve stimulation.

As with other KQs, a couple of the sources in this table are not ones that met our standard inclusion and exclusion criteria specified in the Methods chapter, but we have included them because they were part of materials made available at the April 2016 MEDCAC meeting. In all, the evidence base for KQ 4 includes 36 sources: systematic reviews, nonsystematic reviews, clinical practice guidelines, and other statements from professional societies or regulatory agencies.

#### Consensus About Study Design to Minimize Bias and Placebo Effect

Researchers have used a considerable range of study designs with variably defined study components to examine treatments for TRD or assemble evidence about those interventions (see Table 10). In the midst of this diversity, we encountered a consistent recommendation that the standard use of operationalized TRD definitions and consistent use of validated tools would improve the quality of the evidence base.

Few publications directly addressed the issue, but we detected a general consensus that a prospective, randomized trial design using certain study components best helped minimize bias. Randomized trials of various types, including in a few cases cluster randomized trials or nonrandomized controlled trials, were the preferred study design by the available systematic reviews,^31-36,^ ^39-41,^ ^44,^ ^58,^ ^64-66^ the nonsystematic reviews,^5,^ ^18,^ ^30,^ ^37,^ ^45,^ ^46^ and the guidelines or consensus statements.^19,^ ^21,^ ^23,^ ^38,^ ^42,^ ^67-79^

Some investigators or experts extended their inclusion criteria to accept various nonexperimental (observational) designs of reasonable strength, such as prospective cohort studies. A handful included observational studies that could possibly have been subject to bias from confounding factors. About seven sources included systematic reviews as a research design; some also included meta-analyses.

Similarly, virtually all sources that commented on a preferred study design to minimize bias reflected a consensus that they preferred randomized designs. A few sources specified a preference for use of meta-analyses, including network (i.e., indirect) meta-analyses to enable combining and examining data from trials with both active and inactive comparators.^43^

The literature also emphasized other key study design components to minimize the role of bias. Systematic review of staging methods recommended the use of prospective study designs and validated instruments, where possible.^31,^ ^44^ Studies also recommended using whole structured clinical interviews to diagnosis depression,^31,^ ^44^ because these full assessments could better confirm the MDD (or bipolar) diagnosis and clarify psychiatric comorbidity, seen as a key potential confounder in TRD treatment trials.^36^

Adequate dosage of medication should be at maximum tolerated doses (according to prescription recommendations),^31,^ ^41^ further standardizing the definition. In general, systematic reviews,^31,^ ^41^ nonsystematic reviews,^18,^ ^30,^ ^44-46^ and guidelines or consensus statements^19,^ ^67,^ ^69,^ ^70^ recommended that study duration with adequate dosing should be at least 6 weeks. They also appeared to prefer that remission, operationally defined using a validated instrument, is the preferred outcome.^31,^ ^44^ Systematic reviews emphasized that both compliance and consideration of prior psychotherapy use are important to assess and control for in analyses^31,^ ^41,^ ^44^

At the same time, these sources clearly appreciated that adding the above components risked the feasibility and applicability of these management strategies in real-world settings.^44^

We found nothing mentioned specifically about reducing placebo effect.

#### Trends on Best Study Design to Assess TRD Interventions

Current trends show increased use of traditional study designs. This preference reflects the variability of definitions and study design components and the limited evidence base for standardized, validated instruments to confirm TRD. In the literature we reviewed, we identified no newly emerging designs, although the systematic review for KQs 6 through 11 (next chapter) generally can identify the most current study designs.

#### Consensus on Appropriate Trial Length

Finally, as reported elsewhere, most sources that addressed the issue of trial length for antidepressant medication studies generally took the stance of trial duration being “at least 6 weeks” of a treatment at an adequate dose.^18,^ ^19,^ ^30,^ ^31,^ ^41,^ ^44-46,^ ^67,^ ^69,^ ^70^ Of note, getting patients to an adequate dose of a given medication may take a few weeks; for that reason, 6 weeks of adequate dosing may produce a trial length longer than 6 weeks.

Some groups were comfortable with 4 to 6 weeks’ duration for a drug study; some advocated for or advised longer trials (e.g., 8 to 10 weeks). Yet others commented that the trials needed to provide adequate dosages of the medications in question. Almost one-third of the sources did not deal with this issue at all, however.

## Key Question 5 Risk Factors for Treatment-Resistant Depression

We reviewed all included publications for any reference to risk factors for TRD and abstracted relevant information. These risk factors can be sorted into four main categories: (1) risk factors reflected in TRD definition and staging, (2) sociodemographic risk factors, (3) psychiatric and medical comorbidity, and (4) other clinical variables. We sorted each of those categories by whether the publications were systematic reviews, ostensibly providing the highest quality of evidence; nonsystematic reviews; or guideline or consensus statements. Finally, having TRD can be represented by two different outcomes: failure for a patient with depression either to achieve remission with or to respond to an intervention (because the latter also indicates failure to remit). The literature has reported it both ways. Accordingly, within each cell in the tables below, we identify what is reported about predictors for remission and response, respectively.

### Key Points

1. Although many risk factors are posited for TRD, evidence addressing risk factors for TRD is quite limited.
2. Several components of the TRD definition (disease severity, duration of current episode, number of previous hospitalizations, and number of failed antidepressant trials) appeared to be associated with greater risk of TRD. For example, the probability of responding to an antidepressant declines by a factor of approximately 15 percent to 20 percent for each prior failed drug treatment.
3. The sociodemographic variables of age (older) and marital status (divorced/widowed) increased the risk of TRD.
4. Coexisting anxious symptoms, anxiety disorders, and personality disorders were associated with TRD.
5. Some other clinical characteristics (such as having melancholic features, suicidality) were associated with greater risk of TRD.

### Detailed Synthesis

Tables 12 through15 summarize risk factors associated with TRD. The evidence base, hampered by various definitions of TRD and potential risk factors, is quite limited. In all, the evidence base for KQ 5 includes six separate sources. One recent systematic review provided the most comprehensive summary of risk factors for TRD.^36^

Table 12 reflects the evidence associating the different components of TRD and the presence of TRD itself. Key components of the definition—disease severity, duration of current episode, number of previous hospitalizations, and number of failed antidepressant trials—appeared to be associated with an increased risk of TRD. One guideline noted that the probability of responding to an antidepressant declines by a factor of approximately 15 percent to 20 percent for each prior failed drug treatment.^67^ Failure of a particular class of antidepressant, however, did not appear to be associated with TRD risk. Of note, use of higher doses of antidepressant medication in prior treatment trials was associated with the highest risk of having TRD; however, the need for higher doses is likely a consequence of having TRD rather than a predictor of TRD.

Table 12 Components of definitions of treatment-resistant depression

Topic Authors and Year of Publication Type of Source | Depressive Disease Severity | Duration of Current Episode | Number of Previous Hospitali-zations | Number of Prior (Failed) Treatments | No Treatment Response During First 2 Treatments | Class of Previous Antidepres-sants) | Dose of Previous Antidepres-sant Treatment(s)
Definition and meaning of TRD Sackeim, 2001^37^ Non-systematic review | Not addressed | For remission: Greater duration of current episode associated with lower remission rates For response: Greater duration of current episode associated lower response rates | Not addressed | For remission: Not addressed For response: Greater number of failed AD treatments associated with lower response rates | Not addressed | Not addressed | Not addressed
World Federation of Societies of Biological Psychiatry Guidelines for Unipolar Depression Bauer et al., 2009^67^ Guideline | Not addressed | Not addressed | Not addressed | For remission: Greater number of prior AD attempts associated with decreased remission rates For response: Greater number of prior AD attempts associated with decreased response rates | Not addressed | Not addressed | Not addressed
Predictors of nonresponse De Carlo, Calati, and Serretti, 2016^36^ Systematic review | For remission: Higher baseline severity of depression associated with lower remission rates illness For response: No association with depressive severity | For remission: Evidence not available For response: Longer duration of current episode associated with lower response rates | For remission: Evidence not available For response: Greater number of prior hospitalizations associated with lower response rates | Not addressed | Not addressed | For remission: Mixed results For response: Not addressed | For remission: Weak evidence suggesting higher doses associated with lower remission rates, but high doses may be a consequence of TRD rather than a predictor For response: Higher dose associated with lower response rates, but high doses may be a consequence of TRD rather than a predictor

AD = antidepressant; TRD = treatment-resistant depression.

Table 13 shows the limited evidence regarding associations between sociodemographic risk factors and TRD. Both age, reflected as a continuous variable or as a cut-off of 40 years or older, and being divorced or widowed were associated with a greater risk of TRD. Neither sex nor gender nor race appeared to be clear risk factors.

Table 14 reviews the information regarding medical and psychiatric comorbidities. The limited evidence showed no clear association between medical comorbidities or chronic pain, respectively, and TRD. Particular psychiatric comorbidities, however, were predictors of TRD. Specifically, coexisting anxious symptoms and comorbid anxiety disorders, substance abuse disorders, and personality disorders each were identified as a risk factor for TRD.

Table 15 reports the information regarding other clinical risk factors for TRD. The limited evidence showed two clinical variables were risk factors for TRD as measured by failure to respond: having melancholic features and having suicidality. One review that looked at risk factors for not responding to rTMS indicated that particular genetic polymorphisms appeared associated with the risk of not responding to rTMS.

Table 13 Demographics and related risk factors for treatment-resistant depression

Topic Authors and Year of Publication Type | Age | Female Sex | Marital Status | Nonwhite Race or Ethnicity
De Carlo, Calati, and Serretti, 2016^36^ Predictors of nonresponse Systematic review | For remission: No association between older age and lower remission rates For response: Older age associated with lower rate of response | For remission: No association found between sex and lower rates of remission For response: No association found between sex and lower rates of response | For remission: Being divorced/widowed associated with lower rates of remission For response: No association found between marital status and lower rates of response | For remission: Inconclusive evidence For response: Inconclusive evidence
SR on rTMS Ontario Health Association, 2016^64^ Systematic review | For remission: Age ≥40 years associated with lower remission rates after rTMS treatments For response: Not addressed | Not addressed | Not addressed | Not addressed

rTMS = repetitive transcranial magnetic stimulation; SR = systematic review

Table 14 Medical and psychological comorbidities as risk factors for treatment-resistant depression

Topic Authors and Year of Publication Type | Coexisting Medical Comorbidities | Coexisting Psychiatric Comorbidities | Chronic Pain
Definition and Epidemiology of TRD Fava and Davidson, 1996^30^ Nonsystematic review | For remission: Not addressed For response: While frequently cited as a potential risk factor, there is no clear evidence that medical comorbidity is associated with decreased response rates | For remission: Not addressed For response: Substance abuse and even moderate consumption of alcohol have been associated with poorer response to antidepressant treatment Comorbid personality disorders have also been associated with decreased response rates in some but not all studies | Not addressed
Predictors of Nonresponse De Carlo, Calati, and Serretti, 2016^16^ Systematic review | For remission: No association between comorbid medical diagnoses and reduced remission rates For response: No association between comorbid medical diagnoses and response rates | For remission: Anxious symptoms associated with lower remission rates, whereas anxiety disorders did not show a clear association A personality disorder diagnosis was also associated with lower remission rates For response: Anxiety symptoms and anxiety disorders were associated with lower response rates A personality disorder was associated with a lower response rate | For remission: No association between pain and reduced remission rates For response: No association between pain and reduced response rates

TRD = treatment-resistant depression.

Table 15 Relationship between other clinical characteristics and treatment-resistant depression

Topic Authors and Year of Publication Type or Topic | MDD Onset Before Age 20 | Family History of Depressive Disorder | Melancholic Features | Suicidal Risk or Behavior | Other Clinical Characteristics
Predictors of response for rTMS Silverstein et al., 2015^34^ Systematic review | Not addressed | Not addressed | Not addressed | Not addressed | For remission: Not addressed For response: Association of genetic polymorphisms with decreased rate of response following rTMS treatment
Predictors of nonresponse De Carlo, Calati, and Serretti, 2016^36^ Systematic review | For remission: No association between onset of first episode and lower remission rates For response: No association between onset of first episode and lower response rates | For remission: No association between family history of mood disorders and lower remission rates For response: No association between family history of mood disorders and lower response rates | For remission: No association between melancholic features and lower remission rates For response: Having melancholic features increased the likelihood of nonresponse | For remission: No association between increased suicidality and lower remission rates For response: Increased suicidality was associated with lower response rates | Not addressed

MDD = major depressive disorder; rTMS = repetitive transcranial magnetic stimulation.

## Key Question 6 Patient Characteristics, Approaches to Prior Treatments as Inclusion Criteria, and Elements of Diagnostic Assessments

### Description of Included Studies

Our searches identified 163 unique studies (in 197 publications) of interventions in TRD populations. We divided interventions into four categories: (1) brain stimulation treatments (BST), which included electroconvulsive therapy (ECT), repetitive transcranial magnetic stimulation (rTMS), vagal nerve stimulation, and deep brain stimulation (73 studies); (2) pharmacotherapy, including ketamine (71 studies); (3) psychotherapy (11 studies); and (4) complementary and alternative medicine (CAM) therapies and exercise (8 studies).

Below we report on patient and study characteristics overall and by treatment-specific categories. Certain characteristics may change based on study intervention (e.g., participants in a study of ECT may be systematically different from those in a trial of psychotherapy). We give tables with counts for most subsections below; notable exceptions and trends not captured in tables are presented in the text.

### Key Points

1. Confirmation of TRD for study entry was often poorly described.
2. The HAM-D and the Montgomery—Åsberg Depression Rating Scale were commonly used to set minimum depressive severity thresholds for study entry; most studies involved patients with moderately severe depression.
3. Studies were inconsistent about the necessary duration of prior treatment attempts for study entry.
4. Most studies required at least one and often two prior failed treatment attempts of adequate therapy.
5. Several patient characteristics were rarely considered for study entry: duration of depressive symptoms, prior depressive relapses, prior treatment intolerance, prior augmentation or combination therapy, prior psychotherapy, and suicidality.

### Detailed Synthesis

#### Patient Characteristics Related to Inclusion or Exclusion

##### Age

Nearly all studies included participants ages 18 years or older, although four studies (pharmacology only) limited enrollment to participants 60 years or older (Table 16). Fifty studies (31%) used a maximum cutoff of 65 years of age. Forty studies (25%) did not report age criteria; 38 studies (23%) did not report an age limit for inclusion. Most studies reported a mean age between 50 and 60 years.

Table 16 Number of studies reporting maximum age for study enrollment

Age | BST | Psychotherapy | Pharmacology | CAM/Exercise
Maximum
60 | 1 | 0 | 0 | 2
65 | 12 | 5 | 30 | 3
70 | 9 | 0 | 1 | 1
75 | 4 | 2 | 6 | 0
80 | 1 | 0 | 3 | 1
85 | 3 | 0 | 1 | 0
No maximum age | 15 | 3 | 19 | 1
No age reguirements reported | 28 | 1 | 11 | 0

BST = brain stimulation therapy; CAM = complementary and alternative medicine.

##### Type of Depressive Episode

Of 163 studies, 154 (95%) included any patients with unipolar MDD. Forty-five (28%) studies included patients with both unipolar and bipolar disease (37 BST, 6 pharmacotherapy, 2 CAM/exercise). Nine (6%) studies included only patients with bipolar disease (2 BST, 6 pharmacology, 1 CAM/exercise).

Most studies excluded patients with psychotic depression; rarely were other specific types of depression considered (Table 17). Three studies included patients with double depression (MDD plus antecedent dysthymia). Two studies of bipolar depression excluded patients with rapid cycling disease. One trial excluded patients with seasonal affective disorder and depression secondary to a medical condition. One trial reported rates of dysthymia and schizoaffective disorder.

Table 17 Number of studies considering depressive episode type for study inclusion

Type of Depressive Episode | BST | Psychotherapy | Pharmacology | CAM/Exercise
Psychotic
Inclusion | 0 | 0 | 1 | 0
Exclusion | 34 | 11 | 50 | 7
Just reported | 10 | 0 | 4 | 0
Not considered | 29 | 0 | 16 | 1
Atypical
Inclusion | 0 | 0 | 1 | 0
Exclusion | 2 | 0 | 1 | 0
Just reported | 0 | 0 | 7 | 0
Not considered | 71 | 11 | 62 | 8
Chronic
Inclusion | 3 | 5 | 3 | 0
Exclusion | 1 | 1 | 0 | 0
Just reported | 5 | 1 | 11 | 0
Not considered | 71 | 11 | 62 | 8
Melancholic
Inclusion | 0 | 0 | 0 | 0
Exclusion | 0 | 0 | 0 | 0
Just reported | 4 | 0 | 10 | 0
Not considered | 69 | 11 | 57 | 8
Catatonic
Inclusion | 0 | 0 | 0 | 0
Exclusion | 0 | 0 | 1 | 0
Just reported | 0 | 0 | 1 | 0
Not considered | 73 | 11 | 69 | 8
Postpartum
Inclusion | 0 | 0 | 0 | 0
Exclusion | 0 | 0 | 3 | 0
Just reported | 0 | 0 | 2 | 0
Not considered | 73 | 11 | 66 | 8

BST = brain stimulation therapy; CAM = complementary and alternative medicine.

##### Number of Depression Relapses and Time to Relapse

Only a single trial considered number of depression relapses, a specific subtype of failed treatment where a patient has a depressive episode that remits only briefly and then returns before full recovery occurs, as an inclusion criterion. No study either considered time to relapse as an inclusion criterion or reported on it.

##### Psychiatric Comorbidities

Most studies did not name psychiatric comorbidities as inclusion criteria, although some studies did report on the number of included participants with other psychiatric disease. More frequently, investigators used coexisting psychiatric illnesses as exclusion criteria; substance abuse was the most frequently noted exclusion (Table 18). Many studies named specific disorders for exclusion; some studies more generally excluded any type of psychiatric comorbidity or any other Axis I disorders that were present. Fewer than three studies listed any Axis II disorders generally or attention deficit/hyperactivity disorder specifically as exclusion criteria (not included in table).

Table 18 Number of studies considering comorbid psychiatric diagnoses as exclusion criteria

Other Psychiatric Diagnoses | BST | Psychotherapy | Pharmacology | CAM/Exercise
Studies with any general or specific psychiatric comorbidity exclusion | 49 | 11 | 57 | 8
Any psychiatric comorbidity | 5 | 0 | 2 | 2
Any general Axis I disorder | 6 | 0 | 13 | 0
Anxiety disorders | 6 | 1 | 8 | 1
PTSD | 9 | 1 | 12 | 1
Substance abuse | 42 | 10 | 46 | 7
Eating disorder | 3 | 1 | 8 | 0
OCD | 4 | 1 | 10 | 0
Psychotic disorders | 18 | 4 | 23 | 1
Any personality disorder | 18 | 4 | 23 | 1

BST = brain stimulation therapy; CAM = complementary and alternative medicine; OCD = obsessive-compulsive disorder; PTSD = post-traumatic stress disorder.

##### Medical Comorbidities

Many studies (n=66) potentially excluded participants at the discretion of the investigators, most often because of serious or unstable medical conditions that would have limited participation or involvement in study procedures; examples include ECT or exercise (Table 19). Infrequently cited exclusion criteria (e.g., fewer than 5 studies each) included stroke or transient ischemic attack, multiple sclerosis, Huntington’s chorea, cranial mass, orthopedic injuries including head trauma, and glaucoma (not listed in table).

Table 19 Number of studies considering comorbid medical diagnoses as exclusion criteria

Other Medical Diagnoses | BST | Psychotherapy | Pharmacology | CAM/Exercise
Studies with any general or specific medical comorbidity exclusion | 58 | 7 | 49 | 8
Unspecified serious or unstable medical conditions | 27 | 2 | 31 | 6
Unspecified neurological disorders | 28 | 1 | 3 | 1
Seizure disorders | 22 | 0 | 12 | 3
Other cognitive abnormalities | 31 | 6 | 22 | 0
Cardiac disease | 7 | 0 | 8 | 0
Renal disease | 0 | 0 | 2 | 0
Diabetes | 2 | 0 | 0 | 0
Pregnancy | 8 | 0 | 21 | 1
Abnormal laboratory test results | 0 | 0 | 12 | 3
Pacemakers or metal implants | 13 | 0 | 1 | 0

BST = brain stimulation therapy; CAM = complementary and alternative medicine.

##### Suicidal Ideation and Suicide Attempts

Only one trial specifically included patients with acute suicidality. Fifty-eight studies excluded patients with current suicidal ideation, and 11 studies excluded patients with recent suicide attempts. Seven studies reported only the presence of suicidal ideation among participants; 15 studies reported on prior suicide attempts among participants (Table 20).

Table 20 Number of studies considering suicidal ideation and prior suicide attempts as inclusion or exclusion criteria or reporting on these events

Suicide Ideation or Attempts | BST | Psychotherapy | Pharmacology | CAM/Exercise
Ideation
Inclusion | 0 | 0 | 0 | 0
Exclusion | 18 | 5 | 31 | 4
Just reported | 0 | 0 | 7 | 0
Not considered | 55 | 6 | 33 | 4
Attempts
Inclusion | 0 | 0 | 1 | 0
Exclusion | 7 | 1 | 3 | 0
Just reported | 4 | 3 | 8 | 0
Not considered | 32 | 7 | 59 | 8

BST = brain stimulation therapy; CAM = complementary and alternative medicine.

##### Duration of Symptoms

Most studies (n=126) did not consider duration of symptoms for study inclusion or exclusion. As shown in Table 21, 22 studies (14%) required a minimum symptom duration for inclusion; eight studies (5%) defined both minimum and maximum durations for inclusion. The mean minimum duration of symptoms ranged between 2 months (pharmacology) and 12 months (BST and psychotherapy). The mean maximum duration of symptoms ranged between 12 and 18 months, with a notable exception for BST interventions (51 months).

Table 21 Number of studies specifyinq required symptom duration for study inclusion

Symptom Duration | BST | Psychotherapy | Pharmacology | CAM/Exerciser
Minimum but no maximum | 11 | 4 | 6 | 1
Maximum but no minimum | 2 | 1 | 1 | 0
Both minimum and maximum | 2 | 0 | 5 | 1
Not considered | 57 | 6 | 57 | 6

BST = brain stimulation therapy; CAM = complementary and alternative medicine

#### Instruments to Make a Diagnosis of Depression and Rate Severity

Across all studies, research teams used a total of 12 tools to rate depression severity; the HAM-D was most frequently used (Table 22). Although investigators did not use any of these tools to make a formal diagnosis of depression, they often used them to set thresholds for study inclusion (e.g., HAM-D > 20). Additionally, researchers used many of these tools to measure baseline characteristics and to measure study outcomes.

##### Diagnostic Tools to Confirm a Diagnosis of Depression

In addition to unstructured clinical assessments, investigators used three structured diagnostic tools to confirm the diagnosis of depression: the Diagnostic and Statistical Manual of Mental Disorders (DSM) checklist, the Mini International Neuropsychiatric Interview (MINI), and the Structured Clinical Interview for DSM (SCID) (Table 23). Some studies combined more than one method (e.g., unstructured clinical assessment plus MINI).

Table 22 Number of studies using depression screening instruments for study inclusion

Screening Instrument | BST | Psychotherapy | Pharmacology | CAM/Exercise
HAM-D (all) | 38 | 7 | 29 | 4
HAM-D_17_ | 22 | 4 | 22 | 4
HAM-D_21_ | 10 | 2 | 7 | 0
HAM-D_24_ | 5 | 1 | 0 | 0
HAM-D_28_ | 1 | 0 | 0 | 0
IDS/QIDS (all) | 0 | 0 | 12 | 2
IDS-C_30_ | 0 | 0 | 4 | 0
QIDS-C_16_ | 0 | 0 | 4 | 0
QIDS-SR_16_ | 0 | 0 | 4 | 2
BDI | 0 | 4 | 0 | 0
MADRS | 14 | 0 | 16 | 1
CGI (all) | 5 | 1 | 8 | 0
CGI-S | 5 | 1 | 4 | 0
CGI-I | 0 | 0 | 4 | 0
GAF | 2 | 1 | 0 | 0
No screening tool | 20 | 1 | 14 | 1

BDI = Beck Depression Inventory; BST = brain stimulation therapy; CAM = complementary and alternative medicine; CGI = Clinical Global Impression Scale (S= severity, I = improvement); GAF = Global Assessment of Functioning Scale); HAM-D = Hamilton Rating Scale for Depression; IDS = Inventory of Depressive Symptomatology (C = clinician rated, SR = self-rated); MADRS = Montgomery–Åsberg Depression Rating Scale; QIDS = Quick Inventory of Depressive Symptomatology (C = clinician rated, SR = self-rated).

Table 23 Numbers of studies using tools to confirm depression diagnosis

Tools to Confirm Diagnoses | BST | Psychotherapy | Pharmacology | CAM/Exercise
Structured DSM checklist | 0 | 0 | 6 | 0
MINI | 21 | 2 | 14 | 0
SCID | 17 | 4 | 24 | 5
Unstructured clinical assessment | 36 | 5 | 26 | 3

BST = brain stimulation therapy; CAM = complementary and alternative medicine; DSM = Diagnostic and Statistical Manual; MINI = Mini International Neuropsychiatric Interview; SCID = Structured Clinical Interview for DSM.

Few studies (n=57, 35%) used a standardized definition of TRD to confirm the diagnosis. (These instruments were described in the previous results chapter.) The Antidepressant Treatment History Form (ATHF), which confirms adequate dose and duration, was the most commonly used (Table 24), followed by the Thase and Rush Staging Model (TRSM). The Antidepressant Treatment Response Questionnaire (ATRQ), which systematically clarifies prior pharmacologic use but does not formally stage a depression episode, was reported in eight studies (2 BST and 6 pharmacology). None of the studies we identified for this part of the Technology Assessment used the European Staging Method, the Massachusetts General Hospital staging method (MGH-s), or the Maudsley Staging Method (MSM).

Table 24 Numbers of studies using standardized definitions of treatment-resistant depression to confirm diagnoses

Sources of Standardized Definitions | BST | Psychotherapy | Pharmacology | CAM/Exercise
ATHF | 15 | 1 | 13 | 1
ATRQ | 2 | 0 | 6 | 0
TRSM | 15 | 1 | 3 | 0

ATHF = Antidepressant Treatment History Form; ATRQ = Antidepressant Treatment Response Questionnaire; BST = brain stimulation therapy; CAM = complementary and alternative medicine; TRSM = Thase and Rush Staging Model

##### Prior Treatments as Inclusion Criteria

###### Reporting of Prior Treatments

Of the 163 studies, nearly all (n=157) reported some inclusion criteria concerning prior antidepressant treatments for study entry. Slightly more than two-thirds of studies (n=108) listed a defined duration of prior treatment for study inclusion; by contrast, about 15 percent of studies (n=23) reported prior treatment attempts for study inclusion as adequate (Table 25). Eighteen studies excluded participants with a predefined number of prior failed treatment attempts.

Table 25 Number of studies using reported duration of prior treatment attempts for study inclusion

Length of prior treatment attempts | BST | Psychotherapy | Pharmacology | CAM/Exercise
<4 weeks | 2 | 0 | 0 | 0
4 weeks | 17 | 1 | 16 | 0
5–7 weeks | 24 | 3 | 24 | 1
≥8 weeks | 2 | 4 | 9 | 5
Adequate | 10 | 0 | 12 | 1
Just reported | 1 | 0 | 4 | 0
Not considered | 17 | 3 | 6 | 1

BST = brain stimulation therapy; CAM = complementary and alternative medicine.

Of all 163 studies, 126 (77%) specified a predetermined antidepressant dosage for study inclusion (Table 26), and 99 studies (61%) required both a prespecified prior treatment duration and antidepressant dosage for study inclusion. Finally, 4 studies (3%) required a prespecified dosage but did not consider length of prior treatment attempts.

Table 26 Number of studies using reported duration and dosage of prior treatment attempts for study inclusion

Length of prior treatment attempts | Dosage of prior treatment considered | Dosage of prior treatment not considered
<4 weeks | 2 | 0
4 weeks | 33 | 1
5–7 weeks | 46 | 6
≥8 weeks | 18 | 2
Adequate | 23 | 0
Just reported | 2 | 3
Not considered | 2 | 25
Total | 126 | 37

The most frequent class of antidepressants required for study inclusion comprised the second-generation antidepressants. Monoamine oxidase inhibitors (MAOI) and atypical antipsychotics were the most frequently excluded (Table 27). Often, studies either reported only the antidepressants that participants had used previously or did not report prior treatment medications at all. Table 27 documents the number of studies reporting medication classes that participants had used and whether specific medication classes were only reported or were considered as inclusion or exclusion criteria. These findings are further split by the four main intervention categories (i.e., BST, psychotherapy, pharmacology, and CAM/exercise).

Table 27 Number of studies using various classes of antidepressants attempted for treatment before study inclusion

Trial Intervention and Drug Classes | Inclusion | Exclusion | Only Reported | Not Considered
BST
SSRI | 7 | 1 | 19 | 46
SNRI | 6 | 1 | 17 | 49
NDRI | 0 | 0 | 7 | 66
TCA | 7 | 0 | 20 | 46
MAOI | 2 | 1 | 8 | 62
5-HT receptor antagonist | 1 | 0 | 6 | 66
Atypical antipsychotics | 0 | 1 | 13 | 59
NMDA | 0 | 0 | 3 | 70
Anticonvulsants | 0 | 3 | 8 | 62
Psychostimulants | 0 | 0 | 5 | 68
Mood stabilizers | 1 | 3 | 13 | 56
Psychotherapy
SSRI | 2 | 0 | 3 | 6
SNRI | 2 | 0 | 2 | 7
NDRI | 2 | 0 | 1 | 8
TCA | 2 | 0 | 0 | 9
MAOI | 1 | 0 | 1 | 9
5-HT receptor antagonist | 1 | 0 | 1 | 9
Atypical antipsychotics | 0 | 0 | 1 | 10
NMDA | 0 | 0 | 1 | 10
Anticonvulsants | 0 | 0 | 1 | 10
Psychostimulants | 0 | 0 | 1 | 10
Mood stabilizers | 1 | 1 | 1 | 8
Pharmacotherapy
SSRI | 20 | 2 | 14 | 35
SNRI | 8 | 2 | 15 | 46
NDRI | 2 | 1 | 14 | 54
TCA | 5 | 3 | 11 | 52
MAOI | 1 | 10 | 8 | 52
5-HT receptor antagonist | 1 | 1 | 9 | 60
Atypical antipsychotics | 0 | 13 | 7 | 51
NMDA | 0 | 4 | 4 | 63
Anticonvulsants | 2 | 6 | 4 | 59
Psychostimulants | 0 | 4 | 5 | 62
Mood stabilizers | 4 | 6 | 6 | 55
CAM/Exercise
SSRI | 4 | 0 | 1 | 3
SNRI | 0 | 1 | 1 | 6
NDRI | 0 | 1 | 1 | 6
TCA | 0 | 1 | 1 | 6
MAOI | 0 | 1 | 0 | 7
5-HT receptor antagonist | 0 | 1 | 0 | 7
Atypical antipsychotics | 0 | 1 | 0 | 7
NMDA | 0 | 1 | 0 | 7
Anticonvulsants | 0 | 1 | 0 | 7
Psychostimulants | 0 | 1 | 0 | 7
Mood stabilizers | 0 | 1 | 0 | 7

5-HT = 5-hydroxytryptamine; BST = brain stimulation therapy; CAM = complementary and alternative medicine; MAOI = monoamine oxidase inhibitor; NDRI = norepinephrine-dopamine reuptake inhibitor; NMDA = N-methyl D-aspartate; SNRI = serotonin-norepinephrine reuptake inhibitor; SSRI, selective serotonin reuptake inhibitor; TCA = tricyclic antidepressant

###### Number of Failed Attempts of Adequate Therapy

Some investigators required a specified number of failed attempts of adequate therapy as another inclusion criterion. “Adequate” was defined in a variety of ways; these could include using, for instance, prespecified duration of treatment, prespecified dosage of antidepressant, a combination of those two criteria, or some other common definition such as that applied in the ATHF. (Table 26 also describes studies in terms of duration and dose.)

The number of failed attempts ranged between one and four (Table 28)—generally either one or two (varying by intervention type). Eighteen studies (6 BST, 9 pharmacology, 3 CAM/Exercise) prespecified a maximum number of treatment failures for study inclusion. No trial required more than four failed treatment attempts for study entry; seven studies in all did not consider this criterion.

Table 28 Number of studies requiring a failed attempt of adequate therapy for study inclusion

Number of Failed Attempts | BST | Psychotherapy | Pharmacology | CAM/Exercise
1 | 21 | 8 | 47 | 4
2 | 35 | 3 | 21 | 3
3 | 4 | 0 | 2 | 0
4 | 8 | 0 | 0 | 0
Not considered | 5 | 0 | 1 | 1

BST = brain stimulation therapy; CAM = complementary and alternative medicine.

###### Prior Treatment Intolerance

Few studies (n=6) used patient intolerance of prior treatment as an inclusion criterion (4 BST stimulation, 2 pharmacology). Four studies used prior intolerance as an exclusion criterion (1 BST, 3 pharmacology). Additionally, four studies reported the prevalence of prior treatment intolerance among study participants without using it as an inclusion criterion (2 BST stimulation, 2 pharmacology).

###### Use of Augmentation and Combination Pharmacological Therapies

Few studies considered use of prior augmentation and combination therapies for either inclusion (n=7) or exclusion (n=3) criteria. Only 13 studies reported whether participants had previously used an augmentation or combination regimen.

###### Use of Electroconvulsive Therapy and Psychotherapy

A minority of studies considered ECT (a type of BST) (n=57, or 35%, for BST or pharmacotherapy interventions) (Table 29). An even smaller minority included psychotherapy (n=28, or 17%, across all interventions) among its inclusion criteria.

Table 29 Number of studies considering use of electroconvulsive therapy or psychotherapy for study inclusion

Type of Therapy | BST | Psychotherapy | Pharmacotherapy | CAM/Exercise
ECT
Inclusion | 4 | 0 | 1 | 0
Exclusion | 17 | 0 | 15 | 0
Just reported | 15 | 0 | 5 | 0
Not considered | 37 | 11 | 50 | 8
Psychotherapy
Inclusion | 1 | 1 | 0 | 0
Exclusion | 1 | 8 | 9 | 2
Just reported | 1 | 0 | 5 | 0
Not considered | 70 | 2 | 57 | 6

BST, brain stimulation therapies; CAM, complementary and alternative medicine; ECT = electroconvulsive therapy.

##### Diagnostic Characteristics

###### Diagnostic Assessments

The majority of studies used structured diagnostic assessments (n=97, 60%); these included a DSM checklist, SCID, or MINI (Table 30). Unstructured assessments were primarily clinical assessments, often described in the study methods as “...met DSM criteria for MDD.” However, study authors often did not state clearly whether investigators used these tools to confirm the diagnosis of MDD for study entry or to confirm the presence of TRD.

Table 30 Number of studies reporting structured or unstructured diagnostic assessments

Type of Assessment | BST | Psychotherapy | Pharmacology | CAM/Exercise
Structured | 37 | 8 | 47 | 5
Unstructured | 36 | 3 | 24 | 3

BST = brain stimulation therapy; CAM = complementary and alternative medicine.

###### Scores on Standardized and Validated Depression Rating Instruments

Investigators used a variety of depression rating instruments either to limit study enrollment or to track study outcomes (see Tables 22 and 23 above). For studies that measured or monitored depression severity using a validated instrument (Table 31), the majority included participants with moderate depression (91 of 120 studies). Table 32 gives the thresholds for mild, moderate, and severe depression according to different instruments.

Table 31 Mean depression severity rating in studies using validated depression-rating instruments

Depression Severity Level | BST | Psychotherapy | Pharmacology | CAM/Exercise
Mild | 2 | 4 | 5 | 1
Moderate | 39 | 5 | 41 | 6
Severe | 9 | 0 | 8 | 0

BST = brain stimulation therapies; CAM = complementary and alternative medicine.

Table 32 Severity cut points for commonly used depression rating instruments

Instrument | Mild | Moderate | Severe
BDI | ≤ 18 | 18–29 | ≥ 30
HAM-D_17_ | ≤ 13 | 14–19 | ≥ 20
HAM-D_21_ | ≤ 15 | 16–22 | ≥ 23
HAM-D_24_ | ≤ 18 | 19–26 | ≥ 27
IDS-C_30_ | ≤ 23 | 24–36 | ≥ 37
MADRS | ≤ 19 | 20–34 | ≥ 35
QIDS-SR_16_ | ≤ 10 | 11–15 | ≥ 16
QIDS-C_16_ | ≤ 10 | 11–15 | ≥ 16

BDI = Beck Depression Inventory; HAM-D = Hamilton Rating Scale for Depression; IDS = Inventory of Depressive Symptomatology (C = clinician rated); MADRS = Montgomery–Åsberg Depression Rating Scale; QIDS = Quick Inventory of Depressive Symptomatology (C = clinician rated, SR = self-rated).

###### Study Setting

Most studies enrolled from or were conducted in outpatient settings (n=105, 64%) (Table 33). A small minority (n=26; 16%) were conducted exclusively in inpatient settings, which were typically psychiatric wards. A substantial number of studies (n=83, 51%) did not clearly describe the study setting or did not report the setting at all.

Table 33 Clinical settings in which participants were enrolled or treated

Enrollment or Study Setting | BST | Psychotherapy | Pharmacology | CAM/Exercise
Primary care clinic | 0 | 3 | 0 | 0
Psychiatric clinic | 14 | 1 | 11 | 3
Primary care + psychiatric clinics | 0 | 2 | 6 | 0
Unspecified outpatient clinic | 31 | 4 | 25 | 5
Inpatient setting | 12 | 1 | 13 | 0
Inpatient + any outpatient clinic | 9 | 0 | 7 | 0
Setting not reported | 7 | 0 | 9 | 0

BST = brain stimulation therapies; CAM = complementary or alternative medicine.

## Key Question 7 Comparison of Inclusion Criteria With Definition of Treatment-Resistant Depression from Narrative Questions

This KQ assesses how well the inclusion criteria from eligible intervention studies (reported in KQ 6) match current definitions of TRD (from KQ 1 in the previous chapter). Based on the 38 publications from KQ 1 (14 systematic reviews, 6 nonsystematic but relevant reviews, and 18 guidelines or consensus statements), we have identified the following four key variables defining TRD:

1. Minimum number of treatment failures. In KQ 1, a minimum of two treatment failures was the most common definition.
2. Prior adequate treatment dose. In KQ 1, this criterion ranged from “minimum effective dose” to “maximum tolerated dose.”
3. Prior adequate treatment duration. In KQ 1, the most common duration was either at least 4 or at least 6 weeks. We selected at least 4 weeks as a threshold for adequate in considering the findings from the systematic reviews.
4. Formal staging of TRD using a staging system described in KQ 1.

Against the key variables noted above, we assessed how well inclusion criteria for the 151 unique intervention studies reflect what previous observers or investigators had considered to be TRD. Six of the studies we have reviewed for this chapter involved patients with bipolar disorder alone; for reasons of simplicity, we have combined these studies with the MDD studies.

With regard to adequacy of dose or duration (variables 2 and 3 above), we assessed not merely whether the trial authors stated that they had considered prior treatment dose (or duration); we also determined whether they specifically indicated how they had confirmed that information, as noted below.

For adequate dose, we first identified whether studies stated that they had restricted eligibility to patients who had received an adequate prior dose as part of their inclusion criteria (i.e., that an adequate dose was considered in determining eligibility). If so, we subsequently identified whether the study had systematically confirmed this dose by specifying dosage levels through interview, questionnaire (e.g., ATRQ), or other formal clarification. We considered a statement that eligibility criteria required a minimum therapeutic dose as stated by product labeling to indicate confirmation.

Similarly, for adequate duration, we first identified whether the studies stated they considered this criterion by restricting eligibility to those patients with a prior adequate duration; if that were the case for these studies, we then determined whether they confirmed the duration by clarifying that patients previously received what KQ 1 had indicated was an adequate dose. In KQ 1, approximately one-half of the eligible reviews and guidelines identified a minimum of 4 weeks of treatment; the other half identified the minimum as 6 weeks. We define an adequate dose here as 4 weeks because one of the primary tools to confirm adequacy of dose and duration, the ATHF, required at least 4 weeks to be considered adequate duration.

### Key Points

1. Inclusion criteria as specified by the eligible TRD studies did not closely align with the definition(s) of TRD identified in the narrative review.
2. Although the most common definition of TRD involves a minimum of two failed prior adequate antidepressant studies, the most common minimum number of treatment failures used as an inclusion criteria for TRD was one (49%) (only 38 percent required a minimum of two failed trials).
3. Of all 163 studies, 77 percent considered in their selection criteria whether the patient had been treated previously with an adequate dose; 58 percent systematically confirmed that the dose was adequate by specifying dosage levels through interview, questionnaire, or other formal clarification.
4. Of all 163 studies, 82 percent considered in their selection criteria whether prior treatments were of adequate duration; 72 percent systematically confirmed that the duration was adequate (≥4 weeks of treatment).
5. Thirty-three percent of all studies set inclusion criteria based on stage of TRD using a formal staging model.
6. Seventeen percent of studies had all the most commonly described criteria for TRD: a minimum of two prior treatment failures, confirmation that a dose was adequate, and confirmation that duration was 4 weeks or longer.

### Detailed Synthesis

For this KQ, we analyzed the match between inclusion criteria of the 163 studies examined in this chapter with the key components of TRD definitions identified in KQ 1 (the narrative results chapter). To reflect better overall how well the TRD studies match TRD definitions, we did not sort by type of intervention; rather, we considered treatment studies as a whole.

As reported in Table 34, we first sorted by the number of minimum prior treatment failures that investigators used to indicate TRD in their studies. Per KQ 1, this criterion specified a minimum of one, two, or three prior treatment failures (the rows identified on the far left); we added a row for four prior treatment attempts because some intervention studies used that criterion. We also specified a row for studies that did not consider prior treatment failures at all. Then, for each of these categories for prior failed treatment attempts, we recorded the numbers of studies that (a) considered (identified) adequate dosage as a selection criterion and (b) confirmed that dose by specifying dosage levels through interview, questionnaire (e.g., ATRQ) or other formal clarification (e.g., ATHF or TSRM stage of 3 or greater). Subsequent to that analysis, we documented whether investigators identified adequate duration as a selection criterion for their studies and whether they confirmed duration—in this case as at least 4 weeks. Finally, we recorded the number of studies that formally staged the TRD using a specific staging model.

Table 34 Numbers of studies of treatment-resistant depression considering or confirming key inclusion criteria for defining the diagnosis

Minimum Prior Treatment Failures | Number of Studies Using This Minimum for Inclusion | Adequate Dosage Considered | Adequate Dosage Confirmed | Adequate Duration Considered | Adequate Duration Confirmed | TRD Staged
1 | 80 | 69 | 59 | 71 | 67 | 22
2 | 62 | 47 | 30 | 52 | 45 | 25
3 | 6 | 5 | 3 | 5 | 2 | 3
≥4 | 8 | 4 | 2 | 5 | 3 | 3
Not considered | 7 | 1 | 1 | 1 | 0 | 1

TRD = treatment-resistant depression.

#### Minimum Number of Prior Treatment Failures

The most common minimum number of treatment failures used as an inclusion criterion for TRD was one (see Table 33) (i.e., used by 80 of 163 studies [49%]). The criterion specifying a minimum of at least two treatment failures (the most commonly described TRD definition) was used by 62 studies (38%). Of note, as indicated in Table 28 in KQ 6, pharmacology studies were most likely to use a minimum of one failed trial (59%, or 47/80), while BST was most likely to use a minimum of two (56%, or 35/62). Only a small number had either three, or four or more as a minimum for prior treatment failures (6/163, 4%, and 8/163 (5%). Finally, seven studies (4%) did not consider the number of prior treatment failures explicitly in their selection criteria.

#### Adequate Dose Considered and Confirmed

Overall, 77 percent of all studies (125/163) stated explicitly that they considered adequate dose as part of their selection criteria. This percentage did not substantially differ by the minimum number of prior failures. For studies requiring one trial failure, 86 percent considered this criterion; for those requiring a minimum of two failures, 76 percent (47/62) considered adequate dose as part of their selection criteria.

By contrast, however, fewer confirmed the dose by specifying discrete dosage levels through interview or other means of other formal clarification. Overall, 58 percent (86/163) systematically confirmed that the dose was adequate. Dose confirmation was most likely for those with a minimum of one prior treatment failure (i.e., 74 percent [59/80]); for studies requiring two treatment failures, the figure was 48 percent (30/62).

Studies that did not consider the number of prior treatment failures in selection criteria only rarely considered adequate dosage for eligibility.

#### Adequate Duration Considered and Confirmed

Overall (Table 34), 82 percent of studies (133/163) considered adequate duration as part of their inclusion criteria. Those studies with a minimum requirement of one treatment failure most commonly considered adequate duration (89%, or 71/80); those requiring two failures considered adequate duration 84 percent of the time (52/62).

Fewer studies systematically confirmed duration. Overall, 72 percent (117/163) confirmed that the duration was adequate (≥4 weeks of treatment). Such confirmation was mostly likely for those with a minimum of one prior treatment failure (84 percent [67/80]); for studies requiring at least two treatment failures, the figure was 73 percent (45/62).

#### Formal Staging of Treatment-Resistant Depression

Inclusion criteria requiring formal staging of TRD using an identified model to determine eligibility were not common (Table 34). Only 33 percent of all studies (53/163) set inclusion criteria based on stage of TRD using a formal model. Confirmation was most likely for those with a minimum of two prior treatment failures (40%; 25/62) and less common for those with a minimum of one prior treatment failure (28%; 22/80).

#### Number of Studies Enrolling TRD Sample With Most Commonly Reported Components of the TRD Definition

We reviewed the eligible studies to determine those that met the most commonly reported part of the TRD definition: a minimum of two prior treatment failures, a confirmed adequate dose, and a confirmed adequate duration of treatment (≥4 weeks). Only 17% of studies (27/163) specified and confirmed through eligibility criteria that their population had these three most common components of the current TRD definition.

When we loosened the benchmark so that study inclusion criteria merely needed to state that adequacy of dose and duration was considered (not systematically confirmed), only 25% of studies (40/163) met that mark.

## Key Question 8 Main Study Designs, Approaches for Run-In or Wash-Out Periods, and Study Durations

### Description of Included Studies

As reported earlier for KQ 6, we had 163 unique studies of interventions in TRD populations, analyzed in four broad categories: BST (including ECT, rTMS, vagal nerve stimulation, and deep brain stimulation [73 studies]), pharmacotherapy (71 studies), psychotherapy (11 studies), and CAM therapies and exercise (8 studies). To address this KQ, we focused on designs of the studies, ways that investigators applied either run-in or wash-out periods, and length of studies. The three tables below document counts and percentages overall and within each intervention category; notable exceptions and trends not captured in tables are presented in the text.

### Key Points

1. Most studies had RCT designs (88%); this rate did not differ by intervention type. Few psychotherapy RCTs were double blind (1 of 10).
2. Few studies had run-in periods (21%) or wash-out periods (23%).
  a. In the majority of the 35 studies (63%) with a run-in stage, it consisted of an active medication period.
  b. In the majority of the 37 studies (68%) with a wash-out stage, it consisted of a medication-free period.
  c. Only one CAM/exercise trial included a run-in period; no CAM/exercise trials included a wash-out period.
3. Study duration varied across studies, ranging from less than 2 weeks to more than 4 years.
  a. The majority of the BST studies lasted 2 months or less (62%).
  b. The average duration of the psychotherapy studies was longer than the length of other intervention studies; 36 percent lasted 1 year or longer.

### Detailed Synthesis

#### Study Characteristics

##### Study Design

Of the 163 unique TRD studies, 73 were of BST, 11 of psychotherapy, 71 of pharmacology, and 8 of CAM or exercise interventions. Overall (Table 35), a majority of the studies had RCT designs (88%). None was a cluster RCT. Study design was mostly consistent across intervention types. The vast majority of the BST, psychotherapy, and pharmacology studies were RCTs (89%, 91%, and 85%, respectively); all CAM/exercise studies had RCT designs. Although a majority or plurality of BST, pharmacology, and CAM/exercise RCTs were double-blind, only one of the ten psychotherapy RCTs was; more than one-half of the psychotherapy RCTs were single-blind (6 of 10).

Table 35 Numbers of studies by study design and intervention type

Study Design | Total n (%) | BST n (%) | Psychotherapy n (%) | Pharmacology n (%) | CAM/Exercise n (%)
RCT studies | 143 (88%) | 65 (89%) | 10 (91%) | 60 (85%) | 8 (100%)
Double-blind | 97 (68%) | 55 (85%) | 1 (10%) | 37 (62%) | 4 (50%)
Single-blind | 27 (19%) | 8 (12%) | 6 (60%) | 10 (17%) | 3 (38%)
Open label | 19 (13%) | 2 (3%) | 3 (30%) | 13 (22%) | 1 (13%)
Cluster | 0 (0%) | 0 (0%) | 0 (0%) | 0 (0%) | 0 (0%)
Non-RCT studies | 20 (12%) | 8 (11%) | 1 (1.4%) | 11 (15%) | 0 (0%)
Nonrandomized controlled | 4 (25%) | 2 (25%) | 0 (0%) | 2 (18%) | 0 (0%)
Prospective cohort | 4 (25%) | 2 (25%) | 1 (100%) | 1 (9%) | 0 (0%)
Retrospective cohort | 9 (45%) | 1 (13%) | 0 (0%) | 8 (73%) | 0 (0%)
Case-control | 2 (10%) | 2 (25%) | 0 (0%) | 0 (0%) | 0 (0%)
Interrupted time series | 1 (5%) | 1 (13%) | 0 (0%) | 0 (0%) | 0 (0%)
Total | 163 (100%) | 73 (100%) | 11 (100%) | 71 (100%) | 8 (100%)

BST = brain stimulation therapies; CAM = complementary and alternative medicine; n = number; RCT = randomized controlled trial.

##### Run-In and Wash-Out Periods

Of 163 studies, 35 (17%) included run-in periods before randomization (Table 36). The types of run-in periods included use of placebo medication (n=1), active medication (n=22), stable medication (n=9), and no treatment (n=3) phases. The use of run-in periods varied by type of intervention; 11 percent, 30 percent, 27 percent, and 13 percent of BST, psychotherapy, pharmacology, and CAM/exercise studies, respectively, included a run-in period before randomization. The goals were to help screen out noncompliant patients, mitigate the effects of a placebo response, ensure that enrolled participants were stable enough to participate in the study, or some combination of these objectives.

Table 36 Numbers of studies with run-in and wash-out periods by intervention type

Use of Run-In and Wash-Out Periods | Total n (%) | BST n (%) | Psychotherapy n (%) | Pharmacology n (%) | CAM/Exercise n (%)
Total | 163 (100%) | 73 (100%) | 11 (100%) | 71 (100%) | 8 (100%)
Run-in | 35 (17%) | 8 (11%) | 4 (30%) | 22 (27%) | 1 (13%)
Placebo | 1 (<1%) | 1 (1%) | 0 (0%) | 0 (0%) | 0 (0%)
Active medication | 22 (13%) | 3 (4%) | 2 (20%) | 17 (23%) | 0 (0%)
Stable medication | 9 (2%) | 3 (4%) | 2 (10%) | 3 (0%) | 1 (13%)
No treatment | 3 (2%) | 1 (1%) | 0 (0%) | 2 (3.1%) | 0 (0%)
No run-in | 128 (83%) | 65 (89%) | 8 (70%) | 54 (73%) | 7 (88%)
Total | 163 (100%) | 73 (100%) | 11 (100%) | 71 (100%) | 8 (100%)
Wash-out | 37 (23%) | 13 (18%) | 1 (9%) | 23 (32%) | 0 (0%)
Medication-free | 25 (15%) | 9 (12%) | 0 (0%) | 16 (23%) | 0 (0%)
Taper | 10 (7%) | 4 (6%) | 1 (9%) | 5 (7%) | 0 (0%)
Immediate discontinuation | 2 (1%) | 0 (0%) | 0 (0%) | 2 (3%) | 0 (0%)
No wash-out | 126 (77%) | 60 (82%) | 10 (91%) | 48 (68%) | 8 (100%)

BST = brain stimulation therapies; CAM = complementary and alternative medicine; n = number.

Of these 163 studies, 37 (23%) required a wash-out period before randomization. Most (n=25) required stopping some existing medications; some (n=10) required a medication taper; and a few (n=2) required immediate discontinuation of medication. Whereas 32 percent of pharmacology studies included a wash-out period, only 18 percent of BST studies and 9 percent of psychotherapy studies did so. No CAM/exercise trial included a wash-out period.

##### Study Duration

The length of included studies ranged from less than 2 weeks (n=5) to more than 4 years (n=9). Taking all studies into consideration (Table 37), the highest proportion ranged from more than 1 month to 2 months (36%); the next commonly used lengths of studies were more than 2 months to 3 months (14%) and more than 2 weeks to 1 month (12%). Twelve studies did not report study duration.

Study duration varied by some intervention types. At one end of the spectrum, 61 percent of BST studies lasted 2 months or less, whereas at the other end, more than 36 percent of psychotherapy studies lasted more than 1 year.

Table 37 Numbers of studies by study duration and intervention type

Duration of Studies | Total n(%) | BST n (%) | Psychotherapy n (%) | Pharmacology n (%) | CAM/Exercise n (%)
Total | 163 (100%) | 73 (100%) | 11 (100%) | 71 (100%) | 8 (100%)
≤ 2 weeks | 5 (3%) | 1 (1%) | 0 (0%) | 4 (6%) | 0 (0%)
<2 weeks to 1 month | 20 (12%) | 16 (22%) | 0 (0%) | 4 (6%) | 0 (0%)
>1 month to 2 months | 59 (36%) | 28 (38%) | 1 (9%) | 27 (37%) | 3 (4%)
>2 months to 3 months | 23 (14%) | 6 (8%) | 2 (18%) | 11 (15%) | 4 (6%)
>3 months to 4 months | 15 (9%) | 3 (4%) | 2 (18%) | 10 (14%) | 0 (0%)
>4 months to 6 months | 8 (5%) | 4 (6%) | 1 (9%) | 3 (4%) | 0 (0%)
>6 months to 8 months | 3 (2%) | 0 (0%) | 1 (9%) | 1 (1%) | 1 (1%)
>6 months to 1 year | 1 (<1%) | 1 (1%) | 0 (0%) | 0 (0%) | 0 (0%)
>1 year to 2 years | 5 (2%) | 2 (3%) | 2 (18%) | 1 (1%) | 0 (0%)
>2 years to 3 years | 2 (1%) | 2 (3%) | 0 (0%) | 0 (0%) | 0 (0%)
>3 years to 4 years | 1 (<1%) | 0 (0%) | 1 (9%) | 0 (0%) | 0 (0%)
>4 years | 9 (6%) | 5 (7%) | 1 (9%) | 3 (4%) | 0 (0%)
Not reported | 12 (7%) | 5 (7%) | 0 (0%) | 7 (10%) | 0 (0%)

BST = brain stimulation therapies; CAM = complementary and alternative medicine; n = number.

## Key Question 9 Risk Factors or Other Patient Characteristics Specifically for Treatment-Resistant Depression

### Concerns With Risk or Prognostic Factors

An unequal distribution of risk or prognostic factors at baseline can lead to selection bias and confounding in controlled studies. Because in any given study the same risk or prognostic factors can act as a confounder for one outcome variable but not for another, in the following sections we refer to them collectively as potential confounders.

Table 38 Risk and prognostic factors that can act as potential confounders

Risk or Prognostic Factor
Age
Chronic pain
Class(es) of previous antidepressant(s)
Medical comorbidities
Psychiatric conditions
Disease severity
Dose of previous antidepressant
Duration of current episode
Family history of depressive disorder
History of bipolar disorder
Interferon or glucocorticoid treatment
Marital status
Melancholic features
Number of previous hospitalizations
Number of prior (failed) treatments
Onset of disease before age 20
Race and ethnicity
Severe, sudden depression during past 3 years
Sex or gender
Socioeconomic status
Suicidal ideation or attempts

Table 38 presents risk and prognostic factors of TRD that could act as potential confounders. We developed this list from an analysis of published systematic reviews and guidelines (KQ 5, in the previous chapter) and a discussion with Centers for Medicare & Medicaid Services (CMS) staff.

Methodologically and statistically, analysts can use four main approaches to minimize the effect of potential confounders: (1) randomization, (2) restriction, (3) stratification, and (4) statistical adjustment.

Randomization refers to allocating individuals (or clusters of individuals) to treatment groups “at random.” The advantage of randomization is that known and unknown potential confounders will be distributed equally across treatment groups if the sample size of a study is large enough.

Randomization, however, cannot guarantee the absence of confounding, particularly in studies with small sample sizes.

Restriction refers to selectively including patients for a study who have similar risk or prognostic factors. Restriction is usually achieved through inclusion or exclusion criteria that define study populations. Restriction leads to homogenous study populations, but it also limits the generalizability (or applicability) of results to populations excluded from a particular study. Restriction cannot control for unknown confounders.

Stratification refers to analyzing data statistically within certain categories. In studies this is usually achieved by subgroup analyses, which should be defined a priori. Like restriction, stratification cannot control for unknown confounders.

Statistical adjustment refers to using statistical methods (usually regression analyses) that control for the unequal distribution of potential confounders across treatment groups. Statistical approaches other than regression analyses are propensity score matching and inverse probability weighting.

In the following sections, we first provide an overview of the designs of the 163 included studies. We then examine to what extent studies employed each of the four strategies to minimize potential confounding.

### Key Points

1. A considerable majority of studies (88%) used randomization as a means to control for potential confounders.
2. All studies applied some exclusion criteria that limited potential confounders. Number of prior failed treatments, psychiatric and medical comorbidities, and severity of disease were the most commonly applied restriction factors to achieve homogeneous study populations.
3. Several studies (20%) stratified analyses by potential confounders. Generally, these factors were age, sex, or gender; number of prior failed treatments; and duration of current depressive episode.
4. Of 20 nonrandomized studies, only 8 reported statistical techniques to control for potential confounding.

### Detailed Synthesis

#### Overview of Studies of Treatment-Resistant Depression

For this KQ, we included 163 studies that met our eligibility criteria, providing data on BST, pharmacologic therapies including ketamine, psychological interventions, and CAM or exercise interventions. Figure 2 presents an overview of their methodological designs; of these, 143 studies were RCTs of various sorts; some were nonrandomized trials, and a handful were prospective or retrospective cohort studies, case-control studies, or interrupted time series.

Sample sizes ranged from 5 to 3,052 patients; the median sample size was 60 participants.

Figure 2 Overview of study designs and number of studies for treatment-resistant depression

#### Randomization

Of 163 studies, 143 (88%) used randomization as a means to control for potential confounders. Of this evidence base, 97 (68%) were double blinded, 27 (19%) were single blinded, and 19 (13%) were open label.

Critical appraisal of the randomization methods revealed that in only three cases were randomization methods clearly inadequate. These studies used alternation or nonrandom number tables as assignment methods. Randomization methods were adequate in 74 RCTs (51%); in 66 RCTs (48%), the randomization methods were not reported adequately.

An assessment of the patient characteristics at baseline revealed that in 28 RCTs (20% of all RCTs), potential confounders were not distributed equally across treatment groups after randomization. Most commonly, these studies had substantial differences between treatment groups in age, baseline severity of depression, duration of illness, or length of the current episode. Ideally, authors would explore such differences by adjusting statistically in their analyses. Only 2 of these 27 RCTs, however, reported results that adjusted statistically for differences in baseline characteristics.

#### Restriction

All studies applied inclusion and exclusion criteria to achieve homogeneous populations. We assessed to what extent studies used potential confounders from Table 37 as inclusion or exclusion criteria to determine their study populations.

Figure 3 presents the numbers of studies that applied such criteria representing these potential confounders. Most studies used more than one of these restriction factors. Therefore, the sum of studies in the figure is larger than the number of included studies for this KQ.

Figure 3 Numbers of studies that used various potential confounders as criteria for inclusion or exclusion of potential study participants

The two most common potential confounders were number of prior failed treatments for TRD and psychiatric comorbidities. The next two frequently encountered confounders were medical comorbidities and severity of disease.

Although marital or socioeconomic status, race or ethnicity, and sex or gender are factors that could act as potential confounders and are listed in Table 37, using them as criteria to determine inclusion or exclusion would not be ethical. Consequently, no study used these factors as inclusion or exclusion criteria. Furthermore, no study restricted its population by chronic pain, family history of depression, melancholic features, onset of severe or sudden depression during the past 3 years, or interferon and glucocorticoid treatment.

#### Stratification

Several studies stratified the population and conducted one or more subgroup analyses. Figure 4 presents the number of studies that conducted such analyses stratifying their patient populations by one of the potential confounders listed in Table 37. No study conducted subgroup analyses on chronic pain, socioeconomic or marital status, onset of severe or sudden depression during the past 3 years, or interferon and glucocorticoid treatment.

Figure 4 Number of studies that conducted subgroup analyses stratifying by various potential confounders

#### Statistical Adjustment

Nineteen studies did not use randomization as a means to minimize the effect of potential confounders. Of these, eight studies reported statistical techniques to control for potential confounding. Seven studies used statistical adjustment of confounders during analyses— adjusting, for example, for baseline differences in severity of disease or age; the eighth study used propensity score matching to minimize the effect of potential confounders. Eleven studies did not report any statistical techniques to control for potential confounders.

## Key Question 10 What are relationships between risk factors or placebo response on results of studies?

Risk factors for disease can sometimes also act as prognostic factors for response, remission, discontinuation of treatment, or other measures of treatment effectiveness. In general, risk factors are characteristics that are associated with causing a specific condition. Prognostic factors are characteristics that influence the outcome in patients who already have the condition. For example, a history of previous depressive episodes is a risk factor for developing another depressive episode in the future but is also a prognostic factor for treatment response. Patients with previous depressive episodes, on average, do not respond as well to treatments as patients with no previous depressive episodes. By contrast, female sex is a risk factor for depression but not a prognostic factor for treatment effectiveness of antidepressants. Men and women, generally, respond equally well to antidepressant treatments and have similar risks for most adverse events.

Similar to patient characteristics, study characteristics can also have an impact on the magnitude of treatment effects in studies. For example, studies with high risk of bias or studies funded by the industry tend to show larger treatment effects than studies with low risk of bias or publicly funded studies.^139,^ ^140^

This KQ explores whether patient-level risk factors or specific study-level characteristics have an impact on results of studies in patients with TRD. It also assesses the impact of placebo response on treatment effects and the relationship between placebo response and study duration.

Table 39 presents patient- and study-level factors that we took into consideration for this KQ. For patient-level factors, we developed this list from an analysis of published systematic reviews and guidelines (KQ 5) and a discussion with CMS staff. For study-level characteristics we relied on available methods research.

Table 39 Potential prognostic factors for treatment-resistant depression treatment success

Potential Prognostic Factors | Variables in Regression Model
Age | Lack of variation of data
Age 65 or older | Inclusion of older adults in study
Bipolar disorder | Proportion of patients with bipolar disorder
Coexisting psychiatric comorbidities | Lack of data
Coexisting medical comorbidities | Lack of data
Duration of current depressive symptoms | Lack of variation of data
Female sex | Proportion of female patients
Funding source | Funding source
Number of prior (failed) treatments | Lack of data
Onset of depression before age 20 | Lack of data
Race or ethnicity | Proportion of nonwhite patients
Severity of depression | Proportion of patients with severe depression
Socioeconomic status | Lack of data
Risk of bias | Risk of bias
Study design | Lack of variation of data
Study duration | Study duration
Study sample size | Study sample size

Because we did not have access to individual patient data of included studies, we converted patient-level factors to study-level factors. For example, we converted “severity of depression” to “proportion of patients with severe depression”. In several instances (e.g., age or duration of current depressive symptoms), the available studies did not provide enough data or the variation of data was too low to make such conversions in a meaningful way. Table 38 also presents the variables that we were able to use in the regression model; here, we italicize those variables that we could not use.

### Key Points

Forty-two studies provided data on two comparisons of interest, namely rTMS compared with sham rTMS (25 studies) and pharmacologic treatments compared with pharmacologic treatments plus augmentation (17 studies).

1. For most risk factors that might influence treatment response, data were either insufficient for regression analyses or reflected no statistically significant impact on study results.
2. In a comparison of pharmacotherapy with pharmacotherapy plus augmentation with a second medication, multivariable analyses indicated that female sex had a significant effect on discontinuation; studies with 60 percent or more female participants had statistically significantly higher discontinuation rates because of adverse events (ratio of odds ratios [ROR] 2.81; 95% confidence interval [CI] 1.04 to 7.59) than studies with fewer than 60 percent females.
3. A smaller placebo response was associated with a statistically significantly larger treatment effect for response (p=0.027), remission (p=0.001), and discontinuation because of adverse events (p=0.010). Study duration did not have an impact on placebo response.

### Description of Included Studies

Out of 163 unique studies of interventions in TRD populations, 42 comparisons were similar enough with respect to interventions and control interventions to warrant regression analyses to assess the impact of patient- and study-level characteristics on study results. These studies addressed two treatment categories: (1) rTMS versus sham rTMS (25 studies) and (2) pharmacotherapy versus pharmacotherapy plus augmentation (17 studies). Our outcomes of interest were response, remission, relapse, overall risk of adverse events, risk of serious adverse events, discontinuation because of adverse events, and suicidal ideation and attempts. Because of lack of data, we could not assess relapse and suicidal ideation and attempts.

### Detailed Synthesis

#### Relationships Between Risk Factors and Results of Included Studies

Out of the 17 variables of interest presented in Table 38, data were sufficient to conduct regression analyses on eight potential prognostic factors for studies comparing rTMS with sham rTMS: depression severity, funding source, proportion of participants 65 years or older, proportion of female participants, proportion of participants with bipolar disease, risk of bias, sample size, and study duration.

Table 40 presents results of bivariable and multivariable regression analyses. The outcome measure is the ROR, which compares the treatment effect (odds ratio) of studies with a specific potential prognostic factor (covariate) with the treatment effect of studies without this covariate. For example, in Table 39 the ROR for response for the proportion of female participants in the bivariable analysis is 2.55 (95% CI, 1.16 to 5.64). This can be interpreted that studies with more than 60 percent of female participants had, on average, odds ratios of response that were twice as large as studies with fewer than 60 percent female participants.

In bivariable analyses, several statistically significant differences emerged (bolded in Table 39). Studies with sample sizes larger than 60 participants had statistically significantly smaller response (ROR, 0.38; 95% CI, 0.17 to 0.84) and remission rates (ROR, 0.14; 95% CI, 0.03 to 0.62) than studies with fewer than 60 participants.

Table 40 Results of bivariable and multivariable regression analyses of potential prognostic factors for studies comparing rTMS with sham rTMS

Potential Prognostic Factor | Response ROR (95% CI) | Remission ROR (95% CI) | Risk of Serious Adverse Events ROR (95% CI) | Discontinuation Because of Adverse Events ROR (95% CI)
Bivariable analyses
Risk of bias (high vs. low or moderate risk of bias) | 0.69 (0.16, 2.99) | 1.61 (0.14, 18.66) | 0.98 (0.06, 17.73) | Nonestimable^a^
Funding source (public vs. industry funding) | 1.58 (0.71, 3.52) | 2.72 (0.87, 8.54) | 1.72 (0.20, 14.92) | Nonestimable^a^
Proportion of patients with severe depression (severe vs. mild or moderate) | 2.32 (0.74, 7.23) | 4.16 (0.69, 24.99) | 0.85 (0.14, 5.05) | 0.91 (0.14, 5.75)
Inclusion of older adults (studies with patients 65 years or older vs. studies without) | 1.09 (0.30, 3.97) | 0.71 (0.03, 14.52) | Nonestimable^a^ | Nonestimable^a^
Study sample size (n ≥60 participants vs.<60 participants)^b^ | 0.38 (0.17, 0.84) | 0.14 (0.03, 0.62) | 0.39 (0.03, 5.51) | 1.43 (0.16, 12.51)
Study duration (≥6 weeks vs. <6 weeks)^b^ | 0.56 (0.24, 1.30) | 0.44 (0.09, 2.01) | 0.45 (0.03, 6.38) | 1.67 (0.19, 14.66)
Proportion of female participants (≥60% vs. <60%)^b^ | 2.55 (1.16, 5.64) | 5.78 (1.52, 21.92) | 1.08 (0.13, 9.15) | 1.62 (0.21, 12.42)
Proportion of participants with bipolar disorder (≥15% vs.<15%)^b^ | 3.26 (1.27, 8.39) | Nonestimable^a^ | Nonestimable^a^ | Nonestimable^a^
Multivariable analysis
Study sample size (n ≥60 participants vs.<60 participants)^b^ | 0.68 (0.13, 3.52) | 0.27 (0.03, 2.33) | NA | NA
Proportion of female participants (≥60% vs. <60%)^b^ | 1.85 (0.50, 6.86) | 2.31 (0.34, 15.56) | NA | NA
Proportion of participants with bipolar disorder (≥15% vs.<15%)^b^ | 1.57 (0.29, 8.37) | NA | NA | NA

a Nonestimable indicates that the model could not be estimated because of a lack of variation for the characteristic among studies reporting the outcome.

b The variable was dichotomized around the median.

CI = confidence interval; NA = not applicable; ROR = ratio of odds ratios; rTMS = repetitive transcranial magnetic stimulation; vs. = versus.

Studies with 60 percent or more of female participants had statistically significantly larger response (ROR, 2.55; 95% CI, 1.16 to 5.64) and remission (ROR, 5.78; 95% CI, 1.52 to 21.92) rates than studies with fewer than 60 percent females.

Likewise, studies with 15 percent or more patients with bipolar disorder had statistically significantly larger response rates (ROR, 3.26; 95% CI, 1.27 to 8.39) than studies with fewer than 15 percent of patients with bipolar disorder.

In multivariable analyses, however, none of these factors remained statistically significant (Table 40).

For the comparison of pharmacotherapy with pharmacotherapy plus augmentation, data were sufficient to conduct regression analyses on four potential prognostic factors: depression severity, proportion of female participants, sample size, and study duration.

Table 41 presents results of bivariable and multivariable regression analyses. In bivariable analyses, three statistically significant differences emerged (bolded in Table 40). Studies that included patients with severe depression had statistically significantly higher rates of discontinuation because of adverse events (ROR, 13.33; 95% CI, 1.32 to 134.15) than studies that included patients with mild or moderate depression.

Second, studies with a study duration of 6 weeks or longer reported significantly lower response rates than studies shorter than 6 weeks (ROR, 0.36; 95% CI, 0.14 to 0.93). Third, studies with 60 percent or more female participants had statistically significantly higher discontinuation rates because of adverse events (ROR, 3.71; 95% CI, 1.56 to 8.84) than studies with fewer than 60 percent females. In multivariable analyses, this was the only factor that remained statistically significant after adjusting for other covariates (ROR, 2.81; 95% CI, 1.04 to 7.59; Table 41). These findings, however, need to be interpreted cautiously.

Table 41 Results of bivariable and multivariable regression analyses of potential prognostic factors for studies comparing pharmacotherapy with pharmacotherapy plus augmentation

Potential Prognostic Factor | Response ROR (95% CI) | Remission ROR (95% CI) | Risk of Serious Adverse Events ROR (95% CI) | Discontinuation Because of Adverse Events ROR (95% CI)
Bivariable analyses
Proportion of patients with severe depression (severe vs. mild or moderate) | 0.96 (0.57, 1.59) | 1.10 (0.65, 1.84) | 0.54 (0.02, 15.80) | 13.33 (1.32, 134.15)
Study sample size (n ≥60 participants vs. <60 participants)^a^ | 0.45 (0.15, 1.34) | 0.75 (0.23, 2.48) | Nonestimable^b^ | 2.94 (0.55, 15.71)
Study duration (≥6 weeks vs. <6 weeks)^b^ | 0.36 (0.14, 0.93) | 0.52 (0.17, 1.62) | 0.51 (0.08, 3.30) | 2.20 (0.70, 6.93)
Proportion of female participants (≥60% vs. <60%)^a^ | 0.93 (0.61, 1.42) | 0.88 (0.58, 1.32) | 0.72 (0.15, 3.46) | 3.71 (1.56, 8.84)
Multivariable analysis
Proportion of patients with severe depression (severe vs. mild or moderate) | NA | NA | NA | 10.23 (0.96, 108.51)
Proportion of female participants (≥60% vs. <60%)^a^ | NA | NA | NA | 2.81 (1.04, 7.59)

a The variable was dichotomized around the median.

b Nonestimable indicates that the model could not be estimated because of a lack of variation for the characteristic among studies reporting the outcome.

CI = confidence interval; NA = not applicable; ROR = ratio of odds ratios; vs. = versus.

#### The Influence of Placebo Response on the Magnitude of Treatment Effect

Only the body of evidence comparing rTMS with sham rTMS provided data to address this question. We conducted regression models to explore the impact of placebo response on estimates of treatment effect of rTMS. We tested whether the effect of treatment varied according to the placebo response in the study. Among rTMS studies, we found a significant variation in treatment effect according to levels of placebo response. The smaller the placebo response, the larger the treatment effect; and the larger the placebo response, the smaller the treatment effect. This finding was true for response (p=0.027), remission (p=0.001), and discontinuation because of adverse events (p=0.010). No significant variation was found across levels of placebo response for the risk of serious adverse events (p=0.369).

Overall, these findings are not surprising because outcome measures in controlled trials are mathematically essentially the difference of effects or the ratio of events between intervention and control groups. Given that the treatment effect in the intervention group is the sum of a placebo effect and an actual treatment effect, it is easier to achieve a larger difference between treatment and control groups if the placebo effect is small.

#### Study Duration as a Moderator of Placebo Response

In cases where we observed significant variation of treatment effect by placebo response interaction was significant, we tested whether study duration moderated the impact of placebo response on the treatment effect, using a three-way interaction between treatment, proportion of placebo responders, and study duration. The relationship between placebo response and treatment effect did not vary by study duration for any of the outcomes.

## Key Question 11 Variables or Information Used to Define Endpoints

This final systematic review KQ is intended to summarize our findings from the 163 included studies about the wide array of variables or other information that the investigators used in defining their outcomes or endpoints. We drew on measures examined in the narrative review KQ 3 for some of these analyses.

In addition, we determined whether any studies recorded information about the following: occurrence of adverse events; attrition from care attributed to either adverse events or lack of efficacy; time to relapse; adherence to treatment; changes in any factors that patients might have deemed salient; changes in employment or disability status; and changes in the use of health care resources, such as hospital admissions, emergency room use, or physician visits. We note that the numbers of studies are not necessarily mutually exclusive (i.e., they will not sum to 163) because investigators often used more than one of these instruments or interviews in a single study.

We first list key points below and then present a detailed synthesis of our analyses. The latter focuses on the following: (a) endpoints, such as outcomes that are specific to depression, those reflecting general psychiatric status, and those identifying functional impairment or quality of life, and (b) additional outcomes specifically requested by CMS. For each, we indicate the frequency with which these various measures are reported in the eligible trials or other studies. As with previous questions, we report these analyses in terms of studies investigating BST, psychotherapy, pharmacology, and CAM/exercise interventions.

### Key Points

1. The two most common outcome measures used to assess depression were the HAM-D and the MADRS. The HAM-D was the most common depression instrument used across all interventions, and the MADRS was used in one-half of the pharmacology studies.
2. Assessment of manic outcomes was rare.
3. The CGI scale was the most common general psychiatric outcome reported, nearly always in pharmacology studies and slightly less than half the time in BST studies.
4. Functional impairment and quality-of-life outcomes were infrequently reported.
5. Adverse events were commonly reported for BST and pharmacology studies but not in either psychotherapy or CAM/exercise studies.
6. Other than in psychotherapy studies, adherence to treatment was not commonly measured.
7. Overall attrition was a commonly reported outcome, but specific attributions of attrition (e.g., to adverse events or lack or efficacy) were less commonly described.
8. Disability status, time to relapse, and use of health care services were very rarely reported.

### Detailed Synthesis

#### Common Clinical Endpoints and Outcomes

We encountered myriad endpoints in the included studies. We classified them mainly as those specific to depression, those specific to mania, those relevant for psychiatric conditions broadly defined, and those more widely applied for assessing quality of life or functional impairment. The measures that studies most commonly used or reported on were the following (in alphabetical order, spelled out for ease of reference and with typical acronyms by which they are usually known):

- The Beck Depression Index (BDI), in several versions
- The Brief Psychiatric Rating Scale (BPRS)
- The Clinical Global Impression (CGI) scales—CGI-I for improvement and CGI-S for severity
- The General Assessment of Functioning (GAF)
- The Hamilton Rating Scale for Depression (HAM-D), in several versions depending on the number of items used
- The Inventory of Depressive Symptomatology (IDS) or the Quick IDS (QIDS), in two versions relating to self-rated (SR) or clinician rated (C)
- The Montgomery-Åsberg Depressive Rating Scale (MADRS)
- The Sheehan Disability Scale (SDS)
- The Short Form Health Surveys (SF), in two main versions depending on the number of items used (SF-36 or SF-12)
- The Young Mania Rating Scale (YMRS)

In addition to these measures, research teams sometimes used other questionnaires or interview assessment tools as endpoints. These appeared, however, in fewer than five studies and we do not report further on them. They included the following (also in alphabetical order, with acronyms when the instruments are reasonably well known by them):

- Apathy Evaluation Scale
- Center for Epidemiologic Studies Depression Scale (CES-D)
- Generalized Anxiety Disorder scale (GAD-7)
- Geriatric Depression Scale
- Melancholia Scale
- Mini—Mental State Examination (MMSE)
- Multidimensional Assessment of Fatigue
- Patient Health Questionnaire (PHQ-9)
- Quality of Life Enjoyment and Satisfaction Questionnaire (Q-LES-Q)
- Structured Clinical Interview for Depression (SCID)
- Symptom Checklist-90-revised (SCL-90-R)

In Table 42 we report frequencies of use of the measures listed first (above) for the four main categories of interventions.

Table 42 Numbers of studies using common measures of endpoints, by type of intervention for treatment-resistant depression

Measures | BST | Psychotherapy | Pharmacology | CAM/Exercise
Depression-Specific Measures
HAM-D (all) | 63 (86.3%) | 8 (72.7%) | 43 (60.6%) | 7 (87.5%)
HAM-D_6_ | 3 (4.1%) | 0 (0%) | 0 (0%) | 1 (12.5%)
HAM-D_17_ | 35 (47.9%) | 5 (45.5%) | 35 (49.3%) | 6 (75.0%)
HAM-D_21_ | 11 (15.1%) | 2 (18.2%) | 8 (11.3%) | 0 (0%)
HAM-D_24_ | 8 (11.0%) | 1 (9.1%) | 0 (0%) | 0 (0%)
HAM-D_28_ | 6 (8.2%) | 0 (0%) | 0 (0%) | 0 (0%)
MADRS | 28 (38.4%) | 1 (10.0%) | 35 (49.3%) | 1 (12.5%)
BDI (all) | 27 (37.0%) | 7 (63.6%) | 5 (7.0%) | 2 (25.0%)
BDI | 16 (21.9%) | 4 (36.4%) | 4 (5.6%) | 0 (0%)
BDI-II | 8 (11.0%) | 3 (27.3%) | 0 (0%) | 2 (25.0%)
BDI-SF | 3 (4.1%) | 0 (0%) | 1 (1.4%) | 0 (0%)
IDS/QIDS | 12 (16.4%) | 0 (0%) | 17 (23.9%) | 3 (37.5%)
IDS-SR_30_ | 5 (6.8%) | 0 (0%) | 4 (5.6%) | 0 (0%)
IDS-C_30_ | 5 (6.8%) | 0 (0%) | 0 (0%) | 1 (12.5%)
QIDS-SR_16_ | 2 (2.7%) | 0 (0%) | 12 (16.9%) | 1 (12.5%)
QIDS-C_16_ | 0 (0%) | 0 (0%) | 1 (1.4%) | 1 (12.5%)
Mania-Specific Measure
YMRS | 5 (6.8%) | 0 (0%) | 2 (2.8%) | 0 (0%)
General Psychiatric Measures
CGI (all) | 32 (43.8%) | 3 (27.3%) | 64 (90.1%) | 4 (50.0%)
CGI-I | 20 (27.4%) | 1 (9.1%) | 33 (46.5%) | 3 (37.5%)
CGI-S | 12 (16.4%) | 2 (18.2%) | 31 (43.7%) | 1 (12.5%)
BPRS | 7 (9.6%) | 0 (0%) | 7 (9.9%) | 0 (0%)
Functional Impairment or Quality-of-Life Measures
SF (all) | 1 (1.4%) | 1 (9.1%) | 6 (8.5%) | 1 (12.5%)
SF-12 | 0 (0%) | 1 (9.1%) | 4 (5.6%) | 0 (0%)
SF-36 | 1 (1.4%) | 0 (0%) | 2 (2.8%) | 1 (12.5%)
GAF | 6 (8.2%) | 0 (0%) | 2 (2.8%) | 2 (25.0%)
SDS | 1 (1.4%) | 0 (0%) | 7 (9.9%) | 0 (0%)
Q-LES-Q | 0 (0%) | 0 (0%) | 3 (4.2%) | 1 (12.5)

BDI = Beck Depression Inventory; BPRS = Brief Psychiatric Rating Scale; BST = brain stimulation therapies, CAM = complementary and alternative medicine; CGI = Clinical Global Impression; CGI-I or -S = Clinical Global Impression-Improvement or -Severity; GAF = Global Assessment of Functioning; HAM-D = Hamilton Depressive Rating Scale; IDS = Inventory of Depressive Symptomatology (C=clinician–rated, SR = self-rated); MADRS = Montgomery-Åsberg Depressive Rating Scale; QIDS = Quick Inventory of Depressive Symptomatology (C=clinician–rated, SR = self-rated); Q-LES-Q = Quality of Life Enjoyment and Satisfaction Questionnaire; SDS = Sheehan Disability Scale; SF = Short Form; SF-12 = Short Form-12 item version; SF-36 = Short Form-36 item version; YMRS = Young Mania Rating Scale.

Among the depression-specific measures, the HAM-D was the most commonly used measure in studies of all four types of interventions. In total, it was applied in 121 studies. The BDI (in its various versions) and MADRS were also frequently used for BST studies and MADRS for pharmacology studies as well. MADRS was used in 65 studies in all and BDI in 41.

Among the general psychiatric assessments or questionnaires, the CGI was the most used measure, again essentially only for BST or pharmacology studies. For the two general psychiatric measures, the CGI was by far the more commonly used (103 studies in all). Among the quality-of-life or functional impairment measures, the Short Form (SF) measures, the GAF, and the SDS appeared in similar numbers of studies (between seven and nine studies) across the intervention types. Assessment of mania-specific symptoms in TRD was rare.

#### Additional Outcomes of Interest

We also report below other outcomes of interest reported in TRD studies (Table 43). We sort the table into six main outcomes in these studies: (1) adverse events (which may have been collected actively, passively, or by a process not clearly described) and related adverse event categories; (2) attrition (with two subcategories of how such attribution was explained); (3) treatment adherence, (4) change in disability status, (5) use of health care resources, and (6) time to relapse. No studies reported change in employment.

Table 43 Numbers of studies reporting on other outcomes or endpoints of interest, by type of intervention for treatment-resistant depression

Additional Outcomes of Interest Measures | BST | Psychotherapy | Pharmacology | CAM/Exercise
Adverse events rates | 57 (78.1%) | 3 (27.3%) | 58 (81.7%) | 3 (37.5%)
Active | 18 (24.7%) | 2 (18.2%) | 25 (35.2%) | 0 (0%)
Passive | 26 (35.6%) | 1 (9.1%) | 10 (14.1%) | 0 (0%)
Unclear | 14 (19.2%) | 0 (0%) | 23 (32.4%) | 3 (37.5%)
Serious adverse events rates | 29 (39.7%) | 2 (18.2%) | 41 (57.7%) | 0 (0%)
Overall adverse event rates | 36 (49.3%) | 3 (27.30%) | 37 (52.1%) | 2 (25.0%)
Attrition overall | 48 (65.8%) | 11 (100%) | 48 (75%) | 5 (62.5%)
Attrition attributed to adverse events | 28 (38.4%) | 2 (18.2%) | 45 (70.3%) | 2 (25.0%)
Attrition attributed to lack of efficacy | 17 23.3%) | 1 (9.1%) | 22 (34.4%) | 1 (12.5%)
Adherence to treatment | 20 (27.4%) | 5 (45.5%) | 12 (16.9%) | 1 (12.5%)
Chanqe in disability status | 1 (1.4%) | 1 (9.1%) | 8 (11.3%) | 0 (0%)
Use of health care resources | 2 (2.7%) | 2 (18.2%) | 1 (1.4%) | 0 (0%)
Time to relapse | 7 (9.6%) | 0 (0%) | 3 (4.2%) | 0 (0%)

BST = brain stimulation therapies; CAM = complementary and alternative medicine.

By a wide margin, adverse events (including serious adverse events and overall rates) were reported more often for BST and pharmacology studies. Overall attrition was commonly reported for all interventions, but rates of attrition for either problems of adverse events or lack of efficacy were more frequently reported by BST and drug studies (consistent with the closer monitoring of adverse events for these interventions).

Adherence to treatment was infrequently reported in TRD studies, most commonly in psychotherapy studies (five of 11 studies) but less commonly with other intervention types.

Relatively few studies of any type of intervention reported on the other variables. Eight pharmacology studies reported on change in disability status, and seven BST studies provided information on time to relapse. Otherwise, very few gave findings about use of health care services.