# Methods

This Technology Assessment is organized into sections addressing the Narrative Review Key Questions (KQs) (1 through 5) and the Systematic Review KQs (6 through 11) concerning treatment-resistant depression (TRD). Table 1 gives our selection (inclusion/exclusion) criteria based on PICOTS (Population, Interventions, Comparators, Outcomes, Timing, and Setting) and outlines our methods to answer the KQs.

## Inclusion and Exclusion Criteria

Our population of interest is adults 18 years of age or older with depression who have not responded to treatment(s). The depressive illness can be part of either major depressive disorder (MDD) or bipolar disorder, but one of these diagnoses must be a primary diagnosis per the Diagnostic and Statistical Manual of Mental Disorders, fourth edition^25^ or 5th edition.^26^ For example, studies of patients who have schizophrenia with a secondary diagnosis of MDD or who have dysthymia would not be eligible for this report. If a study involved both eligible and ineligible patients and did not report data separately, we excluded that whole study. Populations with no evidence of treatment nonresponse (e.g., a study in which the absence of treatment response is not part of the selection criteria) were also not eligible.

Eligible interventions included those that have both been tested as a treatment targeting TRD in adults and identified by guidelines, consensus statements, the Medicare Evidence Development & Coverage Advisory Committee (MEDCAC) panel of April 27, 2016, or systematic reviews as alternatives for TRD treatment studies. These criteria ensure consideration of interventions with a minimum threshold amount of data addressing their effectiveness in TRD populations. Comparison groups include concurrent control groups (e.g., active, sham, or placebo) and a control group from an interrupted time series.

We required outcomes to have been identified in our previous comparative effectiveness work^58,^ ^59^ as the most meaningful to depression management decisionmaking. In that review, we had asked our Technical Expert Panel and Key Informants to rank the relative importance of these depression management outcomes following a process proposed by the GRADE Working Group.^60^ We then had that panel anonymously rank the relative importance of outcomes using SurveyMonkey©. Participants used a 9-point Likert scale to rank outcomes into three categories: (1) critical for decisionmaking, (2) important but not critical for decisionmaking, and (3) of low importance for decisionmaking. They identified six outcomes as critical and five as important, and they supported the inclusion of an additional depressive outcome (change in depressive severity). For one of the adverse events outcomes, serious adverse events, we used the U.S. Food and Drug Administration (FDA) definition^61^ and considered physical, psychological, and cognitive events. We required relevant studies for the current project to report on at least 1 of these 12 outcomes.

We carefully considered eligible dates of publications to focus the review on information most relevant to the current understanding of TRD and the interests of the Centers for Medicare & Medicaid Services. Given our interest in including information pertinent to FDA-approved treatments for TRD (including vagus nerve stimulation, approved in 2005^62^), we set our starting publication date for intervention studies (KQs 6 through 11) and systematic reviews (part of KQs 1 through 5) as January 1, 2005. For all other materials eligible for the KQ 1 through 5 narrative review (e.g., consensus statements and guidelines), we considered literature published since January 1, 1995, reflecting our sponsor’s interest in comprehensively reviewing the variety of conceptualizations of TRD. This beginning date also provides literature relevant to current definitions of TRD with diagnoses.

All study durations and all settings in very highly developed countries, according to the Human Development Index (using three dimensions: long and healthy life, knowledge, and a decent standard of living),^29^ were eligible. Pre/post studies that did not use interrupted time series analyses were excluded, because potential confounding from multiple sources renders questionable the ability of these study designs to support causal inferences. We included English-language articles and excluded studies that had not been published fully in English, because their ability to provide meaningful information about the current understanding of TRD in a Medicare- or Medicare-related population is limited.

Table 1 Inclusion/Exclusion Criteria For Studies Of Treatment-Resistant Depression

PICOTS | Inclusion Criteria | Exclusion Criteria
Population | All adult populations (≥18 years old) identified as having a primary diagnosis of depression (including MDD and bipolar disorder) who have not responded to treatment(s) (the least stringent definition of TRD). The depressive episode must be part of a major depressive disorder or a bipolar disorder per DSM-IV or -5. | Populations without a primary diagnosis of MDD or bipolar disorder are excluded, as well as those without evidence of treatment nonresponse.
Interventions | Any pharmacologic intervention^a^ tested as a treatment for TRD as a primary therapy or as an augmentation agent to an existing primary therapy.; - Antidepressants (e.g., SSRIs, SNRIs, TCAs, MAOIs, atypical agents); - Atypical antipsychotics; - Anticonvulsants; - Mood stabilizers; - Psychostimulants; - Agents approved by FDA for other indications but tested in TRD populations (e.g., ketamine, levothyroxine, clonidine); Any nonpharmacologic device or procedure tested as a treatment for TRD as a primary therapy or as augmentation to an existing primary therapy.; - Devices (i.e., ECT, rTMS, VNS, DBS, MST, tDCS, LFMS, CES). For some of our analyses, we collapse this set of interventions into the category “brain stimulation therapies,” or BST.; Any nonpharmacologic intervention tested as a treatment for TRD as a primary therapy or as augmentation to an existing primary therapy.; - CAM (i.e., acupuncture, meditation [e.g., mindfulness-based stress reduction], omega-3 fatty acids, S-adenosyl-L-methionine (SAMe), St. John’s wort (Hypericum perforatum), light therapy, sleep deprivation); - Psychotherapy (i.e., CBT, third wave CBT, psychodynamic therapies, and integrative therapies); - Exercise (i.e., any formal exercise program) | Interventions not targeting TRD
Comparators | All comparative studies with concurrent control groups or control groups from an interrupted time series or pre/post studies with interrupted time series analyses (which require that data are collected at two or more time points before and after an intervention). | Pre/post studies where interrupted time-series analyses were not conducted
Outcomes | Mental health outcomes identified in previous depression comparative effectiveness review work as either critical or important for decisionmaking: Benefits that are reported as primary endpoints (or outcomes) for a study:; - Reduction in suicidal ideation or suicide attempts; - Quality of life; - Response to treatment; - Remission; - Change in depressive severity; - Functional capacity (physical and cognitive functioning measured by validated scales); - Speed of remission; - Speed of response; - Intervention durability (rates or counts of recurrence of a depressive episode for those who have remitted); Adverse events from the intervention identified as either critical or important for decisionmaking:; - Serious adverse events per FDA definition^b^ (rates or counts); - Overall adverse events (rates or counts); - Treatment discontinuations attributed to adverse events (rates or counts) | None
Timing | Any study duration For KQs 1–5: For systematic reviews, publication date from 1/1/2005 to present; for other literature type or study designs, publication date from 1/1/95 to present For KQs 6–11: Literature publication date from 1/1/2005 to present | Literature published before these specific dates
Setting | Studies that took place in very highly developed countries^c^ | Studies that took place in high, medium, or low human development countries
Study designs | For KQs 1–5: Consensus statements, guidelines, materials from CMS, SAMHSA, FDA, or NIH; UpToDate®; information from the 2016 MEDCAC panel meeting on the definition of TRD; and systematic review articles that (a) searched two or more literature databases, (b) included dual review of the literature and data abstraction, and (c) included quality or risk of bias assessments of included studies. For KQs 6–11: Randomized, or prospective nonrandomized, or observational studies (including concurrent controls and interrupted time series) | For KQs 1–5: Evidence not meeting inclusion criteria. Individual trials were not considered in this section. For KQs 6–11: Pre/post studies without interrupted time-series analyses Any studies without a control group
Language | English only | Studies not published in English

a Pharmacologic: SSRIs: citalopram, escitalopram, fluoxetine, fluvoxamine, paroxetine, sertraline; SNRIs: desvenlafaxine, duloxetine, levomilnacipran, mirtazapine, venlafaxine; NADRIs: bupropion; TCAs: amitriptyline, clomipramine, desipramine, doxepin, imipramine, maprotiline, nortriptyline; MAOIs: phenelzine, selegiline transdermal, tranylcypromine; 5HT Ras: nefazodone, trazodone, vilazodone, vortioxetine; atypical antipsychotics: cariprazine, quetiapine; NMDAs: ketamine; Other Pharmacologic for Combination or Augmentation: Atypical antipsychotics: aripiprazole, asenapine maleate, clozapine, iloperidone, lurasidone, olanzapine, paliperidone, quetiapine, risperidone, ziprasidone; Anticonvulsants: carbamazepine, lamotrigine, oxcarbazepine, topiramate, valproic acid; Psychostimulants: amphetamine-dextroamphetamine, armodafinil, dexmethylphenidate, dextroamphetamine, lisdexamfetamine, methyphenidate, modafinil; Mood stabilizers: lithium, divalproex; Other augmenters: bupropion, buspirone, clonidine, liothyronine, pindolol, pramipexole, triiodo-thyronine (T3).

b For serious adverse events, we use the FDA definition and will consider physical, psychological, and cognitive events.^61^

c “Very High” on Human Development Index: Andorra, Argentina, Australia, Austria, Bahrain, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong China (SAR), Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea (Republic of), Kuwait, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Montenegro, Netherlands, New Zealand,

Norway, Poland, Portugal, Qatar, Saudi Arabia, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States.^29^

BST = brain stimulation treatment; CAM = complementary and alternative medicine therapies; CBT = cognitive behavior therapy; CES = cranial electrotherapy stimulation; CMS = Centers for Medicare & Medicaid Services; DBS = deep brain stimulation; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition; DSM-5 = Diagnostic and Statistical Manual of Mental Disorders, 5^th^ Edition; ECT = electroconvulsive therapy; FDA = U.S. Food and Drug Administration; KQ = Key Question; LFMS = low field magnetic stimulation; MAOI = monoamine oxidase inhibitor; MDD = major depressive disorder; MEDCAC = Medicare Evidence Development &Coverage Advisory Committee; MST = magnetic seizure therapy; NIH = National Institutes of Health; PICOTS = population, intervention, comparator; outcome; timing, setting; rTMS = repetitive transcranial magnetic stimulation; SAMe = S-adenosyl-L-methionine; SAMHSA = Substance Abuse and Mental Health Services Administration; SNRI = serotonin-norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor; TCA = tricyclic antidepressant; tDCS = transcranial direct stimulation; TRD = treatment-resistant depression; VNS = vagus nerve stimulation.

## Searching for the Evidence: Literature Search Strategies to Identify Relevant Studies to Answer Key Questions

An experienced research librarian at the RTI International-University of North Carolina Evidence-based Practice Center developed the strategy for our comprehensive search of the literature. To ensure methodological quality, we followed standard procedures for systematic literature searches specified in the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^24^ Although KQs 1 through 5 were narrative questions (which often turn up for systematic reviews), we nevertheless applied standard methods for the title/abstract and full-text review as much as possible to meet the typical global standards for this step.

We systematically searched the published literature from January 1, 1995, to August 18, 2017, that is indexed in MEDLINE®, EMBASE, PsycINFO, and Cochrane Library and that addresses treatment of TRD in adults. The aim was to assemble literature relevant to current definitions of TRD with diagnoses consistent with definitions in Diagnostic and Statistical Manual of Mental Disorders, Fourth edition^25^ and 5th edition.^26^ As noted earlier, for consensus statements and guidelines that were not part of the published peer-reviewed literature we considered materials that had appeared since January 1, 1995. For systematic reviews that became part of the evidence base for some parts of the narrative KQs 1 through 5, and for intervention studies relevant for the systematic review KQs 6 through 11, we set our publication date for intervention studies as January 1, 2005. We also reviewed both reference lists of all systematic reviews that we included for KQs 1 through 5 and indexed protocols; the goal was to identify any relevant citations that our electronic searches might have missed.

In addition, we searched for consensus statements, management guidelines, and relevant government materials from various Federal agencies, specifically including the following: CMS (and MEDCAC), FDA, National Institutes Health, National Institute of Mental Health, and the Substance Abuse and Mental Health Services Administration. We abstracted Information relevant to KQs 1 through 5 from such sources. We also searched other Web sites such as Clinicaltrials.gov, Guideline.gov (AHRQ’s National Guidelines Clearinghouse), HSRProj (https://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm) (Health Services Research Projects in Progress database), and UpToDate (https://www.uptodate.com/).

Further, the Evidence-based Practice Center Program’s Scientific Resource Center contacted relevant stakeholders, including manufacturers of prescription medications and medical devices used to treat MDD, for scientific information packets (Supplemental Evidence and Data for Systematic reviews [SEADS]) that contained any unpublished information on the efficacy and/or safety of their products when used specifically to treat TRD. SEADS allow an opportunity for the intervention developers and distributors to provide the Evidence-based Practice Center with both published and unpublished data that they believe should be considered for the review. Finally, a notice was also placed in the Federal Register requesting any relevant information on the use treatments for TRD.

Trained members of the research team dually reviewed all titles and abstracts for eligibility based on the pre-established inclusion/exclusion criteria presented in Table 1. Studies marked for possible inclusion by either reviewer underwent full-text review. Any study with inadequate information in the abstract also proceeded to full-text review. These researchers then dually reviewed each full-text article for inclusion or exclusion on the basis of the eligibility criteria. We documented reasons for exclusion at this stage; we also tagged those selected for inclusion with the relevant KQ that the article addressed. Disagreements about inclusion were resolved by consensus discussion.

### Data Abstraction and Data Management

From included systematic reviews, consensus statements, guidelines, and other relevant materials, we abstracted relevant information (e.g., definitions of TRD, study designs, methods, measures, and risk factors) to answer Narrative Review KQs 1 through 5. From all included individual intervention studies, we abstracted relevant information to answer Systematic Review KQs 6 through 11 (see below).

These steps allowed us to catalogue and describe the available controlled studies. We tracked all literature screening results in the EndNote database. We also recorded the reason that each excluded full-text publication did not satisfy the eligibility criteria.

We abstracted data relevant to the KQs from any studies that met our inclusion criteria into a standardized template. One member of the research team collected the data, and another (senior) investigator reviewed the abstraction for accuracy and completeness.

### Assessment of Risk of Bias of Included Studies

Two senior investigators independently assessed the risk of bias of only the individual studies included for KQ 10, because that is the only KQ for which we are assessing a causal relationship. We use risk of bias as a covariate in the regression analyses. Disagreements were resolved by discussion and consensus or by consulting an independent third party. We did not assess risk of bias of other studies as the report is a Technology Assessment.

For randomized controlled trials (RCTs), we used the Cochrane Risk of Bias tool.^27^ Elements of risk of bias assessment for RCTs include, among others, randomization and allocation concealment, similarity of compared groups at baseline, masking of patients and study personnel, use of intent-to-treat analysis, and overall and differential loss to followup.

For nonrandomized trials and observational studies, we employed criteria outlined by the Newcastle-Ottawa Scale, a commonly used tool for assessing quality of nonrandomized studies.^28^ Elements of this tool assess the comparability of baseline characteristics, the method of statistical adjustment for baseline confounding, and the assessment of outcomes.

### Data Synthesis

For the Narrative Review KQs, we present summary text and a series of tables that address each KQ. For example, for KQ 1, the summary table documents the variability of the definitions of TRD used; this information let us identify where any consensus appears to lie. Similar to KQ 1, separate summary tables for KQ 2^,^KQ 3, and KQ 4 present the various methods used to diagnose TRD and the measures and study designs that investigators use in TRD research. Such summary tables allow us to identify any consensus for these issues. Finally, for KQ 5, we report information on identified risk factors for TRD. For all these KQs, we have interpretative text summarizing the content of the tables. We did no quantitative analyses; rather, we provide a qualitative synthesis of what information in these tables mean as answers to these five KQs.

For the subquestions in KQ 2^,^KQ 3, and KQ 4, we developed separate summary tables that address the specific characteristics called out in these questions. Examples include diagnostic tools used in the different diagnostic settings, psychometric properties of measures used to determine efficacy or effectiveness, and study designs that have demonstrated effects on, for example, minimizing bias and placebo effects.

For this Narrative Review, we defined “consensus” in the following manner. “Consensus” reflects a “majority agreement” that can be arrived at in numerous ways. Such a “majority agreement” can be determined by guidelines or best practices, or consensus statements, or systematic reviews that represent state of the art consideration of the relevant topic, or other ways. Our charge was to identify a “consensus” in the TRD literature. Since there is no clearly identified group to formulate such an agreement, we believe that what is presented in consensus statements, clinical practice guidelines, government reports, and the peer-reviewed literature is a legitimate marker for agreement among clinical, research, and policy experts, especially if a majority of those citations appear to agree with each other over time. Hence, we consider such a majority count to indicate consensus.

For the Systematic Review KQs, we developed a similar series of tables addressing KQs 6 through 9 and KQ 11, again with summary text highlighting key findings based on the information in the various tables. For KQ 10 (regression or other statistical analysis), we first defined patient- and study-level covariates that might be relevant in examining correlations. Because we did not have access to individual patient data, we focused primarily on study-level characteristics (e.g., study design, study duration, risk of bias).

To avoid issues of ecological fallacy, whereby inferences about the nature of individuals are wrongly deduced from inferences for the group to which those individuals belong, we converted patient-level covariates to study-level covariates whenever possible (e.g., severity of depression to proportion of patients with severe depression in a study). To ensure consistency, we developed a data codebook and an analysis plan after we selected the covariates. We used Microsoft Excel and SAS software for data management, data cleaning, and graphical display of the data.

Regression or other statistical analyses focus on interventions for which we have at least 10 studies using a similar comparator intervention. ^63^Our main focus is on interventions in general for TRD; we did not focus any of our primary analyses on intervention type (e.g., rTMS vs. psychopharmacologic). We combined interventions into categories (e.g., pharmacological interventions, behavioral interventions). We classified comparator interventions as inactive (e.g., placebo, waiting list, sham) or active. We also selected relevant outcome measures, focusing insofar as possible on patient-centered outcomes.

For computational ease, we focused on dichotomous outcomes (odds ratios). We also recalculated the direction of effect, if necessary, so that an odds ratio >1 indicates a beneficial effect and an odds ratio <1 indicates a harmful effect.

The impact of the study- and patient-level characteristics on treatment effects for each outcome were assessed using random effects meta-regression models. The models were fit using SAS PROC GLIMMIX with a binomial likelihood and logit link function. To quantify the impact of a characteristic on the treatment effect, we computed the ratio of odds ratios and associated 95 percent confidence intervals to compare the odds ratio of the intervention effect (e.g., Brain Stimulation Therapy vs. control) for studies with the specified characteristic (e.g., included older adults) to the odds ratio for studies without the specified characteristic (e.g., did not include older adults). We began with bivariable analyses, comparing results for one characteristic at a time and then conducted multivariable analyses, including all of the characteristics that were significant in the bivariable analyses for the applicable outcome. Some study- and patient-level characteristics were excluded from the analyses owing to lack of variability across studies or high levels of missing data.

### Assessing Applicability

Applicability of findings may vary substantially by the PICOTS. For that reason, we highlight how variability of PICOTS elements could influence applicability (i.e., generalizability or external validity). For example, a TRD definition may differ by population, such as whether the depressive episode is part of MDD or bipolar disorder. Also, a TRD definition relevant to specialty psychiatric settings may not be applicable (or feasible) in primary care settings. Furthermore, findings may differ depending on the definition of the primary outcome of interest (e.g., depression remission vs. improved function).