# Evidence Summary

## Introduction

Patients with either major depressive disorder (MDD) or bipolar disorder can manifest depressive episodes. In 2015, 6.7 percent of adults in the United States (16.1 million people) experienced a depressive episode in the past year,^1^ with the great majority being a part of MDD.^2^ Treatment for MDD can be inadequate because either patients do not seek it or the care they receive is substandard.^3^ Even for patients receiving adequate treatment, only 30 percent (3% of patients with MDD) reach the treatment goal of full recovery or remission. The remaining 70 percent of MDD patients will either respond without remission (about 20%) or not respond at all (50%).^4^

Patients whose depressive disorder does not respond satisfactorily to adequate treatment clearly have harder-to-treat depression,^5^ generally referred to as treatment-resistant depression (TRD). TRD is a complex phenomenon influenced by variety in depressive subtypes, psychiatric comorbidity, and coexisting medical illnesses.^6^ It poses a common, challenging presentation to psychiatric and primary care clinicians.^7^

Although TRD episodes are most commonly associated with MDD, they are also seen in the depressed phase of bipolar disorder. More than 30 percent of those suffering from bipolar disorder and receiving treatment do not experience sustained remission of depressive symptoms.^8^

TRD has substantial effects on patients, their families, communities, and society at large. TRD represents the highest direct and indirect medical costs among those with MDD.^9^ Individuals with TRD are twice as likely to be hospitalized; the cost of this hospitalization is more than six times the mean total cost for depressed patients who are not treatment resistant.^10^ TRD can nearly double both direct and indirect 2-year employer medical expenditures relative to expenditures for patients whose MDD responds to treatment.^11^

TRD is especially relevant for Medicare beneficiaries. Mood disorders (mainly MDD and bipolar disorder) are the second leading cause of disability in Medicare patients under the age of 65.^12^ Depression in the elderly is associated with suicide more than at any other age;^13^ adults 65 or older constitute 16 percent of all suicide deaths.^14^ The decrease in average life expectancy for those with depressive illness, including Medicare beneficiaries, is 7 to 11 years.^15^ Depression is a major predictor of the onset of stroke, diabetes, and heart disease;^16^ it raises patients’ risk of developing coronary heart disease^16^ and the risk of dying from a heart attack nearly threefold.^17^

No universally accepted operational definition of TRD exists.^18^ Definitional dilemmas limit the ability of systematic reviewers or other experts to synthesize information and generalize the TRD findings to the array of patient populations encountered in daily practice. Moreover, varying conceptualizations of TRD have made translating research findings or systematic reviews into clinical practice guidelines challenging and inconsistent. Indeed, guideline definitions of TRD differ, agreement on what constitutes prior treatment adequacy is lacking, and recommended “next step” interventions can diverge.^19-23^

This systematic review was proposed as a large Technology Assessment by the Centers for Medicare & Medicaid Services and conducted for the Agency for Healthcare Research and Quality (AHRQ). We reviewed definitional and other aspects of TRD in clinical research. One aim is to inform future discussions and decisions about how to define the condition and specify the important outcomes measured in research studies. A second aim is to clarify how researchers might best design and conduct trials or observational to guide clinical practice and health policy.

## Methods

To provide a comprehensive and broad understanding of how various experts and investigators have defined and studied TRD, we examined 11 Key Questions (KQs) (Table A). The review was structured to address two categories of questions: a Narrative Review answering general questions, which was more qualitative and less structured than a systematic review and therefore used a more contextual narrative review approach, and a Systematic Review, which addressed specific study design questions.

Table A Key Questions

Narrative Review: KQs 1–5 (general questions) | Systematic Review: KQs 6–11 (specific study design questions)
1. What definitions of TRD appear in these sources and do definitions converge on a best one? 2. What methods do investigators use to diagnose this condition in clinical research, and does a consensus exist about the best ways to reach a clear diagnosis? 3. What measures (i.e., endpoints or outcomes) exist to determine the success or failure of treatment in TRD studies; what clinical focus do they represent (e.g., severity); what psychometric and other properties do they have? 4. What research designs do investigators use in TRD studies and does any consensus exist about best approaches to minimize bias and placebo effects and other elements of study design (e.g., length)? 5. What are the risk factors for TRD? | 6. What are the inclusion criteria for patients in these studies, specifically concerning patient characteristics, prior treatments, and diagnostic characteristics? 7. How do these criteria compare or contrast with definitions encountered in the narrative review? 8. What were primary characteristics of included studies, such as design, run-in or wash-out periods, and length? 9. How were included studies designed to account for TRD risk factors identified in the narrative review? 10. What are relationships between risk factors and results of included TRD studies? 11. What variables or information did included studies report (e.g., patient outcomes, time to relapse, treatment adherence, attrition, and use of health care resources)?

KQ = Key Question; TRD = treatment-resistant depression.

Table B provides an abbreviated list of PICOTS (populations, interventions, comparators, outcomes, time frames, and settings); Table 1 in the main report documents detailed inclusion/exclusion criteria.

We set eligible dates of English-language publications to focus on TRD treatments approved by the U.S. Food and Drug Administration, yield a reasonably comprehensive evidence base, and reflect contemporary approaches to TRD. We searched the published literature from 1/1/1995 through 8/18/2017. For the narrative KQs, we sought literature published since 1/1/95, except for systematic reviews, for which the start date was 1/1/2005. For the systematic KQs we set the publication date for intervention studies as 1/1/2005.

We followed standard procedures for systematic literature searches specified in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^24^ Although KQ 1 through 5 were narrative questions (which often turn up for systematic reviews), we nevertheless applied standard methods for the title/abstract and full-text review as much as possible to meet the typical global standards for this step. We searched for publications indexed in MEDLINE®, EMBASE, PsycINFO, and Cochrane Library; studies had to use TRD definitions with depressive diagnoses consistent with the Diagnostic and Statistical Manual of Mental Disorders, Fourth edition^25^ or 5th edition.^26^ Other materials included consensus statements, clinical practice guidelines, and relevant government reports; website sources were Clinicaltrials.gov, Guideline.gov (AHRQ’s National Guidelines Clearinghouse), HSRProj (https://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm) (Health Services Research Projects in Progress database), and UpToDate® (https://www.uptodate.com/home). To address the different types of questions for the two reviews (Table A), we sorted searches as follows: KQ 1 through 5 considered all sources noted above (including systematic reviews) except for individual intervention trials; only intervention trials were eligible for KQs 6 through 11.

We dually reviewed all titles and abstracts for eligibility. Studies marked for possible inclusion underwent full-text review, also done as dual reviews. Disagreements were resolved by consensus discussion.

One member of the research team abstracted data; another (senior) investigator reviewed the abstraction for accuracy and completeness. For KQ 10 involving additional (regression) analyses (explained in the main report), we assessed risk of bias with appropriate tools: for randomized controlled trials (RCTs), the Cochrane Risk of Bias tool;^27^ for nonrandomized trials and observational studies, the Newcastle-Ottawa Scale.^28^

The draft Technology Assessment was peer-reviewed and posted for public comment.

Table B Inclusion criteria (abbreviated) for Literature searches

PICOTS | Inclusion Criteria
Population | All adult populations (≥18 years old) identified as having a primary diagnosis of depression (including MDD and bipolar disorder) who have had a depressive episode and have not responded to treatment(s) (the least stringent definition of TRD). The depressive episode must be part of an MDD or a bipolar disorder.
Interventions | Any pharmacologic intervention tested as a treatment for TRD as a primary therapy or as an augmentation agent to an existing primary therapy. Any nonpharmacologic device or procedure tested as a treatment for TRD as a primary therapy or as augmentation to an existing primary therapy. Psychotherapy (i.e., cognitive behavioral therapy, third wave cognitive behavioral therapy, psychodynamic therapies, and integrative therapies) Complementary and alternative medicine (CAM) interventions and formal exercise programs.
Comparators | All those above in studies with concurrent control groups or control groups from an interrupted time series or pre/post studies with interrupted time series
Outcomes | Benefits that are reported as primary endpoints (or outcomes) Reduction in suicidal ideation or suicide attempts Quality of life Response to treatment Remission Change in depressive severity Functional capacity (physical and cognitive functioning measured by validated scales) Speed of remission Speed of response Intervention durability (rates or counts of recurrence of a depressive episode for those who have remitted) Adverse events from the intervention identified as either critical or important for decisionmaking Serious adverse events per Food and Drug Administration definition (rates or counts) Overall adverse events (rates or counts) Treatment discontinuations attributed to adverse events (rates or counts)
Timing | Any study duration
Setting | Studies in very highly developed countries^29^
Study Designs | [underlined: For KQs 1–5]: Consensus statements, guidelines, or other materials, and systematic reviews [underlined: For KQs 6–11]: Randomized, or prospective nonrandomized, or observational studies (including concurrent controls and interrupted time series)

## Results

We included 235 articles: 38 for KQ 1 through 5 and 197 for KQs 6 through 11. For KQs 6 through 11 articles, we identified 163 unique studies: 142 RCTs (88%), 4 nonrandomized trials (2%), 13 observational studies (8%), 2 case controls (1%), and 1 interrupted time series (<1%). The results reported below focus on only the “key points” drawn from our syntheses; the findings are reported in detail in two chapters of the main report.

### Narrative Review

#### Key Question 1 Definitions of Treatment-Resistant Depression

- We identified four categories of TRD definitions, distinguished primarily by number of previous failed antidepressant treatment attempts (Table C). Identified this way, individuals either did or did not have TRD.
- We identified five TRD staging models (which delineate the degree of resistance along a spectrum), but only limited research addressed reliability and validity. These models appeared to be equally valid for documenting treatment failure in depressed patients, but their applicability and feasibility in clinical practice are unclear (Table D). Identified this way, people could have TRD along a spectrum of severity.
- No consensus exists on the best TRD definition. However, the majority of systematic reviews and guidelines or consensus statements reported that the commonly used definitions were based on treatment of patients whose depression failed to respond (a decrease in depressive severity of at least half) or did not go into remission (complete recovery as measured by a score on a depressive severity instrument below a threshold) following two or more treatment attempts of an adequate dose and duration.
- Experts do not agree on how to define adequate dose and adequate duration, although the minimum duration cited is typically 4 weeks.

Table C Four categories of definitions of treatment-resistant depression by number of treatment failures and components of defintion

Number of Treatment Failures | Type of Publication on TRD Treatments, Date | Defines Nonresponse or Lack of Remission | Specifies Current Episode? | Defines Adequate Dose? | Defines Adequate Duration (weeks)?
1 or more | Seminal article on defining TRD, 1996^30^ SR - pharmacologic, 2007^31^ SR - lamotrigine augmentation, 2010^32^ SR - psychotherapy, 2011^33^ Review defining TRD, 2014^18^ SR - rTMS, 2015^34^ SR - rTMS, 2015^35^ SR - predictors of nonresponse, 2016^36^ | + +/-- -- - - - - - | -- +/-- -- -- -- -- + -- | + +/-- -- +/-- + -- -- -- | ≥6 ≥4 to ≥8 4 ≥6 6 to 8 -- 4 to 6 --
2 or more | Seminal article on definition of TRD, 2001^37^ SR - pharmacologic treatments, 2007^31^ ICER coverage policy analysis, 2012^38^ SR - lithium or atypical antipsychotics, 2013^39^ SR-rTMS, 2014^40^ SR - nonpharmacological, 2014^41^ Australian/New Zealand Clinical Practice Guideline, 2015^42^ SR - pharmacologic and somatic, 2016^43^ VA/DoD Clinical Practice Guideline, 2016^13^ | + ++/- + - + +/-- - -- - | + +/-- + +/-- +/-- +/-- -- +/-- -- | + ++/- - -- + + + -- + | ≥4 4 to 6 -- ≥4 ≥4 ≥4 ≥4 to 8 -- ≥4 to 6
3 or more | ICSI Adult Depression in Primary Care Guideline, 2016^21^ | + | -- | -- | --
For bipolar TRD: 1 or more | SR – nonpharmacological, 2014^41^ | + | -- | -- | 10 to 12
For bipolar TRD: 1 or more | Australian/New Zealand Clinical Practice Guideline, 2015^42^ | -- | -- | + | ≥3

Legend: + = definition was provided; - = definition was not provided; ++/- = more studies in review provided definition; +/- - = more studies in the review did not provide definition. ICER = Institute for Clinical and Economic Review; ICSI = Institute for Clinical Systems Improvement; MDD = major depressive disorder; SR = systematic review; TRD = treatment-resistant depression; VA/DoD = Veterans Administration/Department of Defense.

Table D Staging models for treatment-resistant depression to define the spectrum of illness

Models Authors and Year of Publication | How is Severity Scored? | Is Failure Defined? | Specify Current Episode? | Define Adequate Dose? | Define Adequate Duration? | Staging Schema | Predictive Validity and Reliability Tested? Other Comments
Antidepressant Treatment History Form^44^ | Sum score based on points per treatment | - | + | + | ≥4 weeks | 5 stages (0 to 5) | Predictive validity confirmed in 3 prospective ECT studies; reliability good in two studies. Does not correspond with number of treatment failures; does not count psychotherapy in failed trials
Thase and Rush Staging Model (TRSM)^5,31,44,45^ | Stages, with higher-numbered stages indicating a greater degree of treatment resistance | + | - | - | ≥4 weeks | 5 stages (1 to 5) | Predictive value has not been systematically assessed; reliability has not been tested. Stage II corresponds with 2 treatment failures; considers number of classes of ADs that have failed to provide a response but not psychotherapy
European Staging Model^44,46^ | Number of weeks with treatment resistance | + | + | - | Varies by nonre-sponder, TRD, and CRD | 3 categories: nonresponder, TRD, and CRD | Predictive value has not been systematically assessed; reliability has not been tested All TRD stages are consistent with 2 treatment failures
Massachusetts General Hospital Staging model (MGH-s)^44,^ ^45^ | Points based on number of prior failures | + | - | + | 6 weeks | 3 stages based on number of AD failures and 3 points for ECT failure | Retrospective chart review showed an association between higher MGH-s score and worse outcome; a retrospective study showed the MGH-s model better predicted nonremission than the TRSM. Reliability for these models was not tested. No direct correspondence with >2 treatment failures.
Maudsley Staging Model^44,^ ^46^ | Points per number of prior attempts, duration, symptoms severity, augmentation use, ECT | + | + | + | Varies by intervention | Points based on duration, symptom severity, number of treatment failures, augmentation, ECT | Only tool with prospective testing showing good validity; 2 studies showed the MSM score predicted future nonresponse significantly better than the TRSM. Reliability not tested. No direct correspondence with ≥2 treatment failures

Legend: + = definition was provided; - = definition was not provided; ++/- = more studies in review provided definition; +/- - = more studies in the review did not provide definition. AD = antidepressant; CRD = chronic resistant depression; ECT = electroconvulsive therapy; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; TRD = treatment-resistant depression.

#### Key Question 2 Preferred Diagnostic Tools

- No consensus exists about the preferred approach for diagnosing TRD.
  ○ The literature emphasizes that a diagnosis of a major depressive episode as a part of MDD or bipolar disorder can be made through a standard clinical evaluation (based on the Diagnostic and Statistical Manual) of Mental Disorders, International Classification of Diseases, or Research Diagnostic Criteria) or a through a more structured clinical assessment (Mini International Neuropsychiatric Interview, Structured Clinical Interview for the Diagnostic and Statistical Manual, or Schedule for Affective Disorders and Schizophrenia), but no preferred approach exists.
  ○ Diagnosing TRD further entails collecting a careful history before treatments (e.g., the number of prior pharmacologic attempts of adequate dose and duration that did not produce remission) or administering a structured, staging tool (Antidepressant Treatment Response Questionnaire, Thase Rush Staging Model, Massachusetts General Hospital Staging Model, or the Maudsley Staging Model) to confirm treatment resistance, but no preferred approach exists, the evidence base is limited, and careful history has not been compared directly with a structured tool.
- The medical setting has no influence on choice of diagnostic tool, although some issues of feasibility arise.

#### Key Question 3 Preferred Outcome Measures to Determine Success or Failure

- No consensus exists about the best outcome measure to use for TRD.
- The three main categories of outcome measures—depression-specific measures, general psychiatric status measures, and functional scales—have both patient-reported and clinician-administered versions available.
  ○ The most common depression-specific measure is the Hamilton Depression Rating Scale (HAM-D). Remission (complete recovery as measured by a score below a threshold) is the preferred endpoint regardless of tool.
  ○ General psychiatric status measures were infrequently described; most commonly reported was the Clinical Global Impression scale.
  ○ Various functional scales have been reported, but no one scale is the most frequently used.
- Most measures have adequate psychometric properties (e.g., reliability and validity) for measuring depressive outcomes.
- The minimum clinically important difference has been variably defined for many of these outcome measures, but none is a consensus preference.

#### Key Question 4 Preferred Study Designs for Treatment-Resistant Depression Treatment Intervention Studies

- Most investigators and expert groups preferred randomized designs over nonexperimental ones as a means of minimizing bias.
- Most available literature did not address, or apparently achieve consensus about, designs that might minimize placebo effects.
- No consensus exists about the appropriate or necessary length of trials or other studies of TRD. A study length of “at least 6 weeks” was often recommended.
- Studies also recommended using whole structured clinical interviews to diagnosis depression, because these full assessments could better confirm the MDD (or bipolar) diagnosis and clarify psychiatric comorbidity, seen as a key potential confounder in TRD treatment trials.
- Getting patients to an adequate dose of a given medication may take a few weeks; for that reason, 6 weeks of adequate dosing may require a trial length longer than 6 weeks.
- Compliance and consideration of prior psychotherapy use are important to assess and control for in analyses.

#### Key Question 5 Risk Factors for Treatment-Resistant Depression

- Evidence about what risk factors are associated with a TRD diagnosis is quite limited.
- Several components of depression (disease severity, duration of current episode, number of previous hospitalizations, and number of failed antidepressant trials) appeared to be associated with increased risk of TRD.
- The sociodemographic variables of age (older) and marital status (divorced or widowed) increased the risk of TRD.
- Coexisting anxiety symptoms, anxiety disorders, and personality disorders were associated with TRD.
- Some other clinical characteristics (such as having melancholic features, suicidality) were associated with greater risk of TRD.

### Systematic Review

We divided interventions into four categories:

- Brain stimulation treatments (BST): electroconvulsive therapy, repetitive transcranial magnetic stimulation, vagal nerve stimulation, and deep brain stimulation (73 studies);
- Pharmacotherapy (71 studies);
- Psychotherapy (11 studies); and
- Complementary and alternative medicine (CAM) therapies and exercise (8 studies).

#### Key Question 6 Inclusion Criteria for Intervention Studies

- Confirmation of TRD for study entry was often poorly described.
- The HAM-D and the Montgomery—Åsberg Depression Rating Scale were commonly used to set minimum depressive severity thresholds for study entry; most studies involved patients with moderately severe depression.
- Studies were inconsistent about the necessary duration of prior treatment attempts for study entry.
- Most studies required at least one, and often two, prior failed treatment attempts of adequate therapy.
- Several patient characteristics were rarely considered for study entry: duration of depressive symptoms, prior depressive relapses, prior treatment intolerance, prior augmentation or combination therapy, prior psychotherapy, and suicidality.

#### Key Question 7 Inclusion Criteria Compared with Definitions of Treatment-Resistant Depression

- Inclusion criteria as specified by the eligible TRD studies did not closely align with the definition(s) of TRD identified in the narrative review.
- Although the most common definition of TRD from our narrative review involved a minimum of two failed prior adequate antidepressant studies, the most common definition in included studies was a minimum of one failed trial (49%) (only 38% required a minimum of two failed trials).
- Of all 163 studies, 77 percent considered in their selection criteria whether the patient had been treated previously with an adequate dose; 58 percent systematically confirmed that the dose was adequate by specifying dosage levels through interview, questionnaire, or other formal clarifications.
- Of all 163 studies, 82 percent considered in their selection criteria whether prior treatments were of adequate duration; 72 percent systematically confirmed that the duration was adequate (≥ 4 weeks of treatment).
- Thirty-three percent of the studies set inclusion criteria based on stage of TRD using a staging model.
- Seventeen percent of studies had all the most commonly described criteria for TRD: a minimum of two prior treatment failures, confirmation that a dose was adequate, and confirmation that duration was 4 weeks or longer.

#### Key Question 8 Characteristics (Design) of Included Studies

- Most studies had RCT designs (88%); this rate did not differ by intervention type.
- Few studies had run-in periods (21%) or wash-out periods (23%).
- Study duration varied across studies, ranging from less than 2 weeks to more than 4 years; the majority of BST studies (the most common intervention type) lasted <2 months (62%).

#### Key Question 9 Controlling for Potential Confounders

- A considerable majority (88%) used randomization as a means to control for potential confounders.
- All studies applied some exclusion criteria to limit potential confounders. Number of prior failed treatments, psychiatric and medical comorbidities, and severity of disease were the most commonly applied restriction factors to achieve homogeneous study populations.
- Several studies (20%) stratified analyses by potential confounders. Generally, these factors were age, sex or gender, number of prior failed treatments, and duration of current depressive episode.
- Of 20 nonrandomized studies, only eight reported statistical techniques to control for potential confounding.

#### Key Question 10 Addressing Risk Factors and Their Relationship to Outcomes

- For most risk factors that might influence treatment response, data were either insufficient for regression analyses or reflected no statistically significant impact on study results.
- In a comparison of pharmacotherapy with pharmacotherapy plus augmentation with a second medication, multivariable analyses indicated that female sex had a significant effect on discontinuation; studies with 60 percent or more female participants had statistically significantly higher discontinuation rates because of adverse events (ratio of odds ratios = 2.81; 95% confidence interval, 1.04 to 7.59) than studies with fewer than 60 percent females.
- A smaller placebo response was associated with a statistically significantly larger treatment effect for response (p=0.027), remission (p=0.001), and discontinuation because of adverse events (p=0.010). Study duration did not have an impact on placebo response.

#### Key Question 11 Key Study Outcomes

- The two most common outcome measures used to assess depression were the HAM-D and the Montgomery—Åsberg Depression Rating Scale.
- Assessment of manic outcomes was rare.
- The Clinical Global Impression scale was the most common general psychiatric outcome reported, nearly always in pharmacology studies and less than half the time in BST studies.
- Functional impairment and quality-of-life outcomes were infrequently reported.
- Other than in psychotherapy studies, adherence to treatment was not commonly reported.
- Overall attrition was a frequently reported outcome, but specific reasons for attrition (e.g., adverse events or lack or efficacy) were less often described.
- Disability status, time to relapse, and use of health care services were very rarely reported.

## Discussion

Our narrative review indicated that no consensus definition existed for TRD. We identified four basic definitions for TRD (three for MDD, one for bipolar disorder). The most common TRD definition for MDD requires a minimum of two prior treatment failures and confirmation of prior adequate dose and duration. No clear consensus emerged on how to define adequacy of either dose or duration. We identified little consensus about the best tools to diagnose TRD or measure its outcome. We saw some agreement on the benefit of minimizing bias by randomization; most of the literature did not address, or apparently achieve consensus about, designs that might minimize placebo effects. Evidence identifying risk factors for TRD and data to assess potential prognostic factors were limited.

Our systematic review indicated that inclusion criteria as specified by the eligible TRD trials or observational studies generally did not closely align with TRD definitions from the narrative review. Only 17 percent of studies reported “two prior treatment failures and confirmation of prior adequate dose and duration.” Most studies (88%) were RCTs, and all applied some exclusion criteria to limit potential confounders. Depressive outcomes were the frequently reported endpoints; clinical global impressions were also often assessed. Functional impairment and quality of life tools were infrequently used.

### Findings in Relationship to What Is Already Known

The variability in the definitions and conceptualization of TRD (from our narrative review) is consistent with other reports from the past decade identifying the lack of any standard, systematic definition of TRD.^18,^ ^31,^ ^44,^ ^47^ Indeed, defining the adequacy of dose and duration, clarifying failure (as remission or response and after what length of time), and determining whether TRD requires the prior use of different classes of antidepressants are all variably defined and implemented. Taken together, the available literature highlights the resulting difficulty in synthesizing information across trials or other types of studies or documents. This characteristic of the evidence base also underscores the problems of translating research findings into guidelines for selecting better treatment options for patients with TRD.

Our systematic review highlighted some key findings not previously described. The mismatch between the most common number of treatment failures (at least two) and what most recent literature has assessed (at least one failure) was stark. Also, the failure of inclusion criteria in recent TRD studies to confirm systematically both adequate dose (58%) and duration (72%) has not previously been described, nor has the finding that only 17 percent of recent intervention studies are consistent with the most common definition of TRD. These results highlight another concern about how to compare and synthesize data across treatment studies.

Finally, despite the substantial morbidity associated with TRD, the relative infrequency of use of patient-oriented outcomes such as functional impairment and quality-of-life measures in considering the benefits of TRD treatment was newly demonstrated. So too was the infrequent measurement of both adherence to treatment or health care services use.

### Implications for Clinical and Policy Decisionmaking

This current state of evidence underscores the challenges facing clinicians. Effective treatments exist, but because of the variability in TRD definitions and study populations, determining to which patients the results apply is difficult. Similarly, the state of the evidence poses challenges for policymakers. Officials, at both Centers for Medicare & Medicaid Services and other public agencies or private-sector organizations, must be confident that two main assumptions are being met. The first is that the population of patients with TRD is being consistently and systematically defined; the second is that meaningful and comparable outcomes of importance to both patients and clinicians are being monitored. Neither is consistently reported in the literature, limiting translation of this treatment information into actual care.

The high level of morbidity associated with TRD is clear. For adequate clinical and policy decisionmaking about TRD patients, however, a widely agreed-upon definition of the condition that addresses how to best determine the number of prior treatment failures and the adequacy of dose and duration is critical. Some means of systematically monitoring this for TRD on a large scale (e.g., a treatment registry using common data elements in an electronic medical record) could substantially help clarify which criteria best define TRD, what the course of illness is, and how interventions might affect that course.

### Limitations of this Technology Assessment

#### Comparative Effectiveness Review Process

The primary challenge of this process was the broad, comprehensive, and inclusive nature of topic, which combined a narrative review (for five KQs) and a systematic one (for six KQs). Given how variable the definitions of TRD are in the literature, we needed to cast a wide net for both published and gray literature to assemble the proper universe of sources that could be managed within a reasonable amount of time and resources. We addressed this challenge by focusing the 11 KQs and the time periods for the literature searches to reflect current conceptualizations of TRD.

#### The Evidence Base

The primary limitation of this evidence base is the heterogeneity of TRD definitions encountered in both reviews (KQ 1 through 5 and KQs 6 through 11). With no agreed-upon definition of TRD and no consensus on very important outcomes, determining to what population clinical trials results apply is difficult. This heterogeneity will prevent others from synthesizing or combining data, even for the more common TRD interventions such as brain stimulation technologies or medications, to translate findings into clinical practice recommendations.

Furthermore, data were insufficient to reliably assess prognostic factors that can predict outcomes of TRD treatment.

### Research Recommendations

We propose several steps to address existing evidence gaps and substantially improve the study and treatment of patients with TRD.

Reducing the heterogeneity of how TRD patient populations are defined is a necessary first step. Perhaps the most critical task is to reach agreement on a standardized, systematic, and feasible definition of TRD. Such a definition should clearly specify the number of prior treatment attempts, what an adequate dose is, and what an adequate duration is. At the very least, the minimum number of past failed therapy attempts should be two. Systematic confirmation of adequacy of prior treatment attempts is a necessary part of this “definitional” step.

Systematic, standardized accounting for potential confounders is also crucial. The factors that must be considered include the following: depressive severity, duration of current episode, prior treatment intolerance, prior augmentation or combination therapy, prior psychotherapy, and psychiatric comorbidities. Other socio-cultural factors that may influence the course of TRD (e.g., gender and age) may also be relevant and deserve further study, as may genetic factors.^42^ Randomization can account for some measured and unmeasured confounders in larger trials, but the smaller RCTs that we identified had imbalances in baseline characteristics and rarely adjusted for such differences. Moreover, nonrandomized TRD studies adjusted for potential confounders less than half of the time

Agreement on a package of outcome measures to be administered in a standard way should be strongly encouraged. The field would benefit from an evidence-informed, multi-stakeholder consensus process to develop a core outcomes set for TRD, potentially something similar to the Outcome Measures in Rheumatology (OMERACT) process in rheumatology (https://www.omeract.org/). Of particular importance is including one measure of depressive severity, one measure of general psychiatric status, one measure of functional impairment or quality of life, and one measure of adherence to medications or other interventions. Another key outcome to consider includes a measure of suicidality (to assess for reduction in suicidality). Common use of measures will allow for better comparisons among trials; it should improve our ability to combine studies for meta-analyses. Patient-reported instruments may be preferred because they are more feasible, generally speaking, and more patient centered than clinician-reported instruments.

Researchers and clinicians should come to consensus on a standard length of treatment. The key is to provide enough time for patients to receive an adequate dose and duration of the intervention. Given the chronicity of TRD and the time to reach an adequate dose and length of treatment, at least 2 months is the bare minimum for studies to be conducted. Also, the increasing risk of relapse with greater levels of resistance7 argues for the need to demonstrate longer term efficacy for the more resistant patients, suggesting a need for even longer trials for the more severely resistant. For this latter group, who may have a more chronic and persistent course, different treatments might be required than for those whose depressive episodes are more episodic.

Whether either run-in stages or wash-out periods affect the efficacy or effectiveness of TRD treatments remains unclear. Comparative trials should examine this issue to clarify whether investigators should use one or the other in designing their trials.

We found only a very few studies of interventions other than pharmacological or BST interventions (that is, psychotherapies and CAM or exercise as remedies for TRD). This gap reduced the evidence base relevant for patients who prefer to avoid, or for whom it would be inappropriate to try, pharmacological agents or more invasive procedures. Consideration of less-studied interventions could help inform patient decisions about options and improve the level of shared or informed decisionmaking.

Trials or robust types of observational studies to test the effectiveness of all such interventions in real-world settings are necessary. Targeting only efficacy (via RCTs) may produce information for clinicians, patients, or policymakers that cannot easily be applied in “ordinary,” every-day circumstances.

To allow for better assessment of quality in TRD, publications of RCTs need to adhere to Consolidated Standards of Reporting Trials specifications for reporting.^48^ Similarly, publications of nonrandomized controlled trials or observational studies should adhere to Strengthening the Reporting of Observational Studies in Epidemiology (STROBE).^49^ Documenting all steps in such investigations, reporting on all planned outcomes, and otherwise ensuring complete transparency for this work are critical actions in adding to the professional literature. These steps would help ensure a consistent definition of TRD and its reported outcomes.

Finally, TRD needs to be monitored, consistently, systematically, and on a large scale. For instance, a treatment registry using common data elements could substantially help clarify the criteria that best define TRD, what the course of illness is, and how interventions might affect that course. Coordination between different specific treatment registries that already exist (e.g., the vagal nerve stimulation registry required by the U.S. Food and Drug Administration,^50,51^ and the transcranial magnetic stimulation registry recently launched by Neurostar^52^) and that have been suggested (e.g., a ketamine registry^53^) would be a necessary step. Data quality would be a key challenge for such an enterprise.

### Conclusions

We encountered substantial diversity at every stage of research on TRD interventions. Of particular concern was the lack of consensus about various elements of even a TRD diagnosis and appropriate inclusion or exclusion criteria. Additionally, little or no agreement about important outcomes and how to assess them hampered analysis. An extensive set of recommendations about additional and more robust approaches to the design and conduct of this research will foster better evidence to translate into clearer guidelines for treating patients with this serious condition.