# Appendix D Risk of Bias Ratings

Table D1 Risk of bias assessments for TRD studies eligible for Key Question 10 regression analysis

Author, Year Study | Randomization adequate? | Allocation concealment adequate? | Baseline characteristics similar? (Especially With Regard to KQ10 Patient-Level Covariates) | Outcome assessors masked? | Care providers masked? | Patients masked? | % Completed Treatment
Altamura, 2008^143^ NA | Unclear | Unclear | No | Yes | No | Yes | Overall: 100 G1:100 G2:100
Avery, 2006^145^ NA | Yes | Unclear | Yes | Yes | No | Yes | Overall: 91 G1:91 G2: 91
Barbee, 2011^150^ NA | Yes | Yes | No | Yes | Yes | Yes | Overall: 68 G1: 71 G2: 65
Berman, 2007^159^ NA | Unclear | Yes | Yes | Yes | Yes | Yes | Overall: 88 G1:90.9 G2: 87.9
Berman, 2009^160^ NA | Unclear | Unclear | Yes | Yes | Unclear | Yes | Overall: 85 G1:83 G2: 87
Blumberger, 2012^161^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 59 G1: 64 G2: 46 G3: 68
Blumberger, 2016^162^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 84 G1:83 G2: 83 G3: 85
Concerto, 2015^170^ NA | Unclear | Unclear | Yes | Unclear | No | Yes | Overalls 00 G1:100 G2:100
Cusin, 2013^172^ NA | Unclear | Yes | No | Unclear | Yes | Yes | Overall: 70 G1: 73 G2: 67
Durgam, 2016^180^ NA | Yes | Yes | Yes | Yes | Yes | Yes | Overall: 82 G1: 76 G2: 83 G3: 87
El-Khalili, 2010^183^ NA | Yes | Unclear | Yes | Unclear | Unclear | Yes | Overall: 77 G1: 77 G2: 70 G3: 85
Fava, 2012^186^ Dording, 2013^187^ Mischoulon, 2012^188^ NA | Yes | Yes | Yes | Yes | Yes | Yes | Overall: 88 G1:86 G2: 90
Fitzgerald, 2006^191^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 94 G1:100 G2: 88
Fitzgerald, 2008^193^ NA | Unclear | Unclear | Yes | Yes | No | Yes | Overall: 94 G1:100 G2: 88
Fitzgerald, 2016^200^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 87 G1:83 G2: 91
Garcia-Toro, 2006^204^ NA | Unclear | Unclear | Unclear | Yes | No | Yes | Overall: 100 G1:100 G2:100
George, 2010^205^ McDonald, 2011^206^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 81 G1: 78 G2: 83
Kamijima, 2013^213^ Ozaki, 2015^214^ NA | Unclear | Yes | Yes | Yes | No | Yes | Overall: 92 G1: 92 G2: 91 G3: 91
Keitner, 2009^216^ NA | Unclear | Unclear | No | Yes | No | Yes | Overall: 86 G1: NR G2: NR
Lenze, 2015^226^ Kaneriya, 2016^227^ NA | Yes | Yes | Unclear | Yes | No | Yes | Overall: 94 G1: 96 G2: 92
Levkovitz, 2015^230^ NA | Yes | Yes | Yes | Yes | Yes | Yes | 5 week (primary endpoint) Overall: 88 G1: 92 G2: 86 End of study Overall: 39 G1: 48 G2: 30
Mahmoud, 2007^232^ NA | Yes | Yes | Yes | Yes | Yes | Yes | Overall: 85 G1: 81 G2: 88
Martinot, 2010^233^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 96 G1: 94 G2: 95232 G3:100
McDonald, 2006^236^ NA | Unclear | Unclear | No | Yes | Unclear | Yes | Overall: NR G1: NR G2: NR
Mogg, 2008^240^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 93 G1: 97 G2: 90
O’Reardon, 2007^253^ Lisanby, 2009^254^ Solvason, 2014^255^ Janicak, 2008^256^ NA | Unclear | Unclear | Yes | Yes | Yes | Yes | Full Sample Overall: 86 G1: 87 G2: 84 Modified ITT sample Overall: 92 G1: 92 G2: 92
Paillere Martinot, 2010^257^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 96 G1: 94 G2: 100 G3: 95
Pallanti, 2010^258^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 100 G1: 100 G2: 100 G3: 100
Papakostas, 2015^264^ Mischoulon, 2017^265^ NA | Yes | Yes | Yes | Yes | Yes | Yes | Overall: 73 G1: 69 G2: 78
Ravindran, 2008^277^ NA | Unclear | Unclear | Yes | Yes | Unclear | Yes | Overall: 90 G1: 85 G2: 94
Rossini, 2005^281^ NA | Yes | Yes | Yes | Yes | No | Yes | Overall: 96 G1: 95 G2: 100 G3: 94

G = Group; ITT = Intention to Treat; KQ = Key Question; NR = Not Reported; TRD = Treatment Resistant Depression

Table D2 Risk of bias assessments for TRD studies eligible for Key Question 10 regression analysis, part 2

Author, Year Study | Was overall attrition ≥20%? | Was differential attrition ≥15%? | Did the study use ITT analyses? | Method of Handling Dropouts in ITT Analysis | Could selective reporting of outcomesbe an issue? | Other bias? | Risk of Bias | Notes Explain High Risk of Bias Ratings
Altamura, 2008^143^ NA | No | No | Yes | NA | No | Yes | Medium | NA
Avery, 2006^145^ NA | No | No | Yes | LOCF | No | No | Low | NA
Barbee, 2011^150^ NA | Yes | No | Yes | LOCF | No | No | Medium | NA
Berman, 2007^159^ NA | No | No | Yes | LOCF | No | Unclear | Low | NA
Berman, 2009^160^ NA | No | No | Yes | LOCF | No | No | Low | NA
Blumberger, 2012^161^ NA | Yes | Yes | Yes | Not reported | No | No | High | Unclear
Blumberger, 2016^162^ NA | No | No | Yes | Not reported | No | No | Low | NA
Concerto, 2015^170^ NA | No | No | N/A | NA | No | No | High | Blinding of outcome assessor not clear
Cusin, 2013^172^ NA | Yes | No | Yes | LOCF | No | No | Medium | NA
Durgam, 2016^180^ NA | No | No | Yes | Not reported | No | Unclear | Low | NA
El-Khalili, 2010^183^ NA | Yes | No | Yes | LOCF | No | No | Medium | NA
Fava, 2012^186^ Dording, 2013^187^ Mischoulon, 2012^188^ NA | No | No | Yes | LOCF | No | No | Low | NA
Fitzgerald, 2006^191^ NA | No | No | Yes | LOCF | No | No | Low | NA
Fitzgerald, 2008^193^ NA | No | No | Yes | LOCF | No | No | Low | NA
Fitzgerald, 2016^200^ NA | No | No | Yes | LOCF | No | Unclear | Low | NA
Garcia-Toro, 2006^204^ NA | No | No | No | NA | Unclear | No | Medium | NA
George, 2010^205^ McDonald, 2011^206^ NA | no | No | Yes | Not reported | No | No | Low | NA
Kamijima, 2013^213^ Ozaki, 2015^214^ NA | No | No | Yes | LOCF | No | Unclear | Low | NA
Keitner, 2009^216^ NA | No | Unclear | Yes | Not reported | No | No | Medium | NA
Lenze, 2015^226^ Kaneriya, 2016^227^ NA | No | No | Yes | Not reported | No | No | Medium | NA
Levkovitz, 2015^230^ NA | No | No | Yes | LOCF | No | Unclear | Medium | NA
Mahmoud, 2007^232^ NA | No | No | Yes | LOCF | No | No | Low | NA
Martinot, 2010^233^ NA | No | No | Yes | Modified ITT | No | No | Low | NA
McDonald, 2006^236^ NA | Unclear | Unclear | Unclear | Not reported | No | Yes | High | Unclear if care providers blinded to treatment assignment, in particular whether providers or technicians set up the TMS/placebo procedure. Procedure for collecting all measures was inconsistent, sometimes collected by patients and sometimes collected by research assistants. Not possible to determine direction of potential bias resulting from this. Information on treatment completion, attrition, missing data are poorly reported, making it difficult to be confident about these elements. It is possible (but unclear) all participants completed treatment, but data missing for about 18% of sample. Although authors state that they used ITT analyses, lack of clear reporting of dropouts or missing data makes it difficult to confirm that a true ITT analysis was performed.
Mogg, 2008^240^ NA | No | No | Yes | Not reported | No | Unclear | Medium | NA
O’Reardon, 2007^253^ Lisanby, 2009^254^ Solvason, 2014^255^ Janicak, 2008^256^ NA | No | No | Yes | LOCF | Yes | No | Medium | NA
Paillere Martinot, 2010^257^ NA | No | No | Yes | LOCF | No | No | Low | NA
Pallanti, 2010^258^ NA | No | No | No | NA | No | No | Low | NA
Papakostas, 2015^264^ Mischoulon, 2017^265^ NA | Yes | No | Yes | Not reported | No | Unclear | Medium | NA
Ravindran, 2008^277^ NA | No | No | Yes | Not reported | No | Unclear | Low | NA
Rossini, 2005^281^ NA | No | No | No | NA | No | Unclear | Low | NA

ITT = Intention to Treat; LOCF = Last Observation Carried Forward; NA = Not Applicable; TRD = Treatment Resistant Depression; TMS = Transcranial Magnetic Stimulation.