# Appendix C Evidence Tables

Table C1 Eligible and reported patient characteristics from key question 6

Table C2 Eligible and reported prior treatment characteristics from key question 6

Table C3 Eligible and reported diagnostic characteristics from key question 6

Table C4 Characteristics of systematic review studies from key question 8

Table C5 Risk factors of systematic review studies from key question 9

Table C6 Details of key question 10 studies eligible for regression analysis

Table C7 Endpoint data from key question 11