# Appendix B Excluded Studies

Exclusions:

X1: Ineligible publication type

X2: Ineligible populations

X3: Ineligible or no interventions

X4: Ineligible or no comparators

X5: Ineligible or no outcomes

X6: Wrong country

X7: Ineligible study design

X8: Does not answer a KQ of the review

X9: Abstract-only record (otherwise eligible)

X10: Irretrievable

X11: SR Published prior to 2006

X12: Duplicate

X13: Exclude due to new 2005 criteria

X14: Exclude, updated publication found

X15: Excluded primary or companion, to be cited in review

X16: Excluded for not meeting Systematic Review (SR) quality criteria

1 Vagus nerve stimulation for treatment-resistance depression. Technol Eval Cent Assess Program Exec Summ. 2005 Aug;20(8):1-2. PMID: 16156089. Exclusion Code: X10.16156089
2 Transcranial magnetic stimulation: Potential new treatment for resistant depression. J Clin Psychiatry. 2007;68(2):315-30. doi: 10.4088/JCP.v68n0219. PMID: 2007-074226-019. Exclusion Code: X1.17335332
3 FDA Executive Summary: Prepared for the January 2728, 2011 meeting of the Neurological Devices Panel. Meeting to Discuss the Classification of Electroconvulsive Therapy Devices (ECT). Silver Spring, MD: United States Food and Drug Administration; 2011. https://wayback.archiveit.org/7993/20170114044018/http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/MedicalDevices/MedicalDevicesAdvisoryCommittee/NeurologicalDevicesPanel/UCM240933.pdf. Accessed 31 Jan, 2017. Exclusion Code: X1.
4 Abdallah CG, Fasula M, Kelmendi B, . Rapid antidepressant effect of ketamine in the electroconvulsive therapy setting. J ECT. 2012 Sep;28(3):157-61. doi: 10.1097/YCT.0b013e31824f8296 [doi]. PMID: 22847373. Exclusion Code: X2.22847373
5 Agency for Healthcare Research and Quality. Surveillance Report: Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults Comparative Effectiveness Review No. 33. (Prepared by RTI International-University of North Carolina under Contract No. 290-02-0016I, TO #2.) AHRQ Publication No. 11-EHC056-EF. Rockville, MD: Agency for Healthcare Research and Quality; April 2016. https://effectivehealthcare.ahrq.gov/searchfor-guides-reviews-andreports/?pageaction=displayproduct&productID=1545 Exclusion Code: X7.
6 Ahmad H, Soldani F. Risk-benefit & decision analyses of electroconvulsive therapy (ECT) in treatment refractory depression. Bipolar Disorders. 2013;15((Ahmad H.; Soldani F.) US Food and Drug Administration (FDA), Silver Spring, United States):102-3. Exclusion Code: X9.
7 Aiyer R, Joffe RT. Deep brain stimulation in treatment resistant depression: A systematic review. Current Psychopharmacology. 2015;4(1):10-6. Exclusion Code: X1.
8 Alexopoulos GS, Reynolds CF, 3rd, Bruce ML, . Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. 2009 Aug;166(8):882-90. doi: 10.1176/appi.ajp.2009.08121779. PMID: 19528195. Exclusion Code: X2.19528195
9 Amital D, Fostick L, Silberman A, . Serious life events among resistant and nonresistant MDD patients. J Affect Disord. 2008 Oct;110(3):260-4. doi: 10.1016/j.jad.2008.01.006. PMID: 18262654. Exclusion Code: X2.18262654
10 Amsterdam JD, Garcia-Espana F, Rosenzweig M. Clomipramine augmentation in treatment-resistant depression. Depress Anxiety. 1997;5(2):84-90. doi: 10.1002/(SICI)1520-6394(1997)5:2<84::AID-DA4>3.0.CO;2-5 [pii]. PMID: 9262938. Exclusion Code: X13.9262938
11 Amsterdam JD, Lorenzo-Luaces L, DeRubeis RJ. Step-wise loss of antidepressant effectiveness with repeated antidepressant trials in bipolar II depression. Bipolar disorders. 2016 Nov 2;18(7):563-70. doi: 10.1111/bdi.12442. PMID: CN-01288389. Exclusion Code: X2.27805299
12 Amsterdam JD, Shults J. Does tachyphylaxis occur after repeated antidepressant exposure in patients with Bipolar II major depressive episode? J Affect Disord. 2009 May;115(1-2):234-40. ; 10.1016/j.jad.2008.07.007 [doi]. PMID: 18694599. Exclusion Code: X2.18694599
13 Anderson IM, Delvai NA, Ashim B, . Adjunctive fast repetitive transcranial magnetic stimulation in depression. Br J Psychiatry. 2007 Jun;190:533-4. ; 10.1192/bjp.bp.106.028019 [doi]. PMID: 17541116. Exclusion Code: X2.17541116
14 Anderson IM, Ferrier IN, Baldwin RC, . Evidence-based guidelines for treating depressive disorders with antidepressants: a revision of the 2000 British Association for Psychopharmacology guidelines. J Psychopharmacol. 2008 Jun;22(4):343-96. doi: 10.1177/0269881107088441. PMID: 18413657. Exclusion Code:18413657
15 Appelberg BG, Syvalahti EK, Koskinen TE, . Patients with severe depression may benefit from buspirone augmentation of selective serotonin reuptake inhibitors: results from a placebo-controlled, randomized, double-blind, placebo wash-in study. J Clin Psychiatry. 2001 Jun;62(6):448-52. PMID: 11465522. Exclusion Code: X13.11465522
16 Aronson R, Offman HJ, Joffe RT, . Triiodothyronine augmentation in the treatment of refractory depression. A metaanalysis. Arch Gen Psychiatry. 1996 Sep;53(9):842-8. PMID: 8792761. Exclusion Code: X11.8792761
17 Association AP. Practice guideline for the treatment of patients with major depressive disorder. 2 ed: American Psychiatric Association; 2000. Exclusion Code: X14.
18 Avery DH, Claypoole K, Robinson L, . Repetitive transcranial magnetic stimulation in the treatment of medication-resistant depression: preliminary data. J Nerv Ment Dis. 1999 Feb;187(2):114-7. PMID: 10067953. Exclusion Code: X13.10067953
19 Avery DH, Holtzheimer PE, 3rd, Fawaz W, . Transcranial magnetic stimulation reduces pain in patients with major depression: a sham-controlled study. J Nerv Ment Dis. 2007 May;195(5):378-81. doi: 10.1097/NMD.0b013e31802f58d1 . PMID: 17502802. Exclusion Code: X5.17502802
20 Baeken C, Duprat R, Wu GR, . Subgenual Anterior Cingulate-Medial Orbitofrontal Functional Connectivity in Medication-Resistant Major Depression: A Neurobiological Marker for Accelerated Intermittent Theta Burst Stimulation Treatment? Biological Psychiatry: Cognitive Neuroscience and Neuroimaging. 2017((Baeken C., cbaeken@hotmail.com; Duprat R.; Wu G.-R.; van Heeringen K.) Department of Psychiatry and Medical Psychology, Ghent University, Ghent)doi: 10.1016/j.bpsc.2017.01.001. Exclusion Code: X4.
21 Bahk WM, Woo YS, Seo HJ, . Nicotinic acetylcholine receptor antagonists for treatment-resistant depression: A meta-analysis. Eur Psychiatry. 2016;33((Bahk W.M.; Woo Y.S.; Seo H.J.; Wang H.R.) Yeouido St. Mary’s Hospital, Psychiatry, Seoul, South Korea):S226. Exclusion Code: X3.
22 Ballard ED, Ionescu DF, Vande Voort JL, . Improvement in suicidal ideation after ketamine infusion: relationship to reductions in depression and anxiety. J Psychiatr Res. 2014 Nov;58:161-6. doi: 10.1016/j.jpsychires.2014.07.027. PMID: 25169854. Exclusion Code: X4.25169854
23 Barbosa L, Berk M, Vorster M. A double-blind, randomized, placebo-controlled trial of augmentation with lamotrigine or placebo in patients concomitantly treated with fluoxetine for resistant major depressive episodes. J Clin Psychiatry. 2003 Apr;64(4):403-7. PMID: 12716240. Exclusion Code: X13.12716240
24 Barbui C, Butler R, Cipriani A, . Depression in adults: drug and physical treatments. BMJ Clin Evid. 2007;2007. PMID: 19454086. Exclusion Code: X8.19454086
25 Barowsky J, Schwartz TL. An evidence-based approach to augmentation and combination strategies for treatment-resistant depression. Psychiatry. 2006 Jul;3(7):42-59. PMID: 2007-02351-004. Exclusion Code: X1.
26 Bauer M, Demyttenaere K, El-Khalili N, . Pooled analysis of adjunct extended-release quetiapine fumarate in patients with major depressive disorder according to ongoing SSRI or SNRI treatment. Int Clin Psychopharmacol. 2014 Jan;29(1):16-25. doi: 10.1097/YIC.0000000000000011 [doi]. PMID: 24108148. Exclusion Code: X7.24108148
27 Bauer M, Dopfmer S. Lithium augmentation in treatment-resistant-depression: metaanalysis of placebo-controlled studies (Structured abstract). J Clin Psychopharmacol. 1999;19(5):427-34. PMID: DARE-11999001921. Exclusion Code: X11.10505584
28 Bauer M, El-Khalili N, Datto C, . A pooled analysis of two randomised, placebo-controlled studies of extended release quetiapine fumarate adjunctive to antidepressant therapy in patients with major depressive disorder. J Affect Disord. 2010 Dec;127(1-3):19-30. ; 10.1016/j.jad.2010.08.032 [doi]. PMID: 20884063. Exclusion Code: X7.20884063
29 Bauer M, Forsthoff A, Baethge C, . Lithium augmentation therapy in refractory depression-update 2002. Eur Arch Psychiatry Clin Neurosci. 2003 Jun;253(3):132-9. doi: 10.1007/s00406-003-0430-9 [doi]. PMID: 12904977. Exclusion Code: X11.12904977
30 Bauer M, Pretorius HW, Constant EL, . Extended-release quetiapine as adjunct to an antidepressant in patients with major depressive disorder: results of a randomized, placebo-controlled, double-blind study. J Clin Psychiatry. 2009 Apr;70(4):540-9. PMID: 19358791. Exclusion Code: X6.19358791
31 Bauer M, Tharmanathan P, Volz HP, . The effect of venlafaxine compared with other antidepressants and placebo in the treatment of major depression: a metaanalysis. Eur Arch Psychiatry Clin Neurosci. 2009 Apr;259(3):172-85. doi: 10.1007/s00406-008-0849-0 [doi]. PMID: 19165525. Exclusion Code: X2.19165525
32 Bauer M, Thase ME, Liu S, . Analysis of potentially predictive factors of efficacy of adjunct extended-release quetiapine fumarate in patients with major depressive disorder. J Psychopharmacol. 2015 May;29(5):565-74. ; 10.1177/0269881114552715 [doi]. PMID: 25257148. Exclusion Code: X7.25257148
33 Baumann P, Nil R, Souche A, . A double-blind, placebo-controlled study of citalopram with and without lithium in the treatment of therapy-resistant depressive patients: a clinical, pharmacokinetic, and pharmacogenetic investigation. J Clin Psychopharmacol. 1996 Aug;16(4):307-14. PMID: 8835706. Exclusion Code: X13.8835706
34 Bech P, Lunde M, Lauritzen L, . The Diagnostic Apathia Scale predicts a dose-remission relationship of T-PEMF in treatment-resistant depression. Acta neuropsychiatrica. 2015(1):1-7. doi: 10.1017/neu.2014.26. PMID: CN-01113381. Exclusion Code: X8.
35 Bedson E, Bell D, Carr D, . Folate Augmentation of Treatment--Evaluation for Depression (FolATED): randomised trial and economic evaluation. Health Technol Assess. 2014 Jul;18(48):vii-viii, 1-159. doi: 10.3310/hta18480 [doi]. PMID: 25052890. Exclusion Code: X2.25052890
36 Belmaker B, Fitzgerald P, George MS, . Managing the risks of repetitive transcranial stimulation. CNS Spectrums. 2003 July;8(7):489. Exclusion Code: X2.12894029
37 Benadhira R, Saba G, Samaan A, . Transcranial magnetic stimulation for refractory depression. Am J Psychiatry. 2005 Jan;162(1):193. ; 10.1176/appi.ajp.162.1.193 [doi]. PMID: 15625226. Exclusion Code: X4.15625226
38 Bergfeld IO, Denys D. Deep brain stimulation as a treatment for treatment-resistant depression. Tijdschrift voor psychiatrie. 2016(12):897. PMID: CN-01331852. Exclusion Code: X1.
39 A randomized, crossover trial of deep brain stimulation of the ventral anterior limb of the internal capsule in depression. European neuropsychopharmacology. Conference: 29th european college of neuropsychopharmacology congress, ECNP 2016. Austria. Conference start: 20160917. Conference end: 20160920; 2016. Exclusion Code: X9.
40 Berlim MT, Broadbent HJ, Van den Eynde F. Blinding integrity in randomized sham-controlled trials of repetitive transcranial magnetic stimulation for major depression: a systematic review and meta-analysis. Int J Neuropsychopharmacol. 2013 Feb 11:1-9. ; 10.1017/S1461145712001691. PMID: 23399312. Exclusion Code: X2.23399312
41 Berlim MT, Fleck MP, Turecki G. Current trends in the assessment and somatic treatment of resistant/refractory major depression: an overview. Ann Med. 2008;40(2):149-59. PMID: 18293145. Exclusion Code: X1.18293145
42 Berlim MT, McGirr A, Eynde F, . Effectiveness and acceptability of deep brain stimulation (DBS) of the subgenual cingulate cortex for treatment-resistant depression: a systematic review and exploratory meta-analysis J Affect Disord. 2014 20 April;159(2):31-8. PMID: DARE-12014020668. Exclusion Code: X7.24679386
43 Berlim MT, Van den Eynde F, Daskalakis ZJ. A systematic review and meta-analysis on the efficacy and acceptability of bilateral repetitive transcranial magnetic stimulation (rTMS) for treating major depression. Psychol Med. 2012 Dec 3:1-10. ; 10.1017/S0033291712002802. PMID: 23200131. Exclusion Code: X2.23200131
44 Berlim MT, Van den Eynde F, Daskalakis ZJ. A systematic review and meta-analysis on the efficacy and acceptability of bilateral repetitive transcranial magnetic stimulation (rTMS) for treating major depression. Psychol Med. 2013 Nov;43(11):2245-54. doi: 10.1017/S0033291712002802. PMID: 23200131. Exclusion Code: X2.23200131
45 Berlim MT, Van den Eynde F, Jeff Daskalakis Z. Clinically Meaningful Efficacy and Acceptability of Low-Frequency Repetitive Transcranial Magnetic Stimulation (rTMS) for Treating Primary Major Depression: A Meta-Analysis of Randomized, Double-Blind and Sham-Controlled Trials. Neuropsychopharmacology. 2013 Mar;38(4):543-51. doi: 10.1038/npp.2012.237; . PMID: 23249815. Exclusion Code: X2.23249815
46 Berlim MT, van den Eynde F, Tovar-Perdomo S, . Response, remission and drop-out rates following high-frequency repetitive transcranial magnetic stimulation (rTMS) for treating major depression: a systematic review and meta-analysis of randomized, double-blind and sham-controlled trials. Psychol Med. 2013 Mar 18:1-15. ; 10.1017/S0033291713000512. PMID: 23507264. Exclusion Code: X2.23507264
47 Berman RM, Narasimhan M, Sanacora G, . A randomized clinical trial of repetitive transcranial magnetic stimulation in the treatment of major depression. Biol Psychiatry. 2000 Feb 2000;47(4):332-7. PMID: 2000-07308-008. Exclusion Code: X13.10686268
48 Berry SM, Broglio K, Bunker M, . A patient-level meta-analysis of studies evaluating vagus nerve stimulation therapy for treatment-resistant depression. Medical Devices: Evidence and Research. 2013;6(1):17-35. Exclusion Code: X7.
49 Bhagwagar Z, Torbeyns A, Hennicken D, . Assessment of the Efficacy and Safety of BMS-820836 in Patients With Treatment-Resistant Major Depression: Results From 2 Randomized, Double-Blind Studies. J Clin Psychopharmacol. 2015 Aug;35(4):454-9. doi: 10.1097/JCP.0000000000000335 [doi]. PMID: 25961781. Exclusion Code: X3.25961781
50 Bird D, Haddad PM, Dursun SM. An Overview of The Definition and Management of Treatment-Resistant Depression. Klinik Psikofarmakoloji Bülteni. 2002;12(2):92-101. Exclusion Code: X1.
51 Birkenhager TK, van den Broek WW, Mulder PG, . Efficacy and tolerability of tranylcypromine versus phenelzine: a double-blind study in antidepressant-refractory depressed inpatients. J Clin Psychiatry. 2004 Nov;65(11):1505-10. PMID: 15554763. Exclusion Code: X13.15554763
52 Birkenhager TK, van den Broek WW, Wijkstra J, . Treatment of unipolar psychotic depression: an open study of lithium addition in refractory psychotic depression. J Clin Psychopharmacol. 2009 Oct;29(5):513-5. doi: 10.1097/JCP.0b013e3181b6744e . PMID: 19745662. Exclusion Code: X4.19745662
53 Blier P, Ward HE, Tremblay P, . Combination of antidepressant medications from treatment initiation for major depressive disorder: a double-blind randomized study. Am J Psychiatry. 2010 Mar;167(3):281-8. doi: 10.1176/appi.ajp.2009.09020186. PMID: 20008946. Exclusion Code: X2.20008946
54 Blumberger DM, Maller JJ, Thomson L, . A randomized controlled comparison of neuro-navigated unilateral vs sequential bilateral rTMS for treatment resistant depression. Brain Stimulation. 2015(2):365. PMID: CN-01100736. Exclusion Code: X9.
55 Blumberger DM, Mulsant BH, Emeremni C, . Impact of prior pharmacotherapy on remission of psychotic depression in a randomized controlled trial. J Psychiatr Res. 2011 Jul;45(7):896-901. ; 10.1016/j.jpsychires.2011.01.003 [doi]. PMID: 21300377. Exclusion Code: X2.21300377
56 Blumberger DM, Vila-Rodriguez F, Dunlop K, . Intermittent theta-burst versus 10 Hz left dorsolateral prefrontal rTMS for treatment resistant depression: Preliminary results from a two-site, randomized, single blind noninferiority trial. Brain Stimulation. 2015(2):329. PMID: CN-01100751. Exclusion Code: X9.
57 Bocchio-Chiavetto L, Miniussi C, Zanardini R, . 5-HTTLPR and BDNF Val66Met polymorphisms and response to rTMS treatment in drug resistant depression. Neurosci Lett. 2008 May 30;437(2):130-4. PMID: 18450378. Exclusion Code: X4.18450378
58 Bond DJ, Hadjipavlou G, Lam RW, . The Canadian Network for Mood and Anxiety Treatments (CANMAT) task force recommendations for the management of patients with mood disorders and comorbid attention-deficit/hyperactivity disorder. Ann Clin Psychiatry. 2012 Feb;24(1):23-37. . PMID: 22303520. Exclusion Code: X2.22303520
59 Bondolfi G, Aubry JM, Golaz J, . A stepwise drug treatment algorithm to obtain complete remission in depression: a Geneva study. Swiss Med Wkly. 2006 Feb 04;136(5-6):78-85. doi: 10.2006/05/smw-11267. PMID: 16633950. Exclusion Code: X4.16633950
60 Borckardt JJ, Nahas ZH, Teal J, . The painfulness of active, but not sham, transcranial magnetic stimulation decreases rapidly over time: results from the double-blind phase of the OPT-TMS Trial. Brain Stimul. 2013 Nov;6(6):925-8. doi: 10.1016/j.brs.2013.04.009. PMID: 23769413. Exclusion Code: X2.23769413
61 Bortnick B, El-Khalili N, Banov M, . Efficacy and tolerability of extended release quetiapine fumarate (quetiapine XR) monotherapy in major depressive disorder: a placebo-controlled, randomized study. J Affect Disord. 2011 Jan;128(1-2):83-94. doi: 10.1016/j.jad.2010.06.031. PMID: 20691481. Exclusion Code: X2.20691481
62 Boutros NN, Gueorguieva R, Hoffman RE, . Lack of a therapeutic effect of a 2-week sub-threshold transcranial magnetic stimulation course for treatment-resistant depression. Psychiatry Res. 2002 Dec 2002;113(3):245-54. PMID: 2003-01501-006. Exclusion Code: X13.12559481
63 Bowie CR, Gupta M, Holshausen K, . Cognitive remediation for treatment-resistant depression: effects on cognition and functioning and the role of online homework. J Nerv Ment Dis. 2013 Aug;201(8):680-5. doi: 10.1097/NMD.0b013e31829c5030 . PMID: 23896849. Exclusion Code: X3.23896849
64 Bozkurt A. Transcranial magnetic stimulation in treatment resistant depression: The Turkish experience. World Psychiatric Association, International Congress 2006; July 12 - 16 2006; Istanbul, Turkey. 2006:137-8. PMID: CN-00595853. Exclusion Code: X10.
65 Brakemeier EL, Merkl A, Wilbertz G, . Cognitive-behavioral therapy as continuation treatment to sustain response after electroconvulsive therapy in depression: a randomized controlled trial. Biol Psychiatry. 2014 Aug 01;76(3):194-202. doi: 10.1016/j.biopsych.2013.11.030. PMID: 24462229. Exclusion Code: X2.24462229
66 Brakemeier EL, Radtke M, Engel V, . Overcoming treatment resistance in chronic depression: a pilot study on outcome and feasibility of the cognitive behavioral analysis system of psychotherapy as an inpatient treatment program. Psychother Psychosom. 2015;84(1):51-6. doi: 10.1159/000369586. PMID: 25547778. Exclusion Code: X4.25547778
67 Bretlau LG, Lunde M, Lindberg L, . Repetitive transcranial magnetic stimulation (rTMS) in combination with escitalopram in patients with treatment-resistant major depression: a double-blind, randomised, sham-controlled trial. Pharmacopsychiatry. 2008 Mar;41(2):41-7. doi: 10.1055/s-2007-993210 [doi]. PMID: 18311683. Exclusion Code: X12.18311683
68 Bruce ML, Ten Have TR, Reynolds CF, 3rd, . Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. 2004 Mar 03;291(9):1081-91. doi: 10.1001/jama.291.9.1081. PMID: 14996777. Exclusion Code: X2.14996777
69 Brunner E, Tohen M, Osuntokun O, . Efficacy and safety of olanzapine/fluoxetine combination vs fluoxetine monotherapy following successful combination therapy of treatment-resistant major depressive disorder. Neuropsychopharmacology. 2014 Oct;39(11):2549-59. ; 10.1038/npp.2014.101 [doi]. PMID: 24801768. Exclusion Code: X6.24801768
70 Bschor T, Berghofer A, Strohle A, . How long should the lithium augmentation strategy be maintained? A 1-year follow-up of a placebo-controlled study in unipolar refractory major depression. J Clin Psychopharmacol. 2002 Aug;22(4):427-30. PMID: 12172345. Exclusion Code: X13.12172345
71 Calabrese JR, Frye MA, Yang R, . Efficacy and safety of adjunctive armodafinil in adults with major depressive episodes associated with bipolar I disorder: a randomized, double-blind, placebo-controlled, multicenter trial. J Clin Psychiatry. 2014 Oct;75(10):1054-61. doi: 10.4088/JCP.13m08951 [doi]. PMID: 25099397. Exclusion Code: X2.25099397
72 Calabrese JR, Ketter TA, Youakim JM, . Adjunctive armodafinil for major depressive episodes associated with bipolar I disorder: a randomized, multicenter, double-blind, placebo-controlled, proof-of-concept study. J Clin Psychiatry. 2010 Oct;71(10):1363-70. doi: 10.4088/JCP.09m05900gry [doi]. PMID: 20673554. Exclusion Code: X6.20673554
73 Candy M, Jones L, Williams R, . Psychostimulants for depression. Cochrane Database Syst Rev. 2008 Apr 16(2)doi: 10.1002/14651858.CD006722.pub2. PMID: 18425966. Exclusion Code: X2.18425966
74 Cappiello A, McDougle CJ, Malison RT, . Yohimbine augmentation of fluvoxamine in refractory depression: a single-blind study. Biol Psychiatry. 1995 Dec 1;38(11):765-7. ; 10.1016/0006-3223(95)00367-3 [doi]. PMID: 8580232. Exclusion Code: X3.8580232
75 Carpenter LL, Yasmin S, Price LH. A double-blind, placebo-controlled study of antidepressant augmentation with mirtazapine. Biol Psychiatry. 2002 Jan 15;51(2):183-8. PMID: 11822997. Exclusion Code: X13.11822997
76 Carvalho AF, Berk M, Hyphantis TN, . The integrative management of treatment-resistant depression: A comprehensive review and perspectives. Psychother Psychosom. 2015;83(2):70-88. Exclusion Code: X1.
77 Casey DE, Laubmeier KK, Eudicone JM, . Response and remission rates with adjunctive aripiprazole in patients with major depressive disorder who exhibit minimal or no improvement on antidepressant monotherapy. Int J Clin Pract. 2014 Nov;68(11):1301-8. doi: 10.1111/ijcp.12480 [doi]. PMID: 25196314. Exclusion Code: X7.25196314
78 Chen J, Gao K, Kemp DE. Second-generation antipsychotics in major depressive disorder: update and clinical perspective. Curr Opin Psychiatry. 2011 Jan;24(1):10-7. doi: 10.1097/YCO.0b013e3283413505 [doi]. PMID: 21088586. Exclusion Code: X2.21088586
79 Chen S-J, Chang C-H, Tsai H-C, . Superior antidepressant effect occurring 1 month after rTMS: Add-on rTMS for subjects with medication-resistant depression. Neuropsychiatr Dis Treat. 2013;9:397-401. PMID: 2013-13058-001. Exclusion Code: X6.23576870
80 Chen YC, Shen YC, Hung YJ, . Comparisons of glucose-insulin homeostasis following maprotiline and fluoxetine treatment in depressed males. J Affect Disord. 2007 Nov;103(1-3):257-61. ; 10.1016/j.jad.2007.01.023 [doi]. PMID: 17320192. Exclusion Code: X2.17320192
81 Cheng C-M, Juan C-H, Chen M-H, . Different forms of prefrontal theta burst stimulation for executive function of medication-resistant depression: Evidence from a randomized sham-controlled study. Prog Neuropsychopharmacol Biol Psychiatry. 2016;66:35-40. doi: 10.1016/j.pnpbp.2015.11.009. PMID: 2016-05312-005. Exclusion Code: X6.26593273
82 Cheon EJ, Lee KH, Park YW, . Comparison of the Efficacy and Safety of Aripiprazole Versus Bupropion Augmentation in Patients With Major Depressive Disorder Unresponsive to Selective Serotonin Reuptake Inhibitors: A Randomized, Prospective, Open-Label Study. J Clin Psychopharmacol. 2017 Apr;37(2):193-9. doi: 10.1097/JCP.0000000000000663 [doi]. PMID: 28129308. Exclusion Code: X2.28129308
83 Chistyakov AV, Kreinin B, Marmor S, . Preliminary assessment of the therapeutic efficacy of continuous theta-burst magnetic stimulation (cTBS) in major depression: a double-blind sham-controlled study. J Affect Disord. 2015 Jan 1;170:225-9. ; 10.1016/j.jad.2014.08.035 [doi]. PMID: 25261629. Exclusion Code: X2.25261629
84 Choi J, Wang Y, Feng T, . Cognitive training to improve memory in individuals undergoing electroconvulsive therapyNegative findings. J Psychiatr Res. 2017 Sept 2017;92:8-14. doi: 10.1016/j.jpsychires.2017.03.016. PMID: CN-01364922. Exclusion Code: X4.28376409
85 Cipriani A, Barbui C, Butler R, . Depression in adults: drug and physical treatments. BMJ Clin Evid. 2011;2011. PMID: 21609510. Exclusion Code: X7.21609510
86 Conway CR, Gebara MA, Walker MC, . Clinical characteristics and management of treatment-resistant depression. J Clin Psychiatry. 2015 Nov;76(11):1569-70. doi: 10.4088/JCP.14l09462. PMID: 26646033. Exclusion Code: X3.26646033
87 Corcoran CD, Thomas P, Phillips J, . Vagus nerve stimulation in chronic treatment-resistant depression: Preliminary findings of an open-label study. Br J Psychiatry. 2006 Sep;189(3):282-3. PMID: CN-00711623. Exclusion Code: X4.16946367
88 Treatment-resistant depression in primary care. 155th Annual Meeting of the American Psychiatric Association; 2002 May 18-23; Philadelphia, PA; 2002. Exclusion Code: X10.
89 Daban C, Martinez-Aran A, Cruz N, . Safety and efficacy of vagus nerve stimulation in treatment-resistant depression. A systematic review. J Affect Disord. 2008;110(1-2):1-15. doi: 10.1016/j.jad.2008.02.012. PMID: 2008-10669-001. Exclusion Code: X7.18374988
90 De Carlo V, Calati R, Souery D, . Socio-demographic and clinical predictors of non response/non remission in treatment resistant depressed patients: A systematic review. Eur Neuropsychopharmacol. 2014;24((De Carlo V.; Serretti A.) University of Bologna, Department of Biomedical and NeuroMotor Sciences, Bologna, Italy):S457-S8. Exclusion Code: X9.
91 DeBattista C, Kinrys G, Hoffman D, . The use of referenced-EEG (rEEG) in assisting medication selection for the treatment of depression. J Psychiatr Res. 2011 Jan;45(1):64-75. ; 10.1016/j.jpsychires.2010.05.009 [doi]. PMID: 20598710. Exclusion Code: X3.20598710
92 Dell’Osso B, Camuri G, Castellano F, . Meta-review of metanalytic studies with repetitive transcranial magnetic stimulation (rTMS) for the treatment of Major Depression. Clin Pract Epidemiol Ment Health. 2011;7((Dell’Osso B., bernardo.dellosso@policlinico.mi.it; Camuri G.; Castellano F.; Vecchi V.; Benedetti M.; Bortolussi S.; Altamura A.C.) Department of Psychiatry, University of Milan, Fondazione IRCCS Ca’ Granda, 20122 Milano, Italy):167-77. Exclusion Code: X2.
93 Dell’Osso B, Cremaschi L, Spagnolin G, . Augmentative dopaminergic interventions for treatment-resistant bipolar depression: A focus on dopamine agonists and stimulants. Journal of Psychopathology. 2013;19(4):327-40. Exclusion Code: X7.
94 Department of Veteran Affairs (DoD). VA/DoD clinical practice guideline for management of major depressive disorder (MDD). Washington, DC: Department of Veterans Affairs and Department of Defense; 2016. Accessed 27 May, 2016. Exclusion Code: X12.
95 Dew MA, Whyte EM, Lenze EJ, . Recovery from major depression in older adults receiving augmentation of antidepressant pharmacotherapy. Am J Psychiatry. 2007 Jun;164(6):892-9. ; 10.1176/ajp.2007.164.6.892 [doi]. PMID: 17541048. Exclusion Code: X2.17541048
96 DeWilde KE, Levitch CF, Murrough JW, . The promise of ketamine for treatment-resistant depression: current evidence and future directions. Ann N Y Acad Sci. 2015 May;1345:47-58. doi: 10.1111/nyas.12646. PMID: 25649308. Exclusion Code: X1.25649308
97 Dording CM, Mischoulon D, Shyu I, . SAMe and sexual functioning. Eur Psychiatry. 2012 Aug;27(6):451-4. ; 10.1016/j.eurpsy.2011.01.003 [doi]. PMID: 21398094. Exclusion Code: X5.21398094
98 Downar J, Geraci J, Salomons TV, . Anhedonia and reward-circuit connectivity distinguish nonresponders from responders to dorsomedial prefrontal repetitive transcranial magnetic stimulation in major depression. Biol Psychiatry. 2014 Aug 01;76(3):176-85. doi: 10.1016/j.biopsych.2013.10.026. PMID: 24388670. Exclusion Code: X4.24388670
99 Olanzapine-fluoxetine for treatment-resistant depression. XII World Congress of Psychiatry, Aug 24-9, 2002, Yokohama, Japan.; 2002. Exclusion Code: X10.
100 Meta-analysis of olanzapine-fluoxetine in treatment-resistant depression. 155th Annual Meeting of the American Psychiatric Association; 2002 May 18-23rd; Philadelphia, PA, USA; 2002. Exclusion Code: X10.
101 Dubin MJ, Cochran AA, Gross CG, . Mood-enhancing effects of low field magnetic stimulation in depression and related plasticity of resting state connectivity. Brain Stimulation. 2017;10(2):425. doi: 10.1016/j.brs.2017.01.263. Exclusion Code: X9.
102 Dunlop K, Peters SK, Giacobbe P, . Cortico-cortical and cortico-striatal resting-state functional connectivity differentially predicts response to 10 hz rTMS and intermittent TBS to the DLPFC. Brain Stimulation. 2017;10(2):464. doi: 10.1016/j.brs.2017.01.360. Exclusion Code: X9.
103 A randomized comparison of 1 hz vs. 20 hz vs. sham dorsomedial prefrontal rTMS for treatment-resistant depression: preliminary clinical results. Brain stimulation. Conference: 2nd international brain stimulation conference. Spain; 2017. Exclusion Code: X5.
104 Adjunctive ziprasidone in treatment-resistant depression: A pilot study. 156th Annual Meeting of the American Psychiatric Association, May 17-22, San Francisco CA; 2003. Exclusion Code: X10.
105 Dunner DL, Amsterdam JD, Shelton RC, . Adjunctive ziprasidone in treatment-resistant depression: Randomized, double-blind, 8-week pilot study. Neuropsychopharmacology. 2004:S99. PMID: CN-00595468. Exclusion Code: X9.
106 Acute deep brain stimulation in the subgenual cingulate alters REM sleep in patients with treatment resistant depression [conference abstract]. European Neuropsychopharmacology [papers of the 23rd European College of Neuropsychopharmacology (ECNP) Congress, Amsterdam, the Netherlands, 28 August-01 September 2010]; 2010. Exclusion Code: X10.
107 D’Urso G, Mantovani A, Micillo M, . Transcranial direct current stimulation and cognitive-behavioral therapy: evidence of a synergistic effect in treatment-resistant depression. Brain Stimul. 2013 May;6(3):465-7. ; 10.1016/j.brs.2012.09.003 [doi]. PMID: 23031723. Exclusion Code: X7.23031723
108 Edwards DR. A double-blind, placebo-controlled trial of lithium augmentation of antidepressants in treatment-resistant depression in elderly patients. National Research Register. 1998PMID: CN-00595669. Exclusion Code: X10.
109 Edwards SJ, Wakefield V, Nherera L, . Systematic review and mixed treatment comparison of lithium or an atypical antipsychotic (AAP) used to augment a selective serotonin reuptake inhibitor (SSRI) in treatment resistant depression (TRD). Value Health. 2014;17(7):A455. doi: 10.1016/j.jval.2014.08.1242. PMID: CN-01023401. Exclusion Code: X9.
110 Eli Lilly and Company. The study of olanzapine plus fluoxetine in combination for treatment-resistant depression without psychotic features [NCT00035321]. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of medicine. [cited 2006 July]. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/526/CN00596526/frame.html. NLM Identifier: NCT00035321. Exclusion Code: X10.
111 Eli Lilly and Company. A Study in Relapse Prevention of Treatment-Resistant Depression. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2012]. https://clinicaltrials.gov/ct2/show/NCT00958568?term=NCT00958568&rank=1. NLM Identifier: NCT00958568. Exclusion Code: X6.
112 Fagiolini A, Kupfer DJ. Is treatment-resistant depression a unique subtype of depression? Biol Psychiatry. 2003 Apr 15;53(8):640-8. PMID: 12706950. Exclusion Code: X1.12706950
113 Fang J, Rong P, Hong Y, . Transcutaneous Vagus Nerve Stimulation Modulates Default Mode Network in Major Depressive Disorder. Biol Psychiatry. 2016 Feb 15;79(4):266-73. ; 10.1016/j.biopsych.2015.03.025 [doi]. PMID: 25963932. Exclusion Code: X2.25963932
114 Farooq S, Singh SP. Fixed dose-combination products in psychiatry: Systematic review and meta-analysis. Journal of Psychopharmacology. 2015;29(5):556-64. Exclusion Code: X7.25151108
115 Fava M, Alpert J, Nierenberg A, . Double-blind study of high-dose fluoxetine versus lithium or desipramine augmentation of fluoxetine in partial responders and nonresponders to fluoxetine. J Clin Psychopharmacol. 2002 Aug;22(4):379-87. PMID: 12172337. Exclusion Code: X13.12172337
116 Fava M, Rush AJ. Current status of augmentation and combination treatments for major depressive disorder: a literature review and a proposal for a novel approach to improve practice. Psychother Psychosom. 2006;75(3):139-53. doi: 10.1159/000091771. PMID: 16636629. Exclusion Code: X1.16636629
117 Fava M, Thase ME, DeBattista C. A multicenter, placebo-controlled study of modafinil augmentation in partial responders to selective serotonin reuptake inhibitors with persistent fatigue and sleepiness. J Clin Psychiatry. 2005 Jan;66(1):85-93. PMID: 15669893. Exclusion Code: X2.15669893
118 Fava M, Thase ME, DeBattista C, . Modafinil augmentation of selective serotonin reuptake inhibitor therapy in MDD partial responders with persistent fatigue and sleepiness. Ann Clin Psychiatry. 2007 Jul-Sep;19(3):153-9. doi: 10.1080/10401230701464858. PMID: 17729016. Exclusion Code: X2.17729016
119 Fawcett J, Rush AJ, Vukelich J, . Clinical Experience With High-Dosage Pramipexole in Patients With Treatment-Resistant Depressive Episodes in Unipolar and Bipolar Depression. Am J Psychiatry. 2016 Feb 1;173(2):107-11. doi: 10.1176/appi.ajp.2015.15060788 [doi]. PMID: 26844792. Exclusion Code: X7.26844792
120 Fekadu A, Wooderson S, Donaldson C, . A multidimensional tool to quantify treatment resistance in depression: the Maudsley staging method. J Clin Psychiatry. 2009 Feb;70(2):177-84. PMID: 19192471. Exclusion Code: X12.19192471
121 Fekadu A, Wooderson SC, Markopoulo K, . What happens to patients with treatment-resistant depression? A systematic review of medium to long term outcome studies. J Affect Disord. 2009;116(1-2):4-11. doi: 10.1016/j.jad.2008.10.014. PMID: 2009-08238-002. Exclusion Code: X7.19007996
122 Feldman MD, Gillung EP, Delucchi K, . Mindfulness based cognitive therapy versus a health enhancement program for treatment resistant depression: A randomized controlled trial. J Gen Intern Med. 2014:S150-s1. PMID: CN-01010125. Exclusion Code: X9.
123 Ferreri M, Lavergne F, Berlin I, . Benefits from mianserin augmentation of fluoxetine in patients with major depression non-responders to fluoxetine alone. Acta Psychiatr Scand. 2001 Jan;103(1):66-72. PMID: 11202131. Exclusion Code: X13.11202131
124 Feske U, Mulsant BH, Pilkonis PA, . Clinical outcome of ECT in patients with major depression and comorbid borderline personality disorder. Am J Psychiatry. 2004 Nov;161(11):2073-80. ; 10.1176/appi.ajp.161.11.2073 [doi]. PMID: 15514409. Exclusion Code: X2.15514409
125 Fitzgerald PB, Benitez J, Castella AR, . A randomized controlled trial of sequential vilateral rTMS for treatment resistant depression. Aust N Z J Psychiatry. 2005:A45-a6. PMID: CN-00596192. Exclusion Code: X9.
126 Fleurence R, Williamson R, Jing Y, . A systematic review of augmentation strategies for patients with major depressive disorder. Psychopharmacol Bull. 2011;44(4):57-90. Exclusion Code: X7.
127 Folkerts HW, Michael N, Tolle R, . Electroconvulsive therapy vs. paroxetine in treatment-resistant depression -- a randomized study. Acta Psychiatr Scand. 1997 Nov;96(5):334-42. PMID: 9395150. Exclusion Code: X13.9395150
128 Fond G, Loundou A, Rabu C, . Ketamine administration in depressive disorders: A systematic review and meta-analysis. Psychopharmacology (Berl). 2014;231(18):3663-76. Exclusion Code: X7.25038867
129 Fox MD, Buckner RL, White MP, . Efficacy of transcranial magnetic stimulation targets for depression is related to intrinsic functional connectivity with the subgenual cingulate. Biol Psychiatry. 2012 Oct 01;72(7):595-603. doi: 10.1016/j.biopsych.2012.04.028. PMID: 22658708. Exclusion Code: X2.22658708
130 Fregni F, Marcolin MA, Myczkowski M, . Predictors of antidepressant response in clinical trials of transcranial magnetic stimulation. Int J Neuropsychopharmacol. 2006 Dec;9(6):641-54. ; 10.1017/S1461145705006280 [doi]. PMID: 16939662. Exclusion Code: X7.16939662
131 Garcia-Toro M, Mayol A, Arnillas H, . Modest adjunctive benefit with transcranial magnetic stimulation in medication-resistant depression. J Affect Disord. 2001 May 2001;64(2):271-5. PMID: 2001-17769-018. Exclusion Code: X13.11313095
132 Garcia-Toro M, Segura C, Gonzalez A, . Inefficacy of burst-suppression anesthesia in medication-resistant major depression: a controlled trial. J ECT. 2001 Dec;17(4):284-8. PMID: 11731731. Exclusion Code: X3.11731731
133 Gartlehner G, Gaynes BN, Hansen RA, . Comparative benefits and harms of second-generation antidepressants: background paper for the American College of Physicians. Ann Intern Med. 2008 Nov 18;149(10):734-50. . PMID: 19017592. Exclusion Code: X2.19017592
134 Gartlehner G, Hansen RA, Morgan LC, . Second Generation Antidepressants in the Pharmacologic Treatment of Adult Depression—An Update to a 2007 Report Comparative Effectiveness Review No. 46. (Prepared by the RTI International-University of North Carolina Evidence-based Practice Center, Contract No. 290-2007-10056-I#2.). AHRQ Publication No. 12-EHC012-EF. Rockville, MD: Agency for Healthcare Research and Quality; December 2011. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm Exclusion Code: X2.
135 Gaynes BN, Lloyd S, Lux L, . Is Repetitve transcranial magnetic stimulation effective in treatment resistant depression? a systematic review. Neuropsychopharmacology. 2012;38((Gaynes B.N.; Lloyd S.; Lux L.; Gartlehner G.) Univeristy of North, Carolina School of Medicine, Chapel Hill, United States):S306. Exclusion Code: X9.
136 George MS, Wassermann EM, Kimbrell TA, . Mood improvement following daily left prefrontal repetitive transcranial magnetic stimulation in patients with depression: a placebo-controlled crossover trial. Am J Psychiatry. 1997 Dec;154(12):1752-6. PMID: 9396958. Exclusion Code: X13.9396958
137 George TP, Sacco KA, Vessicchio JC, . Nicotinic antagonist augmentation of selective serotonin reuptake inhibitor-refractory major depressive disorder: a preliminary study. J Clin Psychopharmacol. 2008 Jun;28(3):340-4. doi: 10.1097/JCP.0b013e318172b49e . PMID: 18480694. Exclusion Code: X3.18480694
138 Ghaemi SN, Goodwin FK. Long-term naturalistic treatment of depressive symptoms in bipolar illness with divalproex vs. lithium in the setting of minimal antidepressant use. J Affect Disord. 2001 Aug;65(3):281-7. . PMID: 11511408. Exclusion Code: X2.11511408
139 Goldberg JF, Burdick KE, Endick CJ. Preliminary randomized, double-blind, placebo-controlled trial of pramipexole added to mood stabilizers for treatment-resistant bipolar depression. Am J Psychiatry. 2004 Mar;161(3):564-6. doi: 10.1176/appi.ajp.161.3.564 [doi]. PMID: 14992985. Exclusion Code: X13.14992985
140 . The efficacy of unilateral and bilateral repetitive transcranial magnetic stimulation for treatment-resistant late-life depression. American journal of geriatric psychiatry. Conference: 2016 annual meeting of the american association of geriatric psychiatry, AAGP 2016. United states; 2016. Exclusion Code: X9.
141 Gonul AS, Oguz A, Yabanoglu I, . Buspiron and pindolol in augmentation therapy of treatment-resistant depression. Eur Neuropsychopharmacol. 1999(Suppl 5):215. PMID: CN-00319499. Exclusion Code: X9.
142 Gorgulho A, Fernandes F, Lasagno C, . Double-blind randomized trial of V1 trigeminal stimulation for refractory major depression. Stereotact Funct Neurosurg. 2017;95((Gorgulho A.; De Salles A.) Neurosurgery, HCor Neuroscience, Sao Paulo, Brazil):34. doi: 10.1159/000478281. Exclusion Code: X3.
143 Greden JF. Longitudinal course: Key “alert signal” for treatment resistant depression. Biol Psychiatry. 2012;71(8):224S. Exclusion Code: X1.
144 Greenhalgh J, Knight C, Hind D, . Clinical and cost-effectiveness of electroconvulsive therapy for depressive illness, schizophrenia, catatonia and mania: systematic reviews and economic modelling studies. Health Technol Assess. 2005 Mar;9(9):1-156, iii-iv. . PMID: 15774232. Exclusion Code: X2.15774232
145 Grunhaus L, Schreiber S, Dolberg OT, . A randomized controlled comparison of electroconvulsive therapy and repetitive transcranial magnetic stimulation in severe and resistant nonpsychotic major depression. Biol Psychiatry. 2003 Feb 15;53(4):324-31. . PMID: 12586451. Exclusion Code: X13.12586451
146 Haile CN, Murrough JW, Iosifescu DV, . Plasma brain derived neurotrophic factor (BDNF) and response to ketamine in treatment-resistant depression. Int J Neuropsychopharmacol. 2014 Feb;17(2):331-6. ; 10.1017/S1461145713001119 [doi]. PMID: 24103211. Exclusion Code: X1.24103211
147 Han C, Wang SM, Kwak KP, . Aripiprazole augmentation versus antidepressant switching for patients with major depressive disorder: A 6-week, randomized, rater-blinded, prospective study. J Psychiatr Res. 2015 Jul-Aug;66-67:84-94. ; 10.1016/j.jpsychires.2015.04.020 [doi]. PMID: 26013203. Exclusion Code: X1.26013203
148 Haq AU, Sitzmann AF, Goldman ML, . Response of depression to electroconvulsive therapy: a meta-analysis of clinical predictors. J Clin Psychiatry. 2015 2015 Oct;76(10):1374-84. doi: 10.4088/JCP.14r09528 [doi]. PMID: 26528644. Exclusion Code: X7.26528644
149 Hausmann A, Kemmler G, Walpoth M, . No benefit derived from repetitive transcranial magnetic stimulation in depression: a prospective, single centre, randomised, double blind, sham controlled “add on” trial. J Neurol Neurosurg Psychiatry. 2004 Feb;75(2):320-2. PMID: 14742619. Exclusion Code: X13.14742619
150 Heijnen WT, Birkenhager TK, Wierdsma AI, . Antidepressant pharmacotherapy failure and response to subsequent electroconvulsive therapy: a meta-analysis. J Clin Psychopharmacol. 2010 Oct;30(5):616-9. doi: 10.1097/JCP.0b013e3181ee0f5f. PMID: 20814336. Exclusion Code: X1.20814336
151 Heijnen WT, van den Broek WW, Birkenhager TK. Treatment failure with a tricyclic antidepressant followed by lithium addition and response to subsequent electroconvulsive therapy. J Clin Psychiatry. 2008 Dec;69(12):1887-91. . PMID: 19014754. Exclusion Code: X4.19014754
152 Henderson JM. Vagal nerve stimulation versus deep brain stimulation for treatment-resistant depression: show me the data. Clin Neurosurg. 2007;54:88-90. PMID: CN-00712045. Exclusion Code: X1.18504902
153 Hetrick SE, Parker AG, Hickie IB, . Early identification and intervention in depressive disorders: towards a clinical staging model. Psychother Psychosom. 2008;77(5):263-70. doi: 10.1159/000140085. PMID: 18560251. Exclusion Code: X1.18560251
154 Hollon SD, DeRubeis RJ, Fawcett J, . Effect of cognitive therapy with antidepressant medications vs antidepressants alone on the rate of recovery in major depressive disorder: a randomized clinical trial. JAMA Psychiatry. 2014 Oct;71(10):1157-64. doi: 10.1001/jamapsychiatry.2014.1054. PMID: 25142196. Exclusion Code: X2.25142196
155 Holt C, Butler S, Agius M, . An audit to compare patient factors (age, sex, social background & associated physical diagnoses) in people with refractory depression in a Bedfordshire Community Mental Health Team (BCMHT) being augmented with (A) mirtazepine, (B) atypical antipsychotics or (C) both. Psychiatr Danub. 2011 Sep;23 Suppl 1:S166-70. PMID: 21894128. Exclusion Code: X15.21894128
156 Holtzheimer PE, 3rd, Russo J, Claypoole KH, . Shorter duration of depressive episode may predict response to repetitive transcranial magnetic stimulation. Depress Anxiety. 2004;19(1):24-30. PMID: 14978782. Exclusion Code: X13.14978782
157 Honkalampi K, Hintikka J, Koivumaa-Honkanen H, . Long-term alexithymic features indicate poor recovery from depression and psychopathology. A six-year follow-up. Psychother Psychosom. 2007;76(5):312-4. ; 10.1159/000104709 [doi]. PMID: 17700053. Exclusion Code: X2.17700053
158 Hoy KE, Segrave RA, Daskalakis ZJ, . Investigating the relationship between cognitive change and antidepressant response following rTMS: a large scale retrospective study. Brain Stimul. 2012 Oct;5(4):539-46. ; 10.1016/j.brs.2011.08.010 [doi]. PMID: 22305343. Exclusion Code: X4.22305343
159 Humaira A, Downar J, Blumberger D, . Repetitive transcranial magnetic stimulation (rTMS) side effect characterization for treatment resistant depression: Non-inferiority rTMS trial. Brain Stimulation. 2017;10(2):521. doi: 10.1016/j.brs.2017.01.522. Exclusion Code: X9.
160 Ibrahim L, Diazgranados N, Franco-Chaves J, . Course of improvement in depressive symptoms to a single intravenous infusion of ketamine vs add-on riluzole: results from a 4-week, double-blind, placebo-controlled study. Neuropsychopharmacology. 2012 May;37(6):1526-33. ; 10.1038/npp.2011.338 [doi]. PMID: 22298121. Exclusion Code: X3.22298121
161 Ionescu DF, Luckenbaugh DA, Niciu MJ, . Effect of baseline anxious depression on initial and sustained antidepressant response to ketamine. J Clin Psychiatry. 2014 Sep;75(9):e932-8. doi: 10.4088/JCP.14m09049 [doi]. PMID: 25295436. Exclusion Code: X3.25295436
162 Jarventausta K, Chrapek W, Kampman O. Erratum: Effect of S-ketamine as an anesthetic adjuvant to propofol on treatment response to electroconvulsive therapy in treatment-resistant depression: a randomized pilot study (Journal of ECT (2013) 29 (158-161.)). J ECT. 2014(2):176. doi: 10.1097/YCT.0000000000000153. PMID: CN-01001550. Exclusion Code: X1.
163 Jenkins E, Goldner EM. Approaches to understanding and addressing treatment-resistant depression: a scoping review. Depress Res Treat. 2012;2012:469680. doi: 10.1155/2012/469680. PMID: 22570778. Exclusion Code: X1.22570778
164 Judd LL, Akiskal HS, Maser JD, . Major depressive disorder: a prospective study of residual subthreshold depressive symptoms as predictor of rapid relapse. J Affect Disord. 1998 Sep;50(2-3):97-108. PMID: 9858069. Exclusion Code: X2.9858069
165 Juruena MF, Ottoni GL, Machado-Vieira R, . Bipolar I and II disorder residual symptoms: oxcarbazepine and carbamazepine as add-on treatment to lithium in a double-blind, randomized trial. Prog Neuropsychopharmacol Biol Psychiatry. 2009 Feb 1;33(1):94-9. ; 10.1016/j.pnpbp.2008.10.012 [doi]. PMID: 19007842. Exclusion Code: X2.19007842
166 Kagawa S, Mihara K, Nakamura A, . Relationship between plasma concentrations of lamotrigine and its early therapeutic effect of lamotrigine augmentation therapy in treatment-resistant depressive disorder. Ther Drug Monit. 2014 Dec;36(6):730-3. doi: 10.1097/FTD.0000000000000088 [doi]. PMID: 24819973. Exclusion Code: X3.24819973
167 Kalb R, Ellinger K, Reulbach U. Improvement in response times for simple and complex tasks after electroconvulsive therapy. Prog Neuropsychopharmacol Biol Psychiatry. 2003 May;27(3):459-65. ; 10.1016/S0278-5846(03)00033-2 [doi]. PMID: 12691781. Exclusion Code: X4.12691781
168 Katila H, Mezhebovsky I, Mulroy A, . Randomized, double-blind study of the efficacy and tolerability of extended release quetiapine fumarate (quetiapine XR) monotherapy in elderly patients with major depressive disorder. Am J Geriatr Psychiatry. 2013 Aug;21(8):769-84. doi: 10.1016/j.jagp.2013.01.010. PMID: 23567397. Exclusion Code: X2.23567397
169 Katona CL, Abou-Saleh MT, Harrison DA, . Placebo-controlled trial of lithium augmentation of fluoxetine and lofepramine. Br J Psychiatry. 1995 Jan;166(1):80-6. PMID: 7894881. Exclusion Code: X13.7894881
170 Kauffmann CD, Cheema MA, Miller BE. Slow right prefrontal transcranial magnetic stimulation as a treatment for medication-resistant depression: a double-blind, placebo-controlled study. Depress Anxiety. 2004;19(1):59-62. PMID: 2004-11482-009. Exclusion Code: X13.14978787
171 Kayser S, Bewernick BH, Matusch A, . Magnetic seizure therapy in treatment-resistant depression: clinical, neuropsychological and metabolic effects. Psychol Med. 2015 Apr;45(5):1073-92. ; 10.1017/S0033291714002244 [doi]. PMID: 25420474. Exclusion Code: X4.25420474
172 Kellner CH, Husain MM, Knapp RG, . Right Unilateral Ultrabrief Pulse ECT in Geriatric Depression: Phase 1 of the PRIDE Study. Am J Psychiatry. 2016 Nov 01;173(11):1101-9. doi: 10.1176/appi.ajp.2016.15081101. PMID: 27418379. Exclusion Code: X2.27418379
173 Kellner CH, Husain MM, Knapp RG, . A Novel Strategy for Continuation ECT in Geriatric Depression: Phase 2 of the PRIDE Study. Am J Psychiatry. 2016 Nov 01;173(11):1110-8. doi: 10.1176/appi.ajp.2016.16010118. PMID: 27418381. Exclusion Code: X1.27418381
174 Kellner CH, Knapp RG, Petrides G, . Continuation electroconvulsive therapy vs pharmacotherapy for relapse prevention in major depression: a multisite study from the Consortium for Research in Electroconvulsive Therapy (CORE). Arch Gen Psychiatry. 2006 Dec;63(12):1337-44. doi: 10.1001/archpsyc.63.12.1337. PMID: 17146008. Exclusion Code: X2.17146008
175 Kellner CH, Knapp RG, Petrides G, . Continuation electroconvulsive therapy vs pharmacotherapy for relapse prevention in major depression: a multisite study from the Consortium for Research in Electroconvulsive Therapy (CORE). Arch Gen Psychiatry. 2006 Dec;63(12):1337-44. doi: 10.1001/archpsyc.63.12.1337. PMID: 17146008. Exclusion Code: X12.17146008
176 Kellner CH, McClintock SM, McCall WV, . Brief pulse and ultrabrief pulse right unilateral electroconvulsive therapy (ECT) for major depression: efficacy, effectiveness, and cognitive effects. J Clin Psychiatry. 2014 Jul;75(7):777. doi: 10.4088/JCP.14lr08997. PMID: 25093475. Exclusion Code: X1.25093475
177 Kennedy SH, Milev R, Giacobbe P, . Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults. IV. Neurostimulation therapies. J Affect Disord. 2009 Oct;117 Suppl 1:S44-53. ; 10.1016/j.jad.2009.06.039 [doi]. PMID: 19656575. Exclusion Code: X2.19656575
178 Keshtkar M, Ghanizadeh A, Firoozabadi A. Repetitive transcranial magnetic stimulation versus electroconvulsive therapy for the treatment of major depressive disorder, a randomized controlled clinical trial. J ECT. 2011 Dec;27(4):310-4. doi: 10.1097/YCT.0b013e318221b31c [doi]. PMID: 22080240. Exclusion Code: X6.22080240
179 Kessler U, Schoeyen HK, Andreassen OA, . Effects on cognitive function in treatment resistant bipolar depression: ECT compared to algorithm based pharmacological treatment. Eur Psychiatry. 2013;28((Kessler U.; Hammar A°.; Oedegaard K.J.) Moodnet Research Group, Haukeland University Hospital, Psychiatric Division, Bergen, Norway). Exclusion Code: X9.
180 Ketter TA, Post RM, Parekh PI, . Addition of monoamine oxidase inhibitors to carbamazepine: preliminary evidence of safety and antidepressant efficacy in treatment-resistant depression. J Clin Psychiatry. 1995 Oct;56(10):471-5. PMID: 7559374. Exclusion Code: X4.7559374
181 Kiss ZHT, Golding S, Clark D, . Six-month outcomes of tractography targeted subgenual cingulate DBS for treatment resistant depression. Stereotact Funct Neurosurg. 2017;95((Kiss Z.H.T.; Golding S.) Clinical Neurosciences, University of Calgary, Calgary, Canada):13. doi: 10.1159/000478281. Exclusion Code: X9.
182 Kloiber S, Ripke S, Kohli MA, . Resistance to antidepressant treatment is associated with polymorphisms in the leptin gene, decreased leptin mRNA expression, and decreased leptin serum levels. Eur Neuropsychopharmacol. 2013 Jul;23(7):653-62. ; 10.1016/j.euroneuro.2012.08.010 [doi]. PMID: 23026132. Exclusion Code: X2.23026132
183 Knapp M, Romeo R, Mogg A, . Cost-effectiveness of transcranial magnetic stimulation vs. electroconvulsive therapy for severe depression: A multi-centre randomised controlled trial. J Affect Disord. 2008;109(3):273-85. doi: 10.1016/j.jad.2008.01.001. PMID: 2008-09263-006. Exclusion Code: X2.18262655
184 Kok RM. Treatment-resistant depression in the elderly [ISRCTN93105957]. In: ClinicalTrials.gov [Internet]. Netherlands: Netherlands Organisation for Health Research and Development [cited 2005]. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/143/CN00596143/frame.html. NLM Identifier: ISRCTN93105957 Exclusion Code: X10.
185 Kok RM, Nolen WA, Heeren TJ. Outcome of late-life depression after 3 years of sequential treatment. Acta Psychiatr Scand. 2009 Apr;119(4):274-81. ; 10.1111/j.1600-0447.2008.01295.x [doi]. PMID: 19053970. Exclusion Code: X4.19053970
186 Kolshus E, Douglas L, Dunne R. Antidepressant augmentation and combination in unipoiar depression: Strong guidance, wealt foundations. Ir J Psychol Med. 2011;28(4):i-viii. Exclusion Code: X8.
187 . Effects of aripiprazole versus bupropion adjunctive to selective serotonin reuptake inhibitor on the specific symptoms of depression: a randomised prospective open-label multi-center study. European neuropsychopharmacology. Conference: 29th european college of neuropsychopharmacology congress, ECNP 2016. Austria. Conference start: 20160917. Conference end: 20160920; 2016. Exclusion Code: X2.
188 Kornstein SG, Dunner DL, Meyers AL, . A randomized, double-blind study of increasing or maintaining duloxetine dose in patients without remission of major depressive disorder after initial duloxetine therapy. J Clin Psychiatry. 2008 Sep;69(9):1383-92. . PMID: 19193339. Exclusion Code: X4.19193339
189 Kornstein SG, Schneider RK. Clinical features of treatment-resistant depression. J Clin Psychiatry. 2001;62 Suppl 16:18-25. PMID: 11480880. Exclusion Code: X1.11480880
190 Kraus C, Rabl U, Vanicek T, . Administration of ketamine for unipolar and bipolar depression. Int J Psychiatry Clin Pract. 2017 Mar 2017;21(1):2-12. doi: 10.1080/13651501.2016.1254802. PMID: CN-01341411. Exclusion Code: X2.28097909
191 Krstic J, Buzadzic I, Milanovic SD, . Low-frequency repetitive transcranial magnetic stimulation in the right prefrontal cortex combined with partial sleep deprivation in treatment-resistant depression: a randomized sham-controlled trial. J ECT. 2014 Dec;30(4):325-31. doi: 10.1097/YCT.0000000000000099 [doi]. PMID: 24625704. Exclusion Code: X3.24625704
192 Krystal AD, Holsinger T, Weiner RD, . Prediction of the utility of a switch from unilateral to bilateral ECT in the elderly using treatment 2 ictal EEG indices. J ECT. 2000 Dec;16(4):327-37. PMID: 11314870. Exclusion Code: X8.11314870
193 Lai R, Katalinic N, Glue P, . Pilot dose-response trial of i.v. ketamine in treatment-resistant depression. World J Biol Psychiatry. 2014 Sep;15(7):579-84. doi: 10.3109/15622975.2014.922697 [doi]. PMID: 24910102. Exclusion Code: X2.24910102
194 Lally N, Nugent AC, Luckenbaugh DA, . Neural correlates of change in major depressive disorder anhedonia following open-label ketamine. J Psychopharmacol. 2015 May;29(5):596-607. ; 10.1177/0269881114568041 [doi]. PMID: 25691504. Exclusion Code: X3.25691504
195 Lam RW, Chan P, Wilkins-Ho M, . Repetitive transcranial magnetic stimulation for treatment-resistant depression: a systematic review and metaanalysis. Can J Psychiatry. 2008 2008 Sept;53(9):621-31. Exclusion Code: X7.18801225
196 Lam RW, Hossie H, Solomons K, . Citalopram and bupropion-SR: combining versus switching in patients with treatment-resistant depression. J Clin Psychiatry. 2004 Mar;65(3):337-40. PMID: 15096072. Exclusion Code: X13.15096072
197 Lam RW, Kennedy SH, Parikh SV, . Canadian Network for Mood and Anxiety Treatments (CANMAT) 2016 Clinical Guidelines for the Management of Adults with Major Depressive Disorder: Introduction and Methods. Can J Psychiatry. 2016 Sep;61(9):506-9. doi: 10.1177/0706743716659061. PMID: 27486152. Exclusion Code: X7.27486152
198 Lam RW, McIntosh D, Wang J, . Canadian Network for Mood and Anxiety Treatments (CANMAT) 2016 Clinical Guidelines for the Management of Adults with Major Depressive Disorder: Section 1. Disease Burden and Principles of Care. Can J Psychiatry. 2016 Sep;61(9):510-23. doi: 10.1177/0706743716659416. PMID: 27486151. Exclusion Code: X7.27486151
199 Landen M, Bjorling G, Agren H, . A randomized, double-blind, placebo-controlled trial of buspirone in combination with an SSRI in patients with treatment-refractory depression. J Clin Psychiatry. 1998 Dec;59(12):664-8. PMID: 9921700. Exclusion Code: X13.9921700
200 Landen M, Eriksson E, Agren H, . Effect of buspirone on sexual dysfunction in depressed patients treated with selective serotonin reuptake inhibitors. J Clin Psychopharmacol. 1999 Jun;19(3):268-71. PMID: 10350034. Exclusion Code: X5.10350034
201 Langer G, Karazman R, Neumark J, . Isoflurane narcotherapy in depressive patients refractory to conventional antidepressant drug treatment. A double-blind comparison with electroconvulsive treatment. Neuropsychobiology. 1995;31(4):182-94. PMID: 7659199. Exclusion Code: X3.7659199
202 Lapidus KA, Levitch CF, Soleimani L, . Intranasal ketamine in treatment-resistant depression. Neuropsychopharmacology. 2013:S361. doi: 10.1038/npp.2013.280. PMID: CN-01064246. Exclusion Code: X9.
203 Lapidus KAB, Levitch C, Perez AM, . A randomized controlled trial of intranasal ketamine in treatment resistant major depression. Biol Psychiatry. 2014;75(9):44S. Exclusion Code: X9.
204 Lauterbach E, Felber W, Muller-Oerlinghausen B, . Adjunctive lithium treatment in the prevention of suicidal behaviour in depressive disorders: a randomised, placebo-controlled, 1-year trial. Acta Psychiatr Scand. 2008 Dec;118(6):469-79. ; 10.1111/j.1600-0447.2008.01266.x [doi]. PMID: 18808400. Exclusion Code: X2.18808400
205 Lavretsky H, Alstein LL, Olmstead RE, . Complementary use of tai chi chih augments escitalopram treatment of geriatric depression: a randomized controlled trial. Am J Geriatr Psychiatry. 2011 Oct;19(10):839-50. doi: 10.1097/JGP.0b013e31820ee9ef [doi]. PMID: 21358389. Exclusion Code: X3.21358389
206 Lee JC, Blumberger DM, Fitzgerald PB, . The role of transcranial magnetic stimulation in treatment-resistant depression: a review. Curr Pharm Des. 2012;18(36):5846-52. Exclusion Code: X1.22681165
207 Leggett LE, Soril LJJ, Coward S, . Repetitive transcranial magnetic stimulation for treatment-resistant depression in adult and youth populations: A systematic literature review and meta-analysis. Prim Care Companion J Clin Psychiatry. 2015;17(6):379-88. Exclusion Code: X6.
208 Lenze EJ, Farber NB, Kharasch E, . Ninety-six hour ketamine infusion with co-administered clonidine for treatment-resistant depression: A pilot randomised controlled trial. World J Biol Psychiatry. 2016 Apr;17(3):230-8. doi: 10.3109/15622975.2016.1142607. PMID: 26919405. Exclusion Code: X12.26919405
209 Lepping P, Schönfeldt-Lecuona C, Sambhi RS, . A systematic review of the clinical relevance of repetitive transcranial magnetic stimulation. Acta Psychiatr Scand. 2014;130(5):326-41. Exclusion Code: X7.24724996
210 Leuzinger-Bohleber M. ’Consenting to be robbed so as not to be murdered’: psychoanalytic treatments of chronically depressed patients in two parallel depression research studies. Int J Psychoanal. 2012 Jun;93(3):507-8. doi: 10.1111/j.1745-8315.2012.00561.x [doi]. PMID: 22671269. Exclusion Code: X1.22671269
211 Levine J, Pomerantz T, Stier S, . Lack of effect of 6 g inositol treatment of post-ECT cognitive function in humans. J Psychiatr Res. 1995 Nov-Dec;29(6):487-9. . PMID: 8642546. Exclusion Code: X2.8642546
212 Li CT, Chen MH, Juan CH, . Efficacy of prefrontal theta-burst stimulation in refractory depression: a randomized sham-controlled study. Brain. 2014 Jul;137(Pt 7):2088-98. ; 10.1093/brain/awu109 [doi]. PMID: 24817188. Exclusion Code: X6.24817188
213 Li CT, Chen MH, Lin WC, . The effects of low-dose ketamine on the prefrontal cortex and amygdala in treatment-resistant depression: A randomized controlled study. Hum Brain Mapp. 2016 Mar;37(3):1080-90. doi: 10.1002/hbm.23085. PMID: CN-01138313. Exclusion Code: X6.26821769
214 Li X, Xing B, Yu E, . The combined treatment of venlafaxine and quetiapine for treatment-resistant depression: a clinical study. J Neuropsychiatry Clin Neurosci. 2013 Spring;25(2):157-60. ; 10.1176/appi.neuropsych.12070171 [doi]. PMID: 23686035. Exclusion Code: X6.23686035
215 Licht RW, Qvitzau S. Treatment strategies in patients with major depression not responding to first-line sertraline treatment. A randomised study of extended duration of treatment, dose increase or mianserin augmentation. Psychopharmacology (Berl). 2002 May;161(2):143-51. doi: 10.1007/s00213-002-0999-0. PMID: 11981594. Exclusion Code: X13.11981594
216 Lisanby SH. Electroconvulsive therapy for depression. N Engl J Med. 2007 Nov 08;357(19):1939-45. doi: 10.1056/NEJMct075234. PMID: 17989386. Exclusion Code: X1.17989386
217 Liston C, Chen AC, Zebley BD, . Default mode network mechanisms of transcranial magnetic stimulation in depression. Biol Psychiatry. 2014 Oct 01;76(7):517-26. doi: 10.1016/j.biopsych.2014.01.023. PMID: 24629537. Exclusion Code: X4.24629537
218 Little JT, Kimbrell TA, Wassermann EM, . Cognitive effects of 1- and 20-hertz repetitive transcranial magnetic stimulation in depression: preliminary report. Neuropsychiatry Neuropsychol Behav Neurol. 2000 Apr;13(2):119-24. PMID: 10780630. Exclusion Code: X2.10780630
219 Liu B, Zhang Y, Zhang L, . Repetitive transcranial magnetic stimulation as an augmentative strategy for treatment-resistant depression, a meta-analysis of randomized, double-blind and sham-controlled study. BMC Psychiatry. 2014;14doi: 10.1186/s12888-014-0342-4. PMID: 2014-55864-001. Exclusion Code: X7.24443820
220 Liu Y, Zhou X, Zhu D, . Is pindolol augmentation effective in depressed patients resistant to selective serotonin reuptake inhibitors? A systematic review and metaanalysis. Hum Psychopharmacol. 2015 May;30(3):132-42. doi: 10.1002/hup.2465 [doi]. PMID: 25689398. Exclusion Code: X6.25689398
221 Loo CK, Mitchell PB, Croker VM, . Double-blind controlled investigation of bilateral prefrontal transcranial magnetic stimulation for the treatment of resistant major depression. Psychol Med. 2003 Jan;33(1):33-40. PMID: 12537034. Exclusion Code: X13.12537034
222 Lopes Rocha F, Fuzikawa C, Riera R, . Antidepressant combination for major depression in incomplete responders--a systematic review. J Affect Disord. 2013;144(1-2):1-6. Exclusion Code: X2.22835845
223 Lynch TR, Cheavens JS, Cukrowicz KC, . Treatment of older adults with co-morbid personality disorder and depression: a dialectical behavior therapy approach. Int J Geriatr Psychiatry. 2007 Feb;22(2):131-43. doi: 10.1002/gps.1703. PMID: 17096462. Exclusion Code: X2.17096462
224 MacQueen G, Santaguida P, Keshavarz H, . Systematic Review of Clinical Practice Guidelines for Failed Antidepressant Treatment Response in Major Depressive Disorder, Dysthymia, and Subthreshold Depression in Adults. Can J Psychiatry. 2017 Jan;62(1):11-23. doi: 10.1177/0706743716664885. PMID: 27554483. Exclusion Code: X2.27554483
225 Maes M, Libbrecht I, van Hunsel F, . Pindolol and mianserin augment the antidepressant activity of fluoxetine in hospitalized major depressed patients, including those with treatment resistance. J Clin Psychopharmacol. 1999 Apr;19(2):177-82. PMID: 10211920. Exclusion Code: X13.10211920
226 Maes M, Vandoolaeghe E, Desnyder R. Efficacy of treatment with trazodone in combination with pindolol or fluoxetine in major depression. J Affect Disord. 1996 Dec 16;41(3):201-10. . PMID: 8988452. Exclusion Code: X13.8988452
227 Malhi GS, Adams D, Porter R, . Clinical practice recommendations for depression. Acta Psychiatr Scand Suppl. 2009(439):8-26. doi: 10.1111/j.1600-0447.2009.01382.x. PMID: 19356154. Exclusion Code: X14.19356154
228 Malhi GS, Byrow Y. Is treatment-resistant depression a useful concept? Evid Based Ment Health. 2016 Feb;19(1):1-3. doi: 10.1136/eb-2015-102299. PMID: 26767390. Exclusion Code: X1.26767390
229 Manes F, Jorge R, Morcuende M, . A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. Int Psychogeriatr. 2001 Jun 2001;13(2):225-31. PMID: 2001-01938-006. Exclusion Code: X13.11495396
230 Marangell LB, Rush AJ, George MS, . Vagus nerve stimulation (VNS) for major depressive episodes: one year outcomes. Biol Psychiatry. 2002 Feb 15;51(4):280-7. . PMID: 11958778. Exclusion Code: X4.11958778
231 Mark D. Vagus nerve stimulation for treatment-resistant depression (Provisional abstract). Database of Abstracts of Reviews of Effects. 2006(2):24. PMID: DARE-12007008431. Exclusion Code: X10.
232 IPT for treatment-resistant depression. 37th International Meeting of the Society for Psychotherapy Research; 2006 June 21 - 24; Edinburgh; 2006. Exclusion Code: X10.
233 Martinez-Amoros E, Cardoner N, Soria V, . Long-term treatment strategies in major depression: a 2-year prospective naturalistic follow-up after successful electroconvulsive therapy. J ECT. 2012 Jun;28(2):92-7. doi: 10.1097/YCT.0b013e31823e2705 [doi]. PMID: 22531201. Exclusion Code: X2.22531201
234 A randomized, double-blind, placebo-controlled, flexible-dose trial of augmentation with OROS methylphenidate in treatment-resistant depression. 46th Annual NCDEU (New Clinical Drug Evaluation Unit) Meeting; 2006 June 12 - 15; Boca Raton, FL; 2006. Exclusion Code: X10.
235 Masand PS, Patkar AA, Peindl K, . A randomized, double-blind, placebo-controlled, flexible-dose, trial of augmentation with OROS methylphenidate in treatment resistant depression. Neuropsychopharmacology. 2005:S180. PMID: CN-00595767. Exclusion Code: X3.
236 Mather AS, Rodriguez C, Guthrie MF, . Effects of exercise on depressive symptoms in older adults with poorly responsive depressive disorder: randomised controlled trial. Br J Psychiatry. 2002 May;180:411-5. PMID: 11983637. Exclusion Code: X13.11983637
237 Mathew SJ, Murrough JW, aan het Rot M, . Riluzole for relapse prevention following intravenous ketamine in treatment-resistant depression: a pilot randomized, placebo-controlled continuation trial. Int J Neuropsychopharmacol. 2010 Feb;13(1):71-82. ; 10.1017/S1461145709000169 [doi]. PMID: 19288975. Exclusion Code: X3.19288975
238 Quetiapine augmentation for treatment-resistant depression. 46th Annual NCDEU (New Clinical Drug Evaluation Unit) Meeting; 2006 June 12 - 15; Boca Raton, FL; 2006. Exclusion Code: X10.
239 McClintock S, Pierson M, Erkanli A, . Comparing the effects of an index course of magnetic seizure therapy and electroconvulsive therapy on quality of life. Neuropsychopharmacology. 2015;40((McClintock S.; Pierson M.; Erkanli A.; Deng Z.-D.; Luber B.; Husain M.; Lisanby S.) Duke University School of Medicine, Durham, United States):S148-S9. Exclusion Code: X9.
240 McClintock SM, Cullum M, Husain MM, . Evaluation of the Effects od Severe Depression on Global Cognitive Function and Memory. CNS Spectr. 2010 May;15(5):304-13. PMID: 20448521. Exclusion Code: X5.20448521
241 McCormick LM, Brumm MC, Benede AK, . Relative ineffectiveness of ultrabrief right unilateral versus bilateral electroconvulsive therapy in depression. J ECT. 2009 Dec;25(4):238-42. doi: 10.1097/YCT.0b013e31819fdff7 [doi]. PMID: 19384251. Exclusion Code: X2.19384251
242 McIntyre RS, Filteau M-J, Martin L, . Treatment-resistant depression: Definitions, review of the evidence, and algorithmic approach. J Affect Disord. 2014;156:1-7. doi: 10.1016/j.jad.2013.10.043. PMID: 2014-07963-002. Exclusion Code: X1.24314926
243 Systematic review and meta-analysis of randomised controlled trials of bitemporal versus high-dose right unilateral ECT for depression. Brain stimulation. Conference: 2nd international brain stimulation conference. Spain; 2017. Exclusion Code: X9.
244 McPherson S, Cairns P, Carlyle J, . The effectiveness of psychological treatments for treatment-resistant depression: a systematic review (Structured abstract). Acta Psychiatr Scand. 2005;111(5):331-40. PMID: DARE-12005000067. Exclusion Code: X16.15819726
245 Mehdi SM, Atlas SE, Qadir S, . Double-blind, randomized crossover study of intravenous infusion of magnesium sulfate versus 5% dextrose on depressive symptoms in adults with treatment-resistant depression. Psychiatry Clin Neurosci. 2017 Mar;71(3):204-11. doi: 10.1111/pcn.12480 [doi]. PMID: 27862658. Exclusion Code: X3.27862658
246 Meyers BS, Flint AJ, Rothschild AJ, . A double-blind randomized controlled trial of olanzapine plus sertraline vs olanzapine plus placebo for psychotic depression: the study of pharmacotherapy of psychotic depression (STOP-PD). Arch Gen Psychiatry. 2009 Aug;66(8):838-47. doi: 10.1001/archgenpsychiatry.2009.79. PMID: 19652123. Exclusion Code: X2.19652123
247 Milev R, Abraham G, Zaheer J. Add-on quetiapine for bipolar depression: a 12-month open-label trial. Can J Psychiatry. 2006 Jul;51(8):523-30. PMID: 16933589. Exclusion Code: X4.16933589
248 Miller IW, Keitner GI, Schatzberg AF, . The treatment of chronic depression, part 3: psychosocial functioning before and after treatment with sertraline or imipramine. J Clin Psychiatry. 1998 Nov;59(11):608-19. PMID: 9862607. Exclusion Code: X2.9862607
249 Mischoulon D, Alpert JE, Arning E, . Bioavailability of S-adenosyl methionine and impact on response in a randomized, double-blind, placebo-controlled trial in major depressive disorder. J Clin Psychiatry. 2012 Jun;73(6):843-8. doi: 10.4088/JCP.11m07139 [doi]. PMID: 22687580. Exclusion Code: X5.22687580
250 Mitchell J, Trangle M, Degnan B, . Major depression in adults in primary care. Institute for Clinical Systems Improvement. 2013. Exclusion Code: X14.
251 Favoured treatments for treatment resistant depression [abstract]. International Journal of Psychiatry in Clinical Practice [abstracts of the 13th International Forum on Mood and Anxiety Disorders, IFMAD; 2013 Nov 20-22; Monte Carlo Monaco]; 2013. Exclusion Code: X10.
252 Montgomery SA, Nielsen RZ, Poulsen LH, . A randomised, double-blind study in adults with major depressive disorder with an inadequate response to a single course of selective serotonin reuptake inhibitor or serotonin-noradrenaline reuptake inhibitor treatment switched to vortioxetine or agomelatine. Hum Psychopharmacol. 2014 Sep;29(5):470-82. doi: 10.1002/hup.2424 [doi]. PMID: 25087600. Exclusion Code: X3.25087600
253 Moreno FA, Gelenberg AJ, Bachar K, . Pindolol augmentation of treatment-resistant depressed patients. J Clin Psychiatry. 1997 Oct;58(10):437-9. PMID: 9375594. Exclusion Code: X13.9375594
254 Morishita T, Fayad SM, Higuchi MA, . Deep Brain Stimulation for Treatment-resistant Depression: Systematic Review of Clinical Outcomes. Neurotherapeutics. 2014;11(3):475-84. Exclusion Code: X1.24867326
255 Moser DJ, Jorge RE, Manes F, . Improved executive functioning following repetitive transcranial magnetic stimulation. Neurology. 2002 Apr 2002;58(8):1288-90. PMID: 2002-06607-012. Exclusion Code: X13.11971103
256 Moser DJ, Jorge RE, Manes F, . Improved executive functioning following repetitive transcranial magnetic stimulation. Neurology. 2002 Apr 23;58(8):1288-90. PMID: 11971103. Exclusion Code: X13.11971103
257 Mosimann UP, Schmitt W, Greenberg BD, . Repetitive transcranial magnetic stimulation: a putative add-on treatment for major depression in elderly patients. Psychiatry Res. 2004 Apr 30;126(2):123-33. doi: 10.1016/j.psychres.2003.10.006 . PMID: 15123391. Exclusion Code: X13.15123391
258 Mota Pereira J. Facebook enhances antidepressant pharmacotherapy effects. ScientificWorldJournal. 2014;2014:892048. doi: 10.1155/2014/892048 [doi]. PMID: 24574930. Exclusion Code: X3.24574930
259 Mowla A, Kardeh E. Topiramate augmentation in patients with resistant major depressive disorder: a double-blind placebo-controlled clinical trial. Prog Neuropsychopharmacol Biol Psychiatry. 2011 Jun 1;35(4):970-3. ; 10.1016/j.pnpbp.2011.01.016 [doi]. PMID: 21291943. Exclusion Code: X6.21291943
260 Mrazek DA, Hornberger JC, Altar CA, . A review of the clinical, economic, and societal burden of treatment-resistant depression: 1996-2013. Psychiatr Serv. 2014 Aug 1;65(8):977-87. Exclusion Code: X8.24789696
261 Mulsant BH, Alexopoulos GS, Reynolds CF, 3rd, . Pharmacological treatment of depression in older primary care patients: the PROSPECT algorithm. Int J Geriatr Psychiatry. 2001 Jun;16(6):585-92. PMID: 11424167. Exclusion Code: X1.11424167
262 Mulsant BH, Blumberger DM, Ismail Z, . A systematic approach to pharmacotherapy for geriatric major depression. Clin Geriatr Med. 2014 Aug;30(3):517-34. doi: 10.1016/j.cger.2014.05.002. PMID: 25037293. Exclusion Code: X1.25037293
263 Murray G, Michalak EE, Axler A, . Relief of chronic or resistant depression (Re-ChORD): a pragmatic, randomized, open-treatment trial of an integrative program intervention for chronic depression. J Affect Disord. 2010 Jun;123(1-3):243-8. ; 10.1016/j.jad.2009.10.015 [doi]. PMID: 19896200. Exclusion Code: X2.19896200
264 Murrough J, Burdick K, Perez A, . Neurocognitive effects of ketamine in individuals with treatment-resistant depression: A randomized controlled trial. Neuropsychopharmacology. 2014:S391. doi: 10.1038/npp.2014.281. PMID: CN-01040904. Exclusion Code: X9.
265 Nadeau SE, Bowers D, Jones TL, . Cognitive effects of treatment of depression with repetitive transcranial magnetic stimulation. Cogn Behav Neurol. 2014 Jun;27(2):77-87. doi: 10.1097/WNN.0000000000000031 . PMID: 24968008. Exclusion Code: X7.24968008
266 National Institute for Clinical Excellence. Depression: Management of depression in primary and secondary care Clinical Practice Guideline No. 23. London: National Institute for Clinical Excellence; 2004. http://www.nice.org.uk/nicemedia/pdf/CG23fullguideline.pdf] Exclusion Code: X14.
267 Neimat JS, Hamani C, Giacobbe P, . Neural stimulation successfully treats depression in patients with prior ablative cingulotomy. Am J Psychiatry. 2008 Jun;165(6):687-93. ; 10.1176/appi.ajp.2008.07081298 [doi]. PMID: 18519534. Exclusion Code: X1.18519534
268 Nelson JC, Baumann P, Delucchi K, . A systematic review and meta-analysis of lithium augmentation of tricyclic and second generation antidepressants in major depression. J Affect Disord. 2014 Oct;168:269-75. doi: 10.1016/j.jad.2014.05.053. PMID: 25069082. Exclusion Code: X1.25069082
269 Nelson JC, Mankoski R, Baker RA, . Effects of aripiprazole adjunctive to standard antidepressant treatment on the core symptoms of depression: a post-hoc, pooled analysis of two large, placebo-controlled studies. J Affect Disord. 2010 Jan;120(1-3):133-40. ; 10.1016/j.jad.2009.06.026 [doi]. PMID: 19656577. Exclusion Code: X7.19656577
270 Nelson JC, Mazure CM, Jatlow PI, . Combining norepinephrine and serotonin reuptake inhibition mechanisms for treatment of depression: a double-blind, randomized study. Biol Psychiatry. 2004 Feb 1;55(3):296-300. . PMID: 14744472. Exclusion Code: X2.14744472
271 Nelson JC, Thase ME, Bellocchio EE, . Efficacy of adjunctive aripiprazole in patients with major depressive disorder who showed minimal response to initial antidepressant therapy. Int Clin Psychopharmacol. 2012 May;27(3):125-33. doi: 10.1097/YIC.0b013e3283502791 . PMID: 22466058. Exclusion Code: X7.22466058
272 Nelson JC, Thase ME, Trivedi MH, . Safety and Tolerability of Adjunctive Aripiprazole in Major Depressive Disorder: A Pooled Post Hoc Analysis (studies CN138-139 and CN138-163). Prim Care Companion J Clin Psychiatry. 2009;11(6):344-52. doi: 10.4088/PCC.08m00744gre. PMID: 20098527. Exclusion Code: X7.20098527
273 Nemets B, Mishory A, Levine J, . Inositol addition does not improve depression in SSRI treatment failures. J Neural Transm (Vienna). 1999;106(7-8):795-8. doi: 10.1007/s007020050200 [doi]. PMID: 10907738. Exclusion Code: X3.10907738
274 NICE. Depression in adults: recognition and management. 2009. Exclusion Code: X14.
275 Niciu MJ, Luckenbaugh DA, Ionescu DF, . Clinical predictors of ketamine response in treatment-resistant major depression. J Clin Psychiatry. 2014 May;75(5):e417-23. doi: 10.4088/JCP.13m08698 [doi]. PMID: 24922494. Exclusion Code: X4.24922494
276 Niciu MJ, Luckenbaugh DA, Ionescu DF, . Ketamine’s antidepressant efficacy is extended for at least four weeks in subjects with a family history of an alcohol use disorder. Int J Neuropsychopharmacol. 2015 Jan;18(1); 10.1093/ijnp/pyu039 [doi]. PMID: 25539512. Exclusion Code: X3.25539512
277 Nierenberg AA, Alpert JE, Gardner-Schuster EE, . Vagus nerve stimulation: 2-year outcomes for bipolar versus unipolar treatment-resistant depression. Biol Psychiatry. 2008;64(6):455-60. doi: 10.1016/j.biopsych.2008.04.036. PMID: 2008-12281-003. Exclusion Code: X4.18571625
278 Nierenberg AA, Papakostas GI, Petersen T, . Lithium augmentation of nortriptyline for subjects resistant to multiple antidepressants. J Clin Psychopharmacol. 2003 Feb;23(1):92-5. PMID: 12544380. Exclusion Code: X13.12544380
279 Normann C. Olanzapine Augmentation Therapy in Treatment-Resistant Depression: A Double-Blind Placebo-Controlled Trial. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2006 January]. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/133/CN00596133/frame.html. NLM Identifier: NCT00273624. Exclusion Code: X10.
280 Nothdurfter C, Eser D, Schule C, . The influence of concomitant neuroleptic medication on safety, tolerability and clinical effectiveness of electroconvulsive therapy. World J Biol Psychiatry. 2006;7(3):162-70. ; 10.1080/15622970500395280 [doi]. PMID: 16861142. Exclusion Code: X2.16861142
281 . Treatment resistant depression (TRD): psychopathological profiles and pharmacological outcomes. European neuropsychopharmacology. Conference: 29th european college of neuropsychopharmacology congress, ECNP 2016. Austria. Conference start: 20160917. Conference end: 20160920; 2016. Exclusion Code: X9.
282 Okamoto H, Shimizu E, Ozawa K, . Lithium augmentation in milnacipran-refractory depression for the prevention of relapse following electroconvulsive therapy. Aust N Z J Psychiatry. 2005 Jan-Feb;39(1-2):108. ; 10.1111/j.1440-1614.2005.01519.x [doi]. PMID: 15660714. Exclusion Code: X5.15660714
283 Otto Michael W, Wisniewski Stephen R. CBT for treatment resistant depression. [References]. Lancet. 2013 Feb 2;381(9864):352-3. PMID: CN-00875787. Exclusion Code: X1.23219571
284 Padberg F, Zwanzger P, Keck ME, . Repetitive transcranial magnetic stimulation (rTMS) in major depression: relation between efficacy and stimulation intensity. Neuropsychopharmacology. 2002 Oct;27(4):638-45. ; 10.1016/S0893-133X(02)00338-X [doi]. PMID: 12377400. Exclusion Code: X13.12377400
285 Padberg F, Zwanzger P, Thoma H, . Repetitive transcranial magnetic stimulation (rTMS) in pharmacotherapy-refractory major depression: comparative study of fast, slow and sham rTMS. Psychiatry Res. 1999 Nov 29;88(3):163-71. PMID: 10622338. Exclusion Code: X13.10622338
286 Padberg F, Zwanzger P, Thoma H, . Repetitive transcranial magnetic stimulation (rTMS) in pharmacotherapy-refractory major depression: comparative study of fast, slow and sham rTMS. Psychiatry Res. 1999 Nov 29;88(3):163-71. . PMID: 10622338. Exclusion Code: X13.10622338
287 Pae CU, Marks DM, Masand PS, . Methylphenidate extended release (OROS MPH) for the treatment of antidepressant-related sexual dysfunction in patients with treatment-resistant depression: results from a 4-week, double-blind, placebo-controlled trial. Clin Neuropharmacol. 2009 Mar-Apr;32(2):85-8. doi: 10.1097/WNF.0b013e31817e559b [doi]. PMID: 19512961. Exclusion Code: X5.19512961
288 Pagnin D, de Queiroz V, Pini S, . Efficacy of ECT in depression: a meta-analytic review. J ECT. 2004 Mar;20(1):13-20. PMID: 15087991. Exclusion Code: X2.15087991
289 Pallanti S, Bernardi S, Di Rollo A, . Unilateral low frequency versus sequential bilateral repetitive transcranial magnetic stimulation: is simpler better for treatment of resistant depression? Neuroscience. 2010 May 5;167(2):323-8. ; 10.1016/j.neuroscience.2010.01.063 [doi]. PMID: 20144692. Exclusion Code: X12.20144692
290 Papadimitropoulou K, Vossen C, Karabis A, . Comparative efficacy of ketamine and other pharmacological and somatic interventions in adult patients with treatment-resistant depression: A network meta-analysis. Value Health. 2015;18(7):A407. Exclusion Code: X9.
291 Papadimitropoulou K, Vossen C, Karabis A, . Comparative Efficacy and Tolerability of Pharmacological and Somatic Interventions in Adult Patients with Treatment-Resistant Depression: A Systematic Review and Network Metaanalysis. Curr Med Res Opin. 2016 Dec 30:1-27. doi: 10.1080/03007995.2016.1277201. PMID: 28035869. Exclusion Code:28035869
292 Pascual-Leone A, Rubio B, Pallardo F, . Rapid-rate transcranial magnetic stimulation of left dorsolateral prefrontal cortex in drug-resistant depression. Lancet. 1996 Jul 27;348(9022):233-7. PMID: 8684201. Exclusion Code: X13.8684201
293 Patten SB. Updated CANMAT Guidelines for Treatment of Major Depressive Disorder. Can J Psychiatry. 2016 Sep;61(9):504-5. doi: 10.1177/0706743716660034. PMID: 27534886. Exclusion Code: X1.27534886
294 Peng H, Zheng H, Li L, . High-frequency rTMS treatment increases white matter FA in the left middle frontal gyrus in young patients with treatment-resistant depression. J Affect Disord. 2012 Feb;136(3):249-57. ; 10.1016/j.jad.2011.12.006 [doi]. PMID: 22217432. Exclusion Code: X6.22217432
295 Perahia DG, Quail D, Desaiah D, . Switching to duloxetine in selective serotonin reuptake inhibitor non- and partial-responders: effects on painful physical symptoms of depression. J Psychiatr Res. 2009 Feb;43(5):512-8. ; 10.1016/j.jpsychires.2008.07.001 [doi]. PMID: 18707693. Exclusion Code: X5.18707693
296 Perez V, Soler J, Puigdemont D, . A double-blind, randomized, placebo-controlled trial of pindolol augmentation in depressive patients resistant to serotonin reuptake inhibitors. Grup de Recerca en Trastorns Afectius. Arch Gen Psychiatry. 1999 Apr;56(4):375-9. PMID: 10197835. Exclusion Code: X13.10197835
297 Perlis RH, Alpert J, Nierenberg AA, . Clinical and sociodemographic predictors of response to augmentation, or dose increase among depressed outpatients resistant to fluoxetine 20 mg/day. Acta Psychiatr Scand. 2003 Dec;108(6):432-8. . PMID: 14616224. Exclusion Code: X13.14616224
298 Perlis RH, Iosifescu DV, Alpert J, . Effect of medical comorbidity on response to fluoxetine augmentation or dose increase in outpatients with treatment-resistant depression. Psychosomatics. 2004 May-Jun;45(3):224-9. ; 10.1176/appi.psy.45.3.224 [doi]. PMID: 15123848. Exclusion Code: X13.15123848
299 Perlis RH, Ostacher MJ, Patel JK, . Predictors of recurrence in bipolar disorder: primary outcomes from the Systematic Treatment Enhancement Program for Bipolar Disorder (STEP-BD). Am J Psychiatry. 2006 Feb;163(2):217-24. doi: 10.1176/appi.ajp.163.2.217. PMID: 16449474. Exclusion Code: X2.16449474
300 Perry EB, Berman RM, Sanacora G, . Pindolol augmentation in depressed patients resistant to selective serotonin reuptake inhibitors: a double-blind, randomized, controlled trial. J Clin Psychiatry. 2004 Feb;65(2):238-43. PMID: 15003079. Exclusion Code: X13.15003079
301 Effects of repeated ketamine infusions on suicidal ideation in treatment-resistant depression. Neuropsychopharmacology. Conference: 55th annual meeting of the american college of neuropsychopharmacology, ACNP 2016. United states. Conference start: 20161204. Conference end: 20161208; 2016. Exclusion Code: X9.
302 Piccinni A, Del Debbio A, Medda P, . Plasma brain-derived neurotrophic factor in treatment-resistant depressed patients receiving electroconvulsive therapy. Eur Neuropsychopharmacol. 2009;19(5):349-55. doi: 10.1016/j.euroneuro.2009.01.002. PMID: 2009-04545-010. Exclusion Code: X4.19223156
303 Venlafaxine versus paroxetine for treatment resistant depression. XXIst Collegium Internationale Neuro psychopharmacologicum, Glasgow, Scotland. 12th 16th July, 1998.; 1998. Exclusion Code: X10.
304 Poirier MF, Boyer P. Venlafaxine and paroxetine in treatment-resistant depression. Double-blind, randomised comparison. Br J Psychiatry. 1999 Jul;175:12-6. PMID: 10621762. Exclusion Code: X13.10621762
305 Polster JD, Kayser S, Bewernick BH, . Effects of electroconvulsive therapy and magnetic seizure therapy on acute memory retrieval. J ECT. 2015 Mar;31(1):13-9. doi: 10.1097/YCT.0000000000000130 [doi]. PMID: 24853650. Exclusion Code: X2.24853650
306 Posternak MA, Zimmerman M. Switching versus augmentation: a prospective, naturalistic comparison in depressed, treatment-resistant patients. J Clin Psychiatry. 2001 Feb;62(2):135-42; quiz 43. PMID: 11247104. Exclusion Code: X13.11247104
307 Price R, Iosifescu DV, Murrough JW, . Effects of intravenous ketamine on explicit and implicit suicdal cognition: A randomized controlled trial in treatment-resistant depression. Biol Psychiatry. 2013;73(9):142S-3S. Exclusion Code: X9.
308 Pridmore S, Bruno R, Turnier-Shea Y, . Comparison of unlimited numbers of rapid transcranial magnetic stimulation (rTMS) and ECT treatment sessions in major depressive episode. Int J Neuropsychopharmacol. 2000;3(2):129-34. doi: 10.1017/s1461145700001784. PMID: 2001-00315-004. Exclusion Code: X13.11343589
309 Puigdemont D, Perez-Egea R, Portella MJ, . Deep brain stimulation of the subcallosal cingulate gyrus: further evidence in treatment-resistant major depression. Int J Neuropsychopharmacol. 2012 Feb;15(1):121-33. doi: 10.1017/S1461145711001088. PMID: 21777510. Exclusion Code: X15.21777510
310 Qaseem A, Snow V, Denberg TD, . Using second-generation antidepressants to treat depressive disorders: a clinical practice guideline from the American College of Physicians. Ann Intern Med. 2008 Nov 18;149(10):725-33. PMID: 19017591. Exclusion Code: X2.19017591
311 Double-blind optimization of subcallosal cingulate deep brain stimulation for treatment-resistant depression: A pilot study [abstract]. Biological Psychiatry [abstracts of the 68th Annual Scientific Convention and Meeting of the Society of Biological Psychiatry, SOBP; 2013 May 16-18; San Francisco, CA United States]; 2013. Exclusion Code: X10.
312 Ramasubbu R, Lang S, Kiss Z. Optimal stimulation parameters in deep brain stimulation (DBS) for intractable depression: A systematic review. Biol Psychiatry. 2015;77(9):261S. Exclusion Code: X4.
313 Rasmussen KG, Mueller M, Knapp RG, . Antidepressant medication treatment failure does not predict lower remission with ECT for major depressive disorder: a report from the consortium for research in electroconvulsive therapy. J Clin Psychiatry. 2007 Nov;68(11):1701-6. PMID: 18052563. Exclusion Code: X2.18052563
314 Rasmussen KG, Mueller M, Rummans TA, . Is baseline medication resistance associated with potential for relapse after successful remission of a depressive episode with ECT? Data from the Consortium for Research on Electroconvulsive Therapy (CORE). J Clin Psychiatry. 2009 Feb;70(2):232-7. . PMID: 19192459. Exclusion Code: X2.19192459
315 Ravindran AV, Al-Subaie A, Abraham G. Quetiapine: novel uses in the treatment of depressive and anxiety disorders. Expert Opin Investig Drugs. 2010 Oct;19(10):1187-204. doi: 10.1517/13543784.2010.515586 [doi]. PMID: 20795889. Exclusion Code: X7.20795889
316 Impact of low vs. high dose olanzapine or risperidone on outcome and side effects in non-psychotic treatment resistant depression. 46th Annual NCDEU (New Clinical Drug Evaluation Unit) Meeting; 2006 June 12 - 15; Boca Raton, FL; 2006. Exclusion Code: X10.
317 Ray S, Nizamie SH, Akhtar S, . Efficacy of adjunctive high frequency repetitive transcranial magnetic stimulation of left prefrontal cortex in depression: a randomized sham controlled study. J Affect Disord. 2011 Jan;128(1-2):153-159. ; 10.1016/j.jad.2010.06.027 [doi]. PMID: 20621361. Exclusion Code: X2.20621361
318 Ricken R, Ulrich S, Schlattmann P, . Tranylcypromine in mind (Part II): Review of clinical pharmacology and meta-analysis of controlled studies in depression. Eur Neuropsychopharmacol. 2017((Ricken R., roland.ricken@charite.de; Adli M.) Department of Psychiatry and Psychotherapy, Charité, Campus Charité Mitte, Charitéplatz 1, 10117 Berlin, Germany)doi: 10.1016/j.euroneuro.2017.04.003. Exclusion Code: X1.
319 Rizvi SJ, Strafella A, Giacobbe P, . Evaluating dopamine function in treatment resistant depression: Impact on open label deep brain stimulation outcomes for depression. Biol Psychiatry. 2014(9 Suppl 1):238s. doi: 10.1016/j.biopsych.2014.03.015. PMID: CN-01060466. Exclusion Code: X9.
320 Robinson RG, Tenev V, Jorge RE. Citalopram for continuation therapy after repetitive transcranial magnetic stimulation in vascular depression. Am J Geriatr Psychiatry. 2009 Aug;17(8):682-7. doi: 10.1097/JGP.0b013e3181a88423 . PMID: 19625785. Exclusion Code: X2.19625785
321 Rodriguez R, Molet J, Puerta P, . Deep brain stimulation for severe treatment-resistant depression. Stereotact Funct Neurosurg. 2013:140. doi: 10.1159/000351783. PMID: CN-01027086. Exclusion Code: X9.
322 Adjunctive ziprasidone in treatment-resistant depression: Pilot study. 156th Annual Meeting of the American Psychiatric Association, May 17-22, San Francisco CA; 2003. Exclusion Code: X10.
323 Romera I, Perez V, Menchon JM, . Early switch strategy in patients with major depressive disorder: a double-blind, randomized study. J Clin Psychopharmacol. 2012 Aug;32(4):479-86. doi: 10.1097/JCP.0b013e31825d9958 [doi]. PMID: 22722513. Exclusion Code: X2.22722513
324 Rosa MA, Gattaz WF, Pascual-Leone A, . Comparison of repetitive transcranial magnetic stimulation and electroconvulsive therapy in unipolar non-psychotic refractory depression: a randomized, single-blind study. Int J Neuropsychopharmacol. 2006 Dec;9(6):667-76. ; 10.1017/S1461145706007127 [doi]. PMID: 16923322. Exclusion Code: X6.16923322
325 Rosenquist PB, Krystal A, Heart KL, . Left dorsolateral prefrontal transcranial magnetic stimulation (TMS): Sleep factor changes during treatment in patients with pharmacoresistant major depressive disorder. Psychiatry Res. 2013;205(1-2):67-73. doi: 10.1016/j.psychres.2012.09.011. PMID: 2012-26544-001. Exclusion Code: X5.23021320
326 Rossini D, Magri L, Lucca A, . Does rTMS hasten the response to escitalopram, sertraline, or venlafaxine in patients with major depressive disorder? A double-blind, randomized, sham-controlled trial. J Clin Psychiatry. 2005 Dec;66(12):1569-75. PMID: 16401159. Exclusion Code: X2.16401159
327 Rush AJ, Fava M, Wisniewski SR, . Sequenced treatment alternatives to relieve depression (STAR*D): rationale and design. Control Clin Trials. 2004 Feb;25(1):119-42. PMID: 15061154. Exclusion Code: X15.15061154
328 Rush AJ, George MS, Marangell LB, . Acute treatment with vagus nerve stimulation for treatment-resistant depression: results of a controlled trial. Int J Neuropsychopharmacol. 2002(Suppl 1):203. PMID: CN-00394466. Exclusion Code: X9.
329 Rush AJ, George MS, Sackeim HA, . Vagus nerve stimulation (VNS) for treatment-resistant depressions: a multicenter study. Biol Psychiatry. 2000 Feb 15;47(4):276-86. . PMID: 10686262. Exclusion Code: X4.10686262
330 Rush AJ, Sackeim HA, Marangell LB, . Effects of 12 months of vagus nerve stimulation in treatment-resistant depression: a naturalistic study. Biol Psychiatry. 2005 Sep 1;58(5):355-63. ; 10.1016/j.biopsych.2005.05.024 [doi]. PMID: 16139581. Exclusion Code: X4.16139581
331 Rush AJ, Sackeim HA, Marangell LB, . Effects of 12 months of vagus nerve stimulation in treatment-resistant depression: A naturalistic study. Biol Psychiatry. 2005 Sep 1;58(5):355-63. doi: 10.1016/j.biopsych.2005.05.024. PMID: CN-00575270. Exclusion Code: X4.16139581
332 Russell JM, Hawkins K, Ozminkowski RJ, . The cost consequences of treatment-resistant depression. J Clin Psychiatry. 2004 Mar;65(3):341-7. PMID: 15096073. Exclusion Code: X3.15096073
333 Rybakowski JK, Suwalska A, Chlopocka-Wozniak M. Potentiation of antidepressants with lithium or carbamazepine in treatment-resistant depression. Neuropsychobiology. 1999 Sep;40(3):134-9. ; 26610 [doi]. PMID: 10494048. Exclusion Code: X13.10494048
334 Sackeim HA. Acute Continuation and Maintenance Treatment of Major Depressive Episodes With Transcranial Magnetic Stimulation. Brain Stimul. 2016 May-Jun;9(3):313-9. doi: 10.1016/j.brs.2016.03.006. PMID: 27052475. Exclusion Code: X1.27052475
335 Sackeim HA, Haskett RF, Mulsant BH, . Continuation pharmacotherapy in the prevention of relapse following electroconvulsive therapy: a randomized controlled trial. JAMA. 2001 Mar 14;285(10):1299-307. . PMID: 11255384. Exclusion Code: X13.11255384
336 Sackeim HA, Haskett RF, Mulsant BH, . Continuation pharmacotherapy in the prevention of relapse following electroconvulsive therapy: a randomized controlled trial. JAMA. 2001 Mar 14;285(10):1299-307. PMID: 11255384. Exclusion Code: X2.11255384
337 Sackeim HA, Rush AJ, Marangell LB, . Long-term antidepressant effects of vagus nerve stimulation (VNS) in treatment-resistant depression. Neuropsychopharmacology. 2004:S204-5. PMID: CN-00595560. Exclusion Code: X7.
338 Salehi B, Mohammadbeigi A, Kamali AR, . Impact comparison of ketamine and sodium thiopental on anesthesia during electroconvulsive therapy in major depression patients with drug-resistant; a double-blind randomized clinical trial. Ann Card Anaesth. 2015 Oct-Dec;18(4):486-90. ; 10.4103/0971-9784.166444 [doi]. PMID: 26440233. Exclusion Code: X6.26440233
339 Salehi I, Hosseini SM, Haghighi M, . Electroconvulsive therapy and aerobic exercise training increased BDNF and ameliorated depressive symptoms in patients suffering from treatment-resistant major depressive disorder. J Psychiatr Res. 2014 Oct;57:117-24. ; 10.1016/j.jpsychires.2014.06.018 [doi]. PMID: 25073431. Exclusion Code: X1.25073431
340 Saligan LN, Luckenbaugh DA, Slonena EE, . An assessment of the anti-fatigue effects of ketamine from a double-blind, placebo-controlled, crossover study in bipolar disorder. J Affect Disord. 2016 Apr;194:115-9. ; 10.1016/j.jad.2016.01.009 [doi]. PMID: 26807672. Exclusion Code: X5.26807672
341 Santaguida PL, MacQueen G, Keshavarz H, . Treatment for Depression After Unsatisfactory Response to SSRIs. Rockville (MD): Agency for Healthcare Research and Quality (US); 2012. Exclusion Code: X2.
342 Santos MA, Rocha FL, Hara C. Efficacy and safety of antidepressant augmentation with lamotrigine in patients with treatment-resistant depression: A randomized, placebo-controlled, double-blind study. Prim Care Companion J Clin Psychiatry. 2008;10(3):187-90. PMID: CN-00707460. Exclusion Code: X6.18615166
343 Double-blind trial of venlafaxine and paroxetine for treatment-resistant depression CONFERENCE ABSTRACT. 11th European College of Neuropsychopharmacology Congress. Paris, France. 31st October - 4th November 1998.; 1998. Exclusion Code: X10.
344 Schaffer CB, Schaffer LC, Nordahl TE, . An Open Trial of Lurasidone as an Acute and Maintenance Adjunctive Treatment for Outpatients With Treatment-Resistant Bipolar Disorder. J Clin Psychopharmacol. 2016 Feb;36(1):88-9. doi: 10.1097/JCP.0000000000000450 [doi]. PMID: 26650972. Exclusion Code: X3.26650972
345 Schening LJ. Refractory depression treatment options: A meta-analysis. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2004;64:5233. PMID: 2004-99008-299. Exclusion Code: X10.
346 Deep brain stimulation to the medial forebrain bundle in treatment-resistant depression-a placebo controlled clinical study. Neuropsychopharmacology. Conference: 55th annual meeting of the american college of neuropsychopharmacology, ACNP 2016. United states. Conference start: 20161204. Conference end: 20161208; 2016. Exclusion Code: X9.
347 Schoeyen HK, Kessler U, Auestad BH, . Treatment resistant bipolar depression: A randomized controlled trial of electroconvulsive therapy. Bipolar Disorders. 2012;14((Schoeyen H.K.) MoodNet Research Group, Stavanger University Hospital, Stavanger, Norway):45. Exclusion Code: X9.
348 Schramm E, Zobel I, Schoepf D, . Cognitive Behavioral Analysis System of Psychotherapy versus Escitalopram in Chronic Major Depression. Psychother Psychosom. 2015;84(4):227-40. ; 10.1159/000381957 [doi]. PMID: 26022410. Exclusion Code: X2.26022410
349 Schrijvers DL, Baeken C, De Raedt R, . The impact of high-frequency repetitive transcranial magnetic stimulation on fine motor functions in medication-resistant major depression. Neuropsychobiology. 2012;66(4):252-8. ; 10.1159/000341881 [doi]. PMID: 23095489. Exclusion Code: X4.23095489
350 Schule C, Baghai TC, Eser D, . Mirtazapine monotherapy versus combination therapy with mirtazapine and aripiprazole in depressed patients without psychotic features: a 4-week open-label parallel-group study. World J Biol Psychiatry. 2007;8(2):112-22. ; 10.1080/15622970601136203 [doi]. PMID: 17455104. Exclusion Code: X2.17455104
351 Schutter DJ. Antidepressant efficacy of high-frequency transcranial magnetic stimulation over the left dorsolateral prefrontal cortex in double-blind sham-controlled designs: a meta-analysis. Psychol Med. 2009 Jan;39(1):65-75. ; 10.1017/S0033291708003462 [doi]. PMID: 18447962. Exclusion Code: X7.18447962
352 Scott J, Palmer S, Paykel E, . Use of cognitive therapy for relapse prevention in chronic depression. Cost-effectiveness study. Br J Psychiatry. 2003 Mar;182:221-7. PMID: 12611785. Exclusion Code: X13.12611785
353 Senova S, Cotovio G, Oliveira-Maia AJ. Duration of antidepressant response to repetitive transcranial magnetic stimulation: A meta-analysis. Brain Stimulation. 2017;10(2):497. doi: 10.1016/j.brs.2017.01.453. Exclusion Code: X9.
354 Serafini G, Howland RH, Rovedi F, . The Role of Ketamine in Treatment-Resistant Depression: A Systematic Review (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):444-61. PMID: DARE-12014069539. Exclusion Code: X7.
355 Serafini G, Pompili M, Belvederi Murri M, . The effects of repetitive transcranial magnetic stimulation on cognitive performance in treatment-resistant depression. A systematic review. Neuropsychobiology. 2015;71(3):125-39. Exclusion Code: X7.25925699
356 Shapira B, Lidsky D, Gorfine M, . Electroconvulsive therapy and resistant depression: clinical implications of seizure threshold. J Clin Psychiatry. 1996 Jan;57(1):32-8. PMID: 8543545. Exclusion Code: X2.8543545
357 Sharon H. Oral ketamine for treatment resistant major depression-a double blind randomized controlled trial. Biol Psychiatry. 2016;79(9):133S-4S. Exclusion Code: X9.
358 Shelton RC, Tollefson GD, Tohen M, . A novel augmentation strategy for treating resistant major depression. Am J Psychiatry. 2001 Jan;158(1):131-4. doi: 10.1176/appi.ajp.158.1.131. PMID: 11136647. Exclusion Code: X13.11136647
359 Silverstein B, Patel P. Poor response to antidepressant medication of patients with depression accompanied by somatic symptomatology in the STAR*D Study. Psychiatry Res. 2011 May 15;187(1-2):121-4. doi: 10.1016/j.psychres.2010.12.026. PMID: 21216475. Exclusion Code: X4.21216475
360 Efficacy, safety, dose response and sustained effect of esketamine in treatment resistant depression (TRD). Neuropsychopharmacology. Conference: 55th annual meeting of the american college of neuropsychopharmacology, ACNP 2016. United states. Conference start: 20161204. Conference end: 20161208; 2016. Exclusion Code: X9.
361 Singh J, Fedgchin M, Daly E, . A double-blind, randomized, placebo-controlled, parallel group, dose frequency study of intravenous ketamine in patients with treatment-resistant depression. Biol Psychiatry. 2014(9 Suppl 1):44s. doi: 10.1016/j.biopsych.2014.03.014. PMID: CN-01060484. Exclusion Code: X9.
362 Singh J, Fedgchin M, Daly E, . Efficacy and safety of intravenous esketamine in patients with treatment-resistant depression: A double-blind, double-randomization, placebocontrolled phase 2a study. Neuropsychopharmacology. 2013:S369-s70. doi: 10.1038/npp.2013.280. PMID: CN-01064243. Exclusion Code: X3.
363 Singh JB, Fedgchin M, Daly E, . Intravenous Esketamine in Adult Treatment-Resistant Depression: A Double-Blind, Double-Randomization, Placebo-Controlled Study. Biol Psychiatry. 2016 Sep 15;80(6):424-31. doi: 10.1016/j.biopsych.2015.10.018. PMID: 26707087. Exclusion Code: X12.26707087
364 Siwek M, Dudek D, Paul IA, . Zinc supplementation augments efficacy of imipramine in treatment resistant patients: a double blind, placebo-controlled study. J Affect Disord. 2009 Nov;118(1-3):187-95. ; 10.1016/j.jad.2009.02.014 [doi]. PMID: 19278731. Exclusion Code: X2.19278731
365 Sobis J, Jarzab M, Hese RT, . Therapeutic efficacy assessment of weak variable magnetic fields with low value of induction in patients with drug-resistant depression. J Affect Disord. 2010 Jun;123(1-3):321-6. ; 10.1016/j.jad.2009.09.016 [doi]. PMID: 19896204. Exclusion Code: X3.19896204
366 Sokolski KN, Conney JC, Brown BJ, . Once-daily high-dose pindolol for SSRI-refractory depression. Psychiatry Res. 2004 Feb 15;125(2):81-6. doi: 10.1016/j.psychres.2003.12.006 . PMID: 15006431. Exclusion Code: X13.15006431
367 Sola CL, Galardy C, Bahn R, . Acceleration of treatment response utilizing concurrent triiodothyronine with right unilateral electroconvulsive therapy in patients with treatment resistant depression. Biol Psychiatry. 2013(9 Suppl 1):47s. PMID: CN-01025612. Exclusion Code: X9.
368 Song GM, Tian X, Shuai T, . Treatment of adults with treatment-resistant depression: Electroconvulsive therapy plus antidepressant or electroconvulsive therapy alone? evidence from an indirect comparison meta-analysis. Medicine (United States). 2015 Jul;94(26):e1052. Exclusion Code: X6.
369 Souery D, Amsterdam J, de Montigny C, . Treatment resistant depression: methodological overview and operational criteria. Eur Neuropsychopharmacol. 1999 Jan;9(1-2):83-91. PMID: 10082232. Exclusion Code: X1.10082232
370 Souza LH, Salum GA, Mosqueiro BP, . Interpersonal psychotherapy as add-on for treatment-resistant depression: A pragmatic randomized controlled trial. J Affect Disord. 2016 Mar 15;193:373-80. doi: 10.1016/j.jad.2016.01.004. PMID: CN-01133662. Exclusion Code: X6.26799332
371 Souza LH, Salum GA, Mosqueiro BP, . Interpersonal psychotherapy as add-on for treatment-resistant depression: A pragmatic randomized controlled trial. J Affect Disord. 2016 Mar 15;193:373-80. Exclusion Code: X2.26799332
372 Spaans HP, Sienaert P, Bouckaert F, . Speed of remission in elderly patients with depression: electroconvulsive therapy v. medication. Br J Psychiatry. 2015 Jan;206(1):67-71. doi: 10.1192/bjp.bp.114.148213. PMID: 25323140. Exclusion Code: X2.25323140
373 Spaans HP, Verwijk E, Comijs HC, . Efficacy and cognitive side effects after brief pulse and ultrabrief pulse right unilateral electroconvulsive therapy for major depression: a randomized, double-blind, controlled study. J Clin Psychiatry. 2013 Nov;74(11):e1029-36. doi: 10.4088/JCP.13m08538. PMID: 24330903. Exclusion Code: X2.24330903
374 Spampinato C, Aguglia E, Concerto C, . Transcranial magnetic stimulation in the assessment of motor cortex excitability and treatment of drug-resistant major depression. IEEE Trans Neural Syst Rehabil Eng. 2013 May;21(3):391-403. doi: 10.1109/TNSRE.2013.2256432 [doi]. PMID: 23559064. Exclusion Code: X4.23559064
375 Spielmans GI, Berman MI, Linardatos E, . Adjunctive atypical antipsychotic treatment for major depressive disorder: a meta-analysis of depression, quality of life, and safety outcomes. PLoS Med. 2013;10(3):e1001403. doi: 10.1371/journal.pmed.1001403. Exclusion Code: X16.23554581
376 Steffens DC, Nelson JC, Eudicone JM, . Efficacy and safety of adjunctive aripiprazole in major depressive disorder in older patients: a pooled subpopulation analysis. Int J Geriatr Psychiatry. 2011 Jun;26(6):564-72. doi: 10.1002/gps.2564 [doi]. PMID: 20827794. Exclusion Code: X7.20827794
377 Stern WM, Tormos JM, Press DZ, . Antidepressant effects of high and low frequency repetitive transcranial magnetic stimulation to the dorsolateral prefrontal cortex: a double-blind, randomized, placebo-controlled trial. J Neuropsychiatry Clin Neurosci. 2007 Spring;19(2):179-86. PMID: 17431065. Exclusion Code: X1.17431065
378 Stewart JW, McGrath PJ, Quitkin FM. Do age of onset and course of illness predict different treatment outcome among DSM IV depressive disorders with atypical features? Neuropsychopharmacology. 2002 Feb;26(2):237-45. ; 10.1016/S0893-133X(01)00313-X [doi]. PMID: 11790519. Exclusion Code: X13.11790519
379 Stewart TD, Hatch A, Largay K, . Effect of symptom severity on efficacy and safety of aripiprazole adjunctive to antidepressant monotherapy in major depressive disorder: a pooled analysis. J Affect Disord. 2014 Jun;162:20-5. ; 10.1016/j.jad.2014.03.017 [doi]. PMID: 24766999. Exclusion Code: X7.24766999
380 Stimpson N, Agrawal N, Lewis G. Randomised controlled trials investigating pharmacological and psychological interventions for treatment-refractory depression: Systematic review. The British Journal of Psychiatry. 2002;181(4):284-94. doi: 10.1192/bjp.181.4.284. PMID: 2002-04799-005. Exclusion Code: X11.12356654
381 Tang Q, Li G, Wang A, . A systematic review for the antidepressant effects of sleep deprivation with repetitive transcranial magnetic stimulation. BMC Psychiatry. 2015 Nov 14;15:282. doi: 10.1186/s12888-015-0674-8 . PMID: 26573324. Exclusion Code: X7.26573324
382 Taylor D, Carlyle JA, McPherson S, . Tavistock Adult Depression Study (TADS): a randomised controlled trial of psychoanalytic psychotherapy for treatment-resistant/treatment-refractory forms of depression. BMC Psychiatry. 2012;12:60. ; 10.1186/1471-244X-12-60 [doi]. PMID: 22686185. Exclusion Code: X5.22686185
383 Tew JD, Jr., Mulsant BH, Haskett RF, . A randomized comparison of high-charge right unilateral electroconvulsive therapy and bilateral electroconvulsive therapy in older depressed patients who failed to respond to 5 to 8 moderate-charge right unilateral treatments. J Clin Psychiatry. 2002;63(12):1102-5. doi: 10.4088/JCP.v63n1203. PMID: 2003-04162-004. Exclusion Code: X13.12523868
384 Thase ME. The role of Axis II comorbidity in the management of patients with treatment-resistant depression. Psychiatr Clin North Am. 1996 Jun;19(2):287-309. PMID: 8827191. Exclusion Code: X1.8827191
385 Thase ME, Rush AJ. When at first you don’t succeed: sequential strategies for antidepressant nonresponders. J Clin Psychiatry. 1997;58 Suppl 13:23-9. PMID: 9402916. Exclusion Code: X1.9402916
386 Thase ME, Rush AJ, Howland RH, . Double-blind switch study of imipramine or sertraline treatment of antidepressant-resistant chronic depression. Arch Gen Psychiatry. 2002 Mar;59(3):233-9. . PMID: 11879161. Exclusion Code: X13.11879161
387 Thase ME, Trivedi MH, Nelson JC, . Examining the efficacy of adjunctive aripiprazole in major depressive disorder: a pooled analysis of 2 studies. Prim Care Companion J Clin Psychiatry. 2008;10(6):440-7. PMID: 19287552. Exclusion Code: X7.19287552
388 Thase ME, Youakim JM, Skuban A, . Efficacy and safety of adjunctive brexpiprazole 2 mg in major depressive disorder: a phase 3, randomized, placebo-controlled study in patients with inadequate response to antidepressants. J Clin Psychiatry. 2015 Sep;76(9):1224-31. doi: 10.4088/JCP.14m09688 [doi]. PMID: 26301701. Exclusion Code: X3.26301701
389 Thase ME, Youakim JM, Skuban A, . Adjunctive brexpiprazole 1 and 3 mg for patients with major depressive disorder following inadequate response to antidepressants: a phase 3, randomized, double-blind study. J Clin Psychiatry. 2015 Sep;76(9):1232-40. doi: 10.4088/JCP.14m09689 [doi]. PMID: 26301771. Exclusion Code: X3.26301771
390 Thomas LJ, Abel A, Ridgway N, . Cognitive behavioural therapy as an adjunct to pharmacotherapy for treatment resistant depression in primary care: the CoBalT randomised controlled trial protocol. Contemp Clin Trials. 2012 Mar;33(2):312-9. ; 10.1016/j.cct.2011.10.016 [doi]. PMID: 22101205. Exclusion Code: X5.22101205
391 Thomas SJ, Shin M, McInnis MG, . Combination therapy with monoamine oxidase inhibitors and other antidepressants or stimulants: Strategies for the management of treatment-resistant depression. Pharmacotherapy. 2015;35(4):433-49. Exclusion Code: X7.25884531
392 Longer-term efficacy and safety of olanzapine and fluoxetine combination versus fluoxetine monotherapy following successful combination therapy of treatment-resistant depression [abstract]. Neuropsychopharmacology [abstracts of the 51st annual meeting of the american college of neuropsychopharmacology, acnp; 2012 feb 2-6; hollywood, FL united states]; 2012. Exclusion Code: X10.
393 Tohen M, Case M, Trivedi MH, . Olanzapine/fluoxetine combination in patients with treatment-resistant depression: rapid onset of therapeutic response and its predictive value for subsequent overall response in a pooled analysis of 5 studies. J Clin Psychiatry. 2010 Apr;71(4):451-62. doi: 10.4088/JCP.08m04984gre [doi]. PMID: 20361905. Exclusion Code: X7.20361905
394 Trangle M, Gursky J, Haight R, . Adult depression in primary care. Institute for Clinical Systems Improvement (ICSI). 2016. Exclusion Code: X2.
395 Triggs WJ, Ricciuti N, Ward HE, . Right and left dorsolateral pre-frontal rTMS treatment of refractory depression: a randomized, sham-controlled trial. Psychiatry Res. 2010 Aug 15;178(3):467-74. ; 10.1016/j.psychres.2010.05.009 [doi]. PMID: 20643486. Exclusion Code: X12.20643486
396 Trivedi MH, Corey-Lisle PK, Guo Z, . Remission, response without remission, and nonresponse in major depressive disorder: impact on functioning. Int Clin Psychopharmacol. 2009 May;24(3):133-8. doi: 10.1097/YIC.0b013e3283277614 [doi]. PMID: 19318972. Exclusion Code: X7.19318972
397 Trivedi MH, Morris DW, Wisniewski SR, . Increase in work productivity of depressed individuals with improvement in depressive symptom severity. Am J Psychiatry. 2013 Jun;170(6):633-41. doi: 10.1176/appi.ajp.2012.12020250. PMID: 23558394. Exclusion Code: X4.23558394
398 Trivedi MH, Thase ME, Fava M, . Adjunctive aripiprazole in major depressive disorder: analysis of efficacy and safety in patients with anxious and atypical features. J Clin Psychiatry. 2008 Dec;69(12):1928-36. . PMID: 19192475. Exclusion Code: X7.19192475
399 Trivedi MH, Thase ME, Osuntokun O, . An integrated analysis of olanzapine/fluoxetine combination in clinical trials of treatment-resistant depression. J Clin Psychiatry. 2009 Mar;70(3):387-96. . PMID: 19284928. Exclusion Code: X7.19284928
400 Tulen JH, Volkers AC, van den Broek WW, . Sustained effects of phenelzine and tranylcypromine on orthostatic challenge in antidepressant-refractory depression. J Clin Psychopharmacol. 2006 Oct;26(5):542-4. doi: 10.1097/01.jcp.0000236657.08663.ae . PMID: 16974207. Exclusion Code: X6.16974207
401 Unterecker S, Burger R, Hohage A, . Interaction of valproic acid and amitriptyline: analysis of therapeutic drug monitoring data under naturalistic conditions. J Clin Psychopharmacol. 2013 Aug;33(4):561-4. doi: 10.1097/JCP.0b013e3182905d42 [doi]. PMID: 23775047. Exclusion Code: X2.23775047
402 Valiengo L, Bensenor IM, Goulart AC, . The sertraline versus electrical current therapy for treating depression clinical study (select-TDCS): results of the crossover and follow-up phases. Depress Anxiety. 2013 Jul;30(7):646-53. doi: 10.1002/da.22079 [doi]. PMID: 23625554. Exclusion Code: X6.23625554
403 van Beusekom BS, van den Broek WW, Birkenhager TK. Long-term follow-up after successful electroconvulsive therapy for depression: a 4- to 8-year naturalistic follow-up study. J ECT. 2007 Mar;23(1):17-20. doi: 10.1097/01.yct.0000263255.98796.30 . PMID: 17435567. Exclusion Code: X4.17435567
404 Wade RL, Kindermann SL, Hou Q, . Comparative assessment of adherence measures and resource use in SSRI/SNRI-treated patients with depression using second-generation antipsychotics or L-methylfolate as adjunctive therapy. J Manag Care Pharm. 2014 Jan;20(1):76-85. ; 10.18553/jmcp.2014.20.1.76 [doi]. PMID: 24372461. Exclusion Code: X2.24372461
405 Wang G, McIntyre A, Earley WR, . A Randomized, Double-blind Study of the Efficacy and Tolerability of Extended Release Quetiapine Fumarate (Quetiapine XR) Monotherapy in Patients with Major Depressive Disorder. Psychopharmacol Bull. 2012 Feb 15;45(1):5-30. PMID: 27738365. Exclusion Code: X2.27738365
406 Wang G, McIntyre A, Earley WR, . A randomized, double-blind study of the efficacy and tolerability of extended-release quetiapine fumarate (quetiapine XR) monotherapy in patients with major depressive disorder. Neuropsychiatr Dis Treat. 2014;10:201-16. doi: 10.2147/NDT.S50248. PMID: 24511235. Exclusion Code: X2.24511235
407 Wang HR, Woo YS, Bahk WM. Ineffectiveness of nicotinic acetylcholine receptor antagonists for treatment-resistant depression: a meta-analysis. Int Clin Psychopharmacol. 2016;31(5):241-8. Exclusion Code: X3.26982579
408 Weber-Hamann B, Gilles M, Schilling C, . Improved insulin sensitivity in 51 nondiabetic depressed inpatients remitting during antidepressive treatment with mirtazapine and venlafaxine. J Clin Psychopharmacol. 2008 Oct;28(5):581-4. doi: 10.1097/JCP.0b013e31818582ef . PMID: 18794665. Exclusion Code: X2.18794665
409 Weeks HR, 3rd, Tadler SC, Smith KW, . Antidepressant and neurocognitive effects of isoflurane anesthesia versus electroconvulsive therapy in refractory depression. PLoS One. 2013;8(7):e69809. doi: 10.1371/journal.pone.0069809 . PMID: 23922809. Exclusion Code: X4.23922809
410 Weisler RH, Khan A, Trivedi MH, . Analysis of suicidality in pooled data from 2 double-blind, placebo-controlled aripiprazole adjunctive therapy trials in major depressive disorder. J Clin Psychiatry. 2011 Apr;72(4):548-55. doi: 10.4088/JCP.09m05495gre [doi]. PMID: 20816039. Exclusion Code: X7.20816039
411 Wen XJ, Wang LM, Liu ZL, . Metaanalysis on the efficacy and tolerability of the augmentation of antidepressants with atypical antipsychotics in patients with major depressive disorder. Braz J Med Biol Res. 2014 Jul;47(7):605-16. . PMID: 24919175. Exclusion Code: X7.24919175
412 Whyte EM, Basinski J, Farhi P, . Geriatric depression treatment in nonresponders to selective serotonin reuptake inhibitors. J Clin Psychiatry. 2004 Dec;65(12):1634-41. PMID: 15641868. Exclusion Code: X13.15641868
413 Williams NR, Short EB, Hopkins T, . Five-Year Follow-Up of Bilateral Epidural Prefrontal Cortical Stimulation for Treatment-Resistant Depression. Brain Stimul. 2016 Nov - Dec;9(6):897-904. doi: 10.1016/j.brs.2016.06.054. PMID: 27443912. Exclusion Code: X3.27443912
414 Wisniewski SR, Chen CC, Kim E, . Global benefit-risk analysis of adjunctive aripiprazole in the treatment of patients with major depressive disorder. Pharmacoepidemiol Drug Saf. 2009 Oct;18(10):965-72. doi: 10.1002/pds.1805 [doi]. PMID: 19662630. Exclusion Code: X7.19662630
415 Yip AG, George MS, Tendler A, . 61% of unmedicated treatment resistant depression patients who did not respond to acute TMS treatment responded after four weeks of twice weekly deep TMS in the Brainsway pivotal trial. Brain stimulation. 2017 Jul-Aug 2017;10(4):847-9. doi: 10.1016/j.brs.2017.02.013. PMID: CN-01337488. Exclusion Code: X4.28330592
416 . Adjunctive brexpiprazole for treating major depressive disorder, meta-analysis. European neuropsychopharmacology. Conference: 29th european college of neuropsychopharmacology congress, ECNP 2016. Austria. Conference start: 20160917. Conference end: 20160920; 2016. Exclusion Code: X9.
417 Yoon S, Jeon SW, Ko YH, . Adjunctive Brexpiprazole as a Novel Effective Strategy for Treating Major Depressive Disorder: A Systematic Review and Meta-Analysis. J Clin Psychopharmacol. 2017 Feb;37(1):46-53. doi: 10.1097/JCP.0000000000000622. PMID: 27941419. Exclusion Code: X3.27941419
418 Yoshimura R, Ikenouchi-Sugita A, Hori H, . Adding a low dose atypical antipsychotic drug to an antidepressant induced a rapid increase of plasma brain-derived neurotrophic factor levels in patients with treatment-resistant depression. Prog Neuropsychopharmacol Biol Psychiatry. 2010 Mar 17;34(2):308-12. ; 10.1016/j.pnpbp.2009.12.003 [doi]. PMID: 20005280. Exclusion Code: X4.20005280
419 Youssef NA, McCall WV. Relapse prevention after index electroconvulsive therapy in treatment-resistant depression. Ann Clin Psychiatry. 2014;26(4):288-96. PMID: 2014-49981-006. Exclusion Code: X7.25401716
420 Zarate CA, Jr., Mathews D, Ibrahim L, . A randomized trial of a low-trapping nonselective N-methyl-D-aspartate channel blocker in major depression. Biol Psychiatry. 2013 Aug 15;74(4):257-64. ; 10.1016/j.biopsych.2012.10.019 [doi]. PMID: 23206319. Exclusion Code: X3.23206319
421 Zhang XH, Wang LW, Wang JJ, . Adjunctive treatment with transcranial magnetic stimulation in treatment resistant depression: a randomized, double-blind, sham controlled study. Shanghai Archives of Psychiatry. 2001;23(1):17-24. PMID: CN-00782101. Exclusion Code: X6.
422 Zheng H, Zhang L, Li L, . High-frequency rTMS treatment increases left prefrontal myo-inositol in young patients with treatment-resistant depression. Prog Neuropsychopharmacol Biol Psychiatry. 2010 2010 Oct;34(7):1189-95. doi: 10.1016/j.pnpbp.2010.06.009. PMID: 2010-15001-001. First Author & Affiliation: Zheng, Huirong. Exclusion Code: X5.20600472
423 Zheng H, Zhang L, Li L, . High-frequency rTMS treatment increases left prefrontal myo-inositol in young patients with treatment-resistant depression. Prog Neuropsychopharmacol Biol Psychiatry. 2010 Oct 1;34(7):1189-95. ; 10.1016/j.pnpbp.2010.06.009 [doi]. PMID: 20600472. Exclusion Code: X6.20600472
424 Zhong X, He H, Zhang C, . Mood and neuropsychological effects of different doses of ketamine in electroconvulsive therapy for treatment-resistant depression. J Affect Disord. 2016;201:124-30. doi: 10.1016/j.jad.2016.05.011. PMID: CN-01158791. Exclusion Code: X6.27208499
425 Zhou X, Keitner GI, Qin B, . Atypical Antipsychotic Augmentation for Treatment-Resistant Depression: A Systematic Review and Network Meta-Analysis. Int J Neuropsychopharmacol. 2015 Oct;18(11):pyv060. ; 10.1093/ijnp/pyv060 [doi]. PMID: 26012350. Exclusion Code: X6.26012350
426 Zhou X, Ravindran AV, Qin B, . Comparative efficacy, acceptability, and tolerability of augmentation agents in treatment-resistant depression: systematic review and network meta-analysis. J Clin Psychiatry. 2015 Apr;76(4):e487-98. doi: 10.4088/JCP.14r09204 [doi]. PMID: 25919841. Exclusion Code: X6.25919841
427 Zhu H, Yu J, Zheng H. A study of switching to mirtazapine for treatment-resistant depression. Shanghai Archives of Psychiatry. 2003(6):355-7. PMID: CN-00711526. Exclusion Code: X1.