# Appendix A Literature Search Strategies and Yields

## Published Literature

Table A1 PubMed search, 10/14/16. Limited to date range of 1/1/1995 – present.

Search | Query | Items found
#1 | Search “Depression”[Meshl OR “Depressive Disorder”[Mesh] | 173285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#5 | Search “Depression”[Mesh] OR “Depressive Disorder”[Mesh] Filters: Publication date from 1995/01/01; Humans; English; Adult: 19+ years | 78019 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 | Search (((“Drug Resistance”[Mesh] OR refractory[tw] OR resistant[tw] OR augment OR switch)) OR (Non-remitting OR Unremitted OR “Inadequate response” OR Refractory OR Resist* OR “Fail respon*” OR Augment OR Switch OR “Drug Resistance” OR “Treatment Failure” OR Retreatment)) OR (adjunctive OR “second step” OR second-step) | 1168596 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 | Search (#5 AND #6) | 3308 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 | Search (#5 AND #6) Filters: Systematic Reviews | 94 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 | Search (((“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 616555
#10 | Search (((“Longitudinal Studies”[Mesh] OR “Comparative Study”[Publication Type]) OR “Cohort Studies”[Mesh] OR “observational studies”[tw]) OR “Historically Controlled Study”[Mesh] OR “Interrupted Time Series Analysis”[Mesh])
#14 | Search “Guideline” [Publication Type] | 28297
#16 | Search “Consensus Development Conference, NIH”[Publication Type] OR “Consensus Development Conference” [Publication Type] | 10182 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 | Search (#9 OR #10 OR #14 OR #16) | 3436652
#18 | Search (#7 AND #17) | 1656
#19 | Search (#8 OR #18) | 1692

NIH = National Institutes of Health

Table A2 PubMed update search, 8/18/17. Limited to date range of 6/1/2015 – present.

Search | Query | Items found
#1 | Search “Depression”[Meshl OR “Depressive Disorder”[Meshl Sort by: Relevance | 181030 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#5 | Search “Depression”[Mesh] OR “Depressive Disorder”[Mesh] Sort by: RelevanceFilters: Publication date from 2015/06/01; Humans; English; Adult: 19+ years | 9384 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 | Search (((“Drug Resistance”[Mesh] OR refractory[tw] OR resistant[tw] OR augment OR switch)) OR (Non-remitting OR Unremitted OR “Inadequate response” OR Refractory OR Resist* OR “Fail respon*” OR Augment OR Switch OR “Drug Resistance” OR “Treatment Failure” OR Retreatment)) OR (adjunctive OR “second step” OR second-step) Sort by: Relevance | 1232463 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 | Search (#5 AND #6) Sort by: Relevance | 411
#8 | Search (#5 AND #6) Sort by: Relevance Filters: Systematic Reviews | 913
#9 | Search (((“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Meshl Sort by: Relevance | 645671 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 | Search (((“Longitudinal Studies”[Mesh] OR “Comparative Study”[Publication Type]) OR “Cohort Studies”[Mesh] OR “observational studies”[tw]) OR “Historically Controlled Study”[Mesh] OR “Interrupted Time Series Analysis”[Meshl) Sort by: Relevance | 3147788 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 | Search “Guideline” [Publication Typel Sort by: Relevance | 29604
#12 | Search “Consensus Development Conference, NIH” [Publication Type] OR “Consensus Development Conference” [Publication Typel Sort by: Relevance | 10634
#13 | Search (#9 OR #10 OR #11 OR #12) Sort by: Relevance | 3571868 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 | Search (#7 AND #13) Sort by: Relevance | 202
#16 | Search (#8 OR #14) Sort by: Relevance | 208 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)

Table A3 Databases searched for “Treatment Resistant Depression”, 10/14/16. Limited to date range of 1/1/1995 – present.

Database | Hits
Cochrane Database of Systematic Reviews | 4
Cochrane DARE | 13
Cochrane CCTR | 189
EMBASE | 200
PsychInfo | 361

CCTR = Central Register of Controlled Trials; DARE = Database of Abstracts of Reviews of Effects; EMBASE = Excerpta Medica Database; PsychInfo = Psychological Information Database

Table A4 Update databases searched for “Treatment Resistant Depression,” 8/18/17. Limited to date range of 6/1/2015 – present.

Database | Hits
Cochrane Database of Systematic Reviews | 0
Cochrane DARE | 0
Cochrane CCTR | 74
EMBASE | 45
PsychInfo | 33

CCTR = Central Register of Controlled Trials; DARE = Database of Abstracts of Reviews of Effects; EMBASE = Excerpta Medica Database; PsychInfo = Psychological Information Database

NIH = National Institutes of Health

## Gray Literature

Table A5 ClinicalTrials.gov, 8/24/16. Limited to date range of 1/1/1995 – present.

ID | Search | Hits
#1 | “Treatment resistant depression”^*^ | 178

* A search for “Treatment-resistant depression” did not result in additional hits

Table A6 Update, ClinicalTrials.gov, 8/18/17. Limited to date range of 6/1/2015 – present.

ID | Search | Hits
#1 | “Treatment resistant depression”^*^ | 13

* A search for “Treatment-resistant depression” did not result in additional hits

Table A7 Health Services Research Projects in Progress (HSRProj), 8/24/16. Limited to date range of 1/1/1995 – present.

ID | Search | Hits
#1 | “Treatment resistant depression”^*^ | 2

* A search for “Treatment-resistant depression” did not result in additional hits; an updated search on 8/18/17 did not result in any additional hits

Table A8 National Guideline Clearinghouse, 10/20/16. Limited to date range of 1/1/1995 – present.

ID | Search | Hits
#1 | “Treatment resistant depression” | 30
#2 | “Treatment-resistant depression” | 1

* An updated search on 8/18/17 did not result in any additional hits

Table A9 Non-Database Sources and Search Dates

Name | Source | Search Date (s)
NIMH | www.nimh.nih.gov | First search: 9/30/16 Second search: 12/6/16 Updated search:8/18/17
UpToDate | www.uptodate.com | First search: 1/10/17 Updated search: 8/18/17
EHC Website | www.effectivehealthcare.ahrq.gov | First search: 11/8/16 Updated search: 8/18/17
SAMHSA | www.samhsa.gov | First search: 12/6/16 Updated search: 8/18/17
FDA | www.fda.gov | First search: Drugs: 1/10/17–2/9/17 Devices: 12/21/16–1/6/17 Updated search: 8/18/17

EHC = Effective Health Care; FDA = Food and Drug Administration; NIMH = National Institute of Mental Health; SAMHSA = Substance Abuse Mental Health Services Administration

Table A10 Additional Sources

Name | Source | Details
MEDCAC Panel Proceedings | https://www.cms.gov/ | On 12/6/16 MEDCAC panel proceeding documents from April 2016 were searched
Proposal/Protocol Only References | EndNote Database (provided by librarian, 10/13/16) | References from the TRD proposal and protocol were screened for relevancy on 1/20/17

MEDCAC = Medicare Evidence Development and Coverage Advisory; TRD = Treatment Resistant Depression