# References

1 Eberhardt RT, Raffetto JD. Chronic venous insufficiency. Circulation. 2014 Jul 22;130(4):333-46. doi: 10.1161/CIRCULATIONAHA.113.006898. PMID: 25047584.25047584
2 Kearon C, Akl EA, Comerota AJ, . Antithrombotic therapy for VTE disease: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012 Feb;141(2 Suppl):e419S-94S. doi: 10.1378/chest.112301. PMID: 22315268.22315268
3 Korn P, Patel ST, Heller JA, . Why insurers should reimburse for compression stockings in patients with chronic venous stasis. J Vasc Surg. 2002 May;35(5):950-7. PMID: 12021694.12021694
4 Smith JJ, Garratt AM, Guest M, . Evaluating and improving health-related quality of life in patients with varicose veins. J Vasc Surg. 1999 Oct;30(4):710-9. PMID: 10514210.10514210
5 Bates SM, Jaeschke R, Stevens SM, . Diagnosis of DVT: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012 Feb;141(2 Suppl):e351S-418S. doi: 10.1378/chest.112299. PMID: 22315267.22315267
6 Eklof B, Rutherford RB, Bergan JJ, . Revision of the CEAP classification for chronic venous disorders: consensus statement. J Vasc Surg. 2004 Dec;40(6):1248-52. doi: 10.1016/j.jvs.2004.09.027. PMID: 15622385.15622385
7 Porter JM, Moneta GL. Reporting standards in venous disease: an update. International Consensus Committee on Chronic Venous Disease. J Vasc Surg. 1995 Apr;21(4):635-45. PMID: 7707568.7707568
8 Agency for Healthcare Research and Quality (AHRQ). Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality. January 2014. Available at: http://www.effectivehealthcare.ahrq.gov/methodsguide.cfm. Accessed April 1, 2016.
9 Moher D, Liberati A, Tetzlaff J, . Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009 Jul 21;6(7):e1000097. doi: 10.1371/journal.pmed.1000097. PMID: 19621072.19621072
10 Agency for Healthcare Research and Quality (AHRQ). Evidence-based Practice Center Systematic Review Protocol. Project Title: Treatment Strategies for Patients with Lower Extremity Chronic Venous Disease (LECVD). Available at: http://www.ahrq.gov/sites/default/files/wysiwyg/research/findings/ta/topicrefinement/lecvd_protocol.pdf. Accessed May 25, 2016.
11 Seager MJ, Busuttil A, Dharmarajah B, . Editor’s Choice - A Systematic Review of Endovenous Stenting in Chronic Venous Disease Secondary to Iliac Vein Obstruction. Eur J Vasc Endovasc Surg. 2016 Jan;51(1):100-20. doi: 10.1016/j.ejvs.2015.09.002. PMID: 26464055.26464055
12 Razavi MK, Jaff MR, Miller LE. Safety and Effectiveness of Stent Placement for Iliofemoral Venous Outflow Obstruction: Systematic Review and Meta-Analysis. Circ Cardiovasc Interv. 2015 Oct;8(10):e002772. doi: 10.1161/circinterventions.115.002772. PMID: 26438686.26438686
13 Bellmunt-Montoya S, Escribano JM, Dilme J, . CHIVA method for the treatment of chronic venous insufficiency. Cochrane Database Syst Rev. 2015;6:Cd009648. doi: 10.1002/14651858.CD009648.pub3. PMID: 26121003.26121003
14 El-Sheikha J, Carradice D, Nandhra S, . Systematic review of compression following treatment for varicose veins. Br J Surg. 2015 Jun;102(7):719-25. doi: 10.1002/bjs.9788. PMID: 25833417.25833417
15 Goel RR, Abidia A, Hardy SC. Surgery for deep venous incompetence. Cochrane Database Syst Rev. 2015;2:Cd001097. doi: 10.1002/14651858.CD001097.pub3. PMID: 25702915.25702915
16 Nelson EA, Bell-Syer SE. Compression for preventing recurrence of venous ulcers. Cochrane Database Syst Rev. 2014;9:Cd002303. doi: 10.1002/14651858.CD002303.pub3. PMID: 25203307.25203307
17 Nesbitt C, Bedenis R, Bhattacharya V, . Endovenous ablation (radiofrequency and laser) and foam sclerotherapy versus open surgery for great saphenous vein varices. Cochrane Database Syst Rev. 2014;7:Cd005624. doi: 10.1002/14651858.CD005624.pub3. PMID: 25075589.25075589
18 Carroll C, Hummel S, Leaviss J, . Systematic review, network meta-analysis and exploratory cost-effectiveness model of randomized trials of minimally invasive techniques versus surgery for varicose veins. Br J Surg. 2014 Aug;101(9):1040-52. doi: 10.1002/bjs.9566. PMID: 24964976.24964976
19 Mauck KF, Asi N, Elraiyah TA, . Comparative systematic review and metaanalysis of compression modalities for the promotion of venous ulcer healing and reducing ulcer recurrence. J Vasc Surg. 2014 Aug;60(2 Suppl):71S-90S.e1-2. doi: 10.1016/j.jvs.2014.04.060. PMID: 24877851.24877851
20 Mauck KF, Asi N, Undavalli C, . Systematic review and meta-analysis of surgical interventions versus conservative therapy for venous ulcers. J Vasc Surg. 2014 Aug;60(2 Suppl):60S-70S.e1-2. doi: 10.1016/j.jvs.2014.04.059. PMID: 24835693.24835693
21 Shingler S, Robertson L, Boghossian S, . Compression stockings for the initial treatment of varicose veins in patients without venous ulceration. Cochrane Database Syst Rev. 2013;12:Cd008819. doi: 10.1002/14651858.CD008819.pub3. PMID: 24323411.24323411
22 Samuel N, Carradice D, Wallace T, . Endovenous thermal ablation for healing venous ulcers and preventing recurrence. Cochrane Database Syst Rev. 2013;10:Cd009494. doi: 10.1002/14651858.CD009494.pub2. PMID: 24096603.24096603
23 Bellmunt-Montoya S, Escribano JM, Dilme J, . CHIVA method for the treatment of chronic venous insufficiency. Cochrane Database Syst Rev. 2013;7:Cd009648. doi: 10.1002/14651858.CD009648.pub2. PMID: 23821413.23821413
24 Huang TW, Chen SL, Bai CH, . The optimal duration of compression therapy following varicose vein surgery: a metaanalysis of randomized controlled trials. Eur J Vasc Endovasc Surg. 2013 Apr;45(4):397-402. doi: 10.1016/j.ejvs.2013.01.030. PMID: 23433496.23433496
25 Pan Y, Zhao J, Mei J, . Comparison of endovenous laser ablation and high ligation and stripping for varicose vein treatment: a meta-analysis. Phlebology. 2014 Mar;29(2):109-19. doi: 10.1177/0268355512473911. PMID: 23390218.23390218
26 O’Meara S, Cullum N, Nelson EA, . Compression for venous leg ulcers. Cochrane Database Syst Rev. 2012;11:Cd000265. doi: 10.1002/14651858.CD000265.pub3. PMID: 23152202.23152202
27 Siribumrungwong B, Noorit P, Wilasrusmee C, . A systematic review and metaanalysis of randomised controlled trials comparing endovenous ablation and surgical intervention in patients with varicose vein. Eur J Vasc Endovasc Surg. 2012 Aug;44(2):214-23. doi: 10.1016/j.ejvs.2012.05.017. PMID: 22705163.22705163
28 Cohen JM, Akl EA, Kahn SR. Pharmacologic and compression therapies for postthrombotic syndrome: a systematic review of randomized controlled trials. Chest. 2012 Feb;141(2):308-20. doi: 10.1378/chest.11-1175. PMID: 22315114.22315114
29 Shingler S, Robertson L, Boghossian S, . Compression stockings for the initial treatment of varicose veins in patients without venous ulceration. Cochrane Database Syst Rev. 2011(11):Cd008819. doi: 10.1002/14651858.CD008819.pub2. PMID: 22071857.22071857
30 Nesbitt C, Eifell RK, Coyne P, . Endovenous ablation (radiofrequency and laser) and foam sclerotherapy versus conventional surgery for great saphenous vein varices. Cochrane Database Syst Rev. 2011(10):Cd005624. doi: 10.1002/14651858.CD005624.pub2. PMID: 21975750.21975750
31 Murad MH, Coto-Yglesias F, ZumaetaGarcia M, . A systematic review and meta-analysis of the treatments of varicose veins. J Vasc Surg. 2011 May;53(5 Suppl):49s-65s. doi: 10.1016/j.jvs.2011.02.031. PMID: 21536173.21536173
32 Leopardi D, Hoggan BL, Fitridge RA, . Systematic review of treatments for varicose veins. Ann Vasc Surg. 2009 Mar;23(2):264-76. doi: 10.1016/j.avsg.2008.10.007. PMID: 19059756.19059756
33 Subbiah R, Aggarwal V, Zhao H, . Effect of compression stockings on post thrombotic syndrome in patients with deep vein thrombosis: a meta-analysis of randomised controlled trials. Lancet Haematol. 2016 Jun;3(6):e293-300. doi: 10.1016/s2352-3026(16)30017-5. PMID: 27264039.27264039
34 Jin YW, Ye H, Li FY, . Compression Stockings for Prevention of Postthrombotic Syndrome: A Systematic Review and MetaAnalysis. Vasc Endovascular Surg. 2016 Jul;50(5):328-34. doi: 10.1177/1538574416652242. PMID: 27260750.27260750
35 Wu B, Lu J, Yang M, . Sulodexide for treating venous leg ulcers. Cochrane Database Syst Rev. 2016 Jun 2;6:Cd010694. doi: 10.1002/14651858.CD010694.pub2. PMID: 27251175.27251175
36 Balint R, Farics A, Parti K, . Which endovenous ablation method does offer a better long-term technical success in the treatment of the incompetent great saphenous vein? Review. Vascular. 2016 Apr 28doi: 10.1177/1708538116648035. PMID: 27126643.27126643
37 Kheirelseid EA, Bashar K, Aherne T, . Evidence for varicose vein surgery in venous leg ulceration. Surgeon. 2016 Apr 16doi: 10.1016/j.surge.2016.03.007. PMID: 27095286.27095286
38 Burgstaller JM, Steurer J, Held U, . Efficacy of compression stockings in preventing post-thrombotic syndrome in patients with deep venous thrombosis: a systematic review and metaanalysis. Vasa. 2016;45(2):141-7. doi: 10.1024/03011526/a000508. PMID: 27058800.27058800
39 Skervin AL, Thapar A, Franchini AJ, . Systematic Review and Meta-Analysis of Utility of Graduated Compression Stockings in Prevention of Post-Thrombotic Syndrome. Eur J Vasc Endovasc Surg. 2016 Jun;51(6):838-45. doi: 10.1016/j.ejvs.2016.02.022. PMID: 27026391.27026391
40 Van der Velden SK, Lawaetz M, De Maeseneer MG, . Predictors of Recanalization of the Great Saphenous Vein in Randomized Controlled Trials 1 Year After Endovenous Thermal Ablation. Eur J Vasc Endovasc Surg. 2016 Mar 16doi: 10.1016/j.ejvs.2016.01.021. PMID: 26994834.26994834
41 Weller CD, Buchbinder R, Johnston RV. Interventions for helping people adhere to compression treatments for venous leg ulceration. Cochrane Database Syst Rev. 2016;3:Cd008378. doi: 10.1002/14651858.CD008378.pub3. PMID: 26932818.26932818
42 de Oliveira Carvalho PE, Magolbo NG, De Aquino RF, . Oral aspirin for treating venous leg ulcers. Cochrane Database Syst Rev. 2016;2:Cd009432. doi: 10.1002/14651858.CD009432.pub2. PMID: 26889740.26889740
43 Kahn SR, Galanaud JP, Vedantham S, . Guidance for the prevention and treatment of the post-thrombotic syndrome. J Thromb Thrombolysis. 2016 Jan;41(1):144-53. doi: 10.1007/s11239-015-1312-5. PMID: 26780743.26780743
44 Nelson EA, Adderley U. Venous leg ulcers. BMJ Clin Evid. 2016;2016. PMID: 26771825.26771825
45 Berntsen CF, Kristiansen A, Akl EA, . Compression Stockings for Preventing the Postthrombotic Syndrome in Patients with Deep Vein Thrombosis. Am J Med. 2016 Apr;129(4):447.e1-.e20. doi: 10.1016/j.amjmed.2015.11.031. PMID: 26747198.26747198
46 Cohen AT, Hamilton M, Mitchell SA, . Comparison of the Novel Oral Anticoagulants Apixaban, Dabigatran, Edoxaban, and Rivaroxaban in the Initial and Long-Term Treatment and Prevention of Venous Thromboembolism: Systematic Review and Network Meta-Analysis. PLoS One. 2015;10(12):e0144856. doi: 10.1371/journal.pone.0144856. PMID: 26716830.26716830
47 Martinez-Zapata MJ, Vernooij RW, Uriona Tuma SM, . Phlebotonics for venous insufficiency. Cochrane Database of Systematic Reviews. 2016;2016(4).
48 Abdalla G, Fawzi Matuk R, Venugopal V, . The diagnostic accuracy of magnetic resonance venography in the detection of deep venous thrombosis: A systematic review and meta-analysis. Clin Radiol. 2015;70(8):858-71.26091753
49 Ratliff CR, Yates S, McNichol L, . Compression for Primary Prevention, Treatment, and Prevention of Recurrence of Venous Leg Ulcers: An Evidence-and Consensus-Based Algorithm for Care Across the Continuum. J Wound Ostomy Continence Nurs. 2016 Jul-Aug;43(4):347-64. doi: 10.1097/won.0000000000000242. PMID: 27163774.27163774
50 Bolton LL, Girolami S, Corbett L, . The Association for the Advancement of Wound Care (AAWC) venous and pressure ulcer guidelines. Ostomy Wound Manage. 2014 Nov;60(11):24-66. PMID: 25380098.25380098
51 Tang JC, Marston WA, Kirsner RS. Wound Healing Society (WHS) venous ulcer treatment guidelines: what’s new in five years? Wound Repair Regen. 2012 Sep Oct;20(5):619-37. doi: 10.1111/j.1524475X.2012.00815.x. PMID: 22805581.22805581
52 Higgins JPT, Green S. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0 [updated March 2011]. Available from www.cochranehandbook.org: The Cochrane Collaboration; 2011.
53 Wells GA, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa, Canada. Ottawa Hospital Research Institute. Available at www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed May 25, 2016.
54 Santaguida PL, Riley CM, Matchar DB. Chapter 5: Assessing Risk of Bias as a Domain of Quality in Medical Test Studies. J Gen Intern Med. 2012;27(1):33-8. doi: 10.1007/s11606-012-2030-8.
55 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529-36. doi: 10.7326/0003-4819155-8-201110180-00009. PMID: 22007046.22007046
56 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 2902007-10056-I). AHRQ Publication No. 13(14)-EHC130-EF. Rockville, MD: Agency for Healthcare Research and Quality. November 2013. https://www.effectivehealthcare.ahrq.gov/ehc/products/457/1752/methods-guidancegrading-evidence-131118.pdf. Accessed April 7, 2016.
57 Owens DK, Lohr KN, Atkins D, . AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2010 May;63(5):513-23. PMID: 19595577.19595577
58 Myers ER, Moorman P, Gierisch JM, . Benefits and harms of breast cancer screening: a systematic review. JAMA. 2015;314(15):1615-34. PMID: 26501537.26501537
59 Atkins D, Chang SM, Gartlehner G, . Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011 Nov;64(11):1198-207. PMID: 21463926.21463926
60 Hamilton Health Sciences Corporation. Graduated Compression Stockings (GCS) Pilot Substudy. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 June 14]. https://clinicaltrials.gov/show/NCT01234064. NLM Identifier: NCT01234064.
61 VA Office of Research and Development. Physical Conditioning in Management of Chronic Venous Insufficiency. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 June 14]. https://clinicaltrials.gov/show/NCT00013273. NLM Identifier: NCT00013273.
62 Medical University of Vienna. Surgery Versus Sclerotherapy for Isolated Accessory Great Saphenous Vein Varicosis. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 June 14]. https://clinicaltrials.gov/show/NCT02010723. NLM Identifier: NCT02010723.
63 CoDa Therapeutics Inc. A Trial to Assess the Safety and Activity of Nexagon® for the Treatment of Venous Leg Ulcers (The NOVEL Study). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 June 14]. https://clinicaltrials.gov/show/NCT00820196. NLM Identifier: NCT00820196.
64 Serena T, Bannan S, Data J, . Acceleration of venous ulcer healing using a topical connexin43 antisense compound: Phase 2 results. Wound Repair Regen. 2011;19(2):A50.
65 Antoch G, Pourhassan S, Hansen O, . Comparison of colour Doppler ultrasonography, ascending phlebography and clinical examination in the diagnosis of incompetent calf perforating veins. Br J Surg. 2002 Feb;89(2):192-3. doi: 10.1046/j.0007-1323.2001.02003.x. PMID: 11856132.11856132
66 Depalma RG, Kowallek DL, Barcia TC, . Target selection for surgical intervention in severe chronic venous insufficiency: comparison of duplex scanning and phlebography. J Vasc Surg. 2000 Nov;32(5):913-20. doi: 10.1067/mva.2000.110347. PMID: 11054223.11054223
67 Lee W, Chung JW, Yin YH, . Threedimensional CT venography of varicose veins of the lower extremity: image quality and comparison with doppler sonography. AJR Am J Roentgenol. 2008 Oct;191(4):1186-91. doi: 10.2214/ajr.07.3471. PMID: 18806163.18806163
68 Mantoni M, Larsen L, Lund JO, . Evaluation of chronic venous disease in the lower limbs: comparison of five diagnostic methods. Br J Radiol. 2002 Jul;75(895):578-83. doi: 10.1259/bjr.75.895.750578. PMID: 12145130.12145130
69 Massenburg BB, Himel HN, Blue RC, . Magnetic resonance imaging in proximal venous outflow obstruction. Ann Vasc Surg. 2015 Nov;29(8):1619-24. doi: 10.1016/j.avsg.2015.06.083. PMID: 26315799.26315799
70 Meyer T, Cavallaro A, Lang W. Duplex ultrasonography in the diagnosis of incompetent Cockett veins. Eur J Ultrasound. 2000 Jun;11(3):175-80. PMID: 10874192.10874192
71 Rabahie GN, Waisberg DR, Martins LC, . Comparative study among the physical examination, echo-color Doppler mapping and operative approaching in the recurrent lower extremity varicose veins from the saphenofemoral junction. Jornal Vascular Brasileiro. 2011;10(3):198-204.
72 Mousa AY, Broce M, Yacoub M, . Validation of venous duplex ultrasound imaging in determining iliac vein stenosis after standard treatment of active chronic venous ulcers. J Vasc Surg Venous Lymphat Disord. 2016 Jul;4(3):307-12. doi: 10.1016/j.jvsv.2016.02.002. PMID: 27318050.27318050
73 Kurstjens RL, de Wolf MA, Alsadah SA, . The value of hemodynamic measurements by air plethysmography in diagnosing venous obstruction of the lower limb. J Vasc Surg Venous Lymphat Disord. 2016 Jul;4(3):313-9. doi: 10.1016/j.jvsv.2016.01.005. PMID: 27318051.27318051
74 Kayilioglu SI, Koksoy C, Alacayir I. Diagnostic value of the femoral vein flow pattern for the detection of an iliocaval venous obstruction. J Vasc Surg Venous Lymphat Disord. 2016 Jan;4(1):2-8. doi: 10.1016/j.jvsv.2015.08.002. PMID: 26946889.26946889
75 Gloviczki P, Comerota AJ, Dalsing MC, . The care of patients with varicose veins and associated chronic venous diseases: clinical practice guidelines of the Society for Vascular Surgery and the American Venous Forum. J Vasc Surg. 2011 May;53(5 Suppl):2s-48s. doi: 10.1016/j.jvs.2011.01.079. PMID: 21536172.21536172
76 American College of Phlebology. Treatment of Superficial Venous Disease of the Lower Leg. Practice Guidelines: Superficial Venous Disease rev020316. Available at: http://www.phlebology.org/wpcontent/uploads/2016/02/SuperficialVenousDiseaseGuidelinesPMS313-02.03.16.pdf. Accessed May 31, 2016.
77 O’Donnell TF, Jr., Passman MA. Clinical practice guidelines of the Society for Vascular Surgery (SVS) and the American Venous Forum (AVF)--Management of venous leg ulcers. Introduction. J Vasc Surg. 2014 Aug;60(2 Suppl):1s-2s. doi: 10.1016/j.jvs.2014.04.058. PMID: 25064456.25064456
78 National Institute for Health and Care Excellence (NICE). Varicose veins: diagnosis and management. NICE Clinical Guideline 168. Published 24 July 2013. Available at: www.nice.org.uk/guidance/cg168. Accessed May 31, 2016.
79 Khilnani NM. Duplex ultrasound evaluation of patients with chronic venous disease of the lower extremities. American Journal of Roentgenology. 2014 2014/03/01;202(3):633-42. doi: 10.2214/AJR.13.11465.24555602
80 Volcano Corporation. Venogram vs. intravascular ultrasound (IVUS) for diagnosing iliac vein obstruction (VIDIO). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000 [cited 2016 May 31]. https://clinicaltrials.gov/ct2/show/NCT02142062. NLM Identifier: NCT02142062.
81 Kalodiki E, Lattimer CR, Azzam M, . Long-term results of a randomized controlled trial on ultrasound-guided foam sclerotherapy combined with saphenofemoral ligation vs standard surgery for varicose veins. J Vasc Surg. 2012 Feb;55(2):451-7. doi: 10.1016/j.jvs.2011.08.040. PMID: 22104345.22104345
82 Bountouroglou DG, Azzam M, Kakkos SK, . Ultrasound-guided foam sclerotherapy combined with sapheno-femoral ligation compared to surgical treatment of varicose veins: early results of a randomised controlled trial. Eur J Vasc Endovasc Surg. 2006 Jan;31(1):93-100. doi: 10.1016/j.ejvs.2005.08.024. PMID: 16233981.16233981
83 Kalteis M, Adelsgruber P, Messie-Werndl S, . Five-year results of a randomized controlled trial comparing high ligation combined with endovenous laser ablation and stripping of the great saphenous vein. Dermatol Surg. 2015 May;41(5):579-86. doi: 10.1097/dss.0000000000000369. PMID: 25899888.25899888
84 Kalteis M, Berger I, Messie-Werndl S, . High ligation combined with stripping and endovenous laser ablation of the great saphenous vein: early results of a randomized controlled study. J Vasc Surg. 2008 Apr;47(4):822-9; discussion 9. doi: 10.1016/j.jvs.2007.10.060. PMID: 18295441.18295441
85 Rasmussen L, Lawaetz M, Bjoern L, . Randomized clinical trial comparing endovenous laser ablation and stripping of the great saphenous vein with clinical and duplex outcome after 5 years. J Vasc Surg. 2013 Aug;58(2):421-6. doi: 10.1016/j.jvs.2012.12.048. PMID: 23768792.23768792
86 Rasmussen LH, Bjoern L, Lawaetz M, . Randomised clinical trial comparing endovenous laser ablation with stripping of the great saphenous vein: clinical outcome and recurrence after 2 years. Eur J Vasc Endovasc Surg. 2010 May;39(5):630-5. doi: 10.1016/j.ejvs.2009.11.040. PMID: 20064730.20064730
87 Rasmussen LH, Bjoern L, Lawaetz M, . Randomized trial comparing endovenous laser ablation of the great saphenous vein with high ligation and stripping in patients with varicose veins: short-term results. J Vasc Surg. 2007 Aug;46(2):308-15. doi: 10.1016/j.jvs.2007.03.053. PMID: 17600655.17600655
88 Brittenden J, Cotton SC, Elders A, . Clinical effectiveness and cost-effectiveness of foam sclerotherapy, endovenous laser ablation and surgery for varicose veins: results from the Comparison of LAser, Surgery and foam Sclerotherapy (CLASS) randomised controlled trial. Health Technol Assess. 2015 Apr;19(27):1-342. doi: 10.3310/hta19270. PMID: 25858333.25858333
89 Brittenden J, Cotton SC, Elders A, . A randomized trial comparing treatments for varicose veins. N Engl J Med. 2014 Sep 25;371(13):1218-27. doi: 10.1056/NEJMoa1400781. PMID: 25251616.25251616
90 Perala J, Rautio T, Biancari F, . Radiofrequency endovenous obliteration versus stripping of the long saphenous vein in the management of primary varicose veins: 3-year outcome of a randomized study. Ann Vasc Surg. 2005 Sep;19(5):669-72. doi: 10.1007/s10016-005-6613-2. PMID: 16052388.16052388
91 Rautio T, Ohinmaa A, Perala J, . Endovenous obliteration versus conventional stripping operation in the treatment of primary varicose veins: a randomized controlled trial with comparison of the costs. J Vasc Surg. 2002 May;35(5):958-65. PMID: 12021712.12021712
92 Disselhoff BC, der Kinderen DJ, Kelder JC, . Five-year results of a randomized clinical trial comparing endovenous laser ablation with cryostripping for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1107-11. doi: 10.1002/bjs.7542. PMID: 21633948.21633948
93 Disselhoff BC, Buskens E, Kelder JC, . Randomised comparison of costs and costeffectiveness of cryostripping and endovenous laser ablation for varicose veins: 2-year results. Eur J Vasc Endovasc Surg. 2009 Mar;37(3):357-63. doi: 10.1016/j.ejvs.2008.11.013. PMID: 19111485.19111485
94 Disselhoff BC, der Kinderen DJ, Kelder JC, . Randomized clinical trial comparing endovenous laser with cryostripping for great saphenous varicose veins. Br J Surg. 2008 Oct;95(10):1232-8. doi: 10.1002/bjs.6351. PMID: 18763255.18763255
95 Lurie F, Creton D, Eklof B, . Reprinted article “Prospective randomised study of endovenous radiofrequency obliteration (closure) versus ligation and vein stripping (EVOLVeS): two-year follow-up”. Eur J Vasc Endovasc Surg. 2011 Sep;42 Suppl 1:S107-13. doi: 10.1016/j.ejvs.2011.06.019. PMID: 21855011.21855011
96 Lurie F, Creton D, Eklof B, . Prospective randomised study of endovenous radiofrequency obliteration (closure) versus ligation and vein stripping (EVOLVeS): two-year follow-up. Eur J Vasc Endovasc Surg. 2005 Jan;29(1):67-73. doi: 10.1016/j.ejvs.2004.09.019. PMID: 15570274.15570274
97 Lurie F, Creton D, Eklof B, . Prospective randomized study of endovenous radiofrequency obliteration (closure procedure) versus ligation and stripping in a selected patient population (EVOLVeS Study). J Vasc Surg. 2003 Aug;38(2):207-14. PMID: 12891099.12891099
98 Rasmussen LH, Lawaetz M, Bjoern L, . Randomized clinical trial comparing endovenous laser ablation, radiofrequency ablation, foam sclerotherapy and surgical stripping for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1079-87. doi: 10.1002/bjs.7555. PMID: 21725957.21725957
99 Rasmussen L, Lawaetz M, Serup J, . Randomized clinical trial comparing endovenous laser ablation, radiofrequency ablation, foam sclerotherapy, and surgical stripping for great saphenous varicose veins with 3-year follow-up. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(4):349-56.26992754
100 Gauw SA, Lawson JA, van Vlijmen-van Keulen CJ, . Five-year follow-up of a randomized, controlled trial comparing saphenofemoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anesthesia. J Vasc Surg. 2016 Oct 22;63(2):420-8. doi: 10.1016/j.jvs.2015.08.084. PMID: 26602795.26602795
101 Pronk P, Gauw SA, Mooij MC, . Randomised controlled trial comparing sapheno-femoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anaesthesia: one year results. Eur J Vasc Endovasc Surg. 2010 Nov;40(5):649-56. doi: 10.1016/j.ejvs.2010.08.007. PMID: 20888274.20888274
102 Carradice D, Mekako AI, Mazari FA, . Clinical and technical outcomes from a randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1117-23. doi: 10.1002/bjs.7615. PMID: 21638277.21638277
103 Carradice D, Mekako AI, Mazari FA, . Randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg. 2011 Apr;98(4):501-10. doi: 10.1002/bjs.7394. PMID: 21283981.21283981
104 Nandhra S, El-sheikha J, Carradice D, . A randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. J Vasc Surg. 2015 Mar;61(3):741-6. doi: 10.1016/j.jvs.2014.09.037. PMID: 25720930.25720930
105 Samuel N, Carradice D, Wallace T, . Randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. Ann Surg. 2013 Mar;257(3):419-26. doi: 10.1097/SLA.0b013e318275f4e4. PMID: 23160149.23160149
106 Belcaro G, Cesarone M, Di Renzo A, . Treatments for varicose veins: Surgery, sclerotherapy, foamsclerotherapy and combined (surgery+sclerotherapy) options. A 10-year, prospective, randomised, controlled, follow-up study. The VEDICO* trial and EST (European Sclerotherapy Trial). Angeiologie. 2003;55(1):29-36.
107 Belcaro G, Cesarone MR, Di Renzo A, . Foam-sclerotherapy, surgery, sclerotherapy, and combined treatment for varicose veins: a 10-year, prospective, randomized, controlled, trial (VEDICO trial). Angiology. 2003 May-Jun;54(3):307-15. PMID: 12785023.12785023
108 Gohel MS, Barwell JR, Taylor M, . Long term results of compression therapy alone versus compression plus surgery in chronic venous ulceration (ESCHAR): randomised controlled trial. BMJ. 2007 Jul 14;335(7610):83. doi: 10.1136/bmj.39216.542442.BE. PMID: 17545185.17545185
109 Gohel MS, Barwell JR, Earnshaw JJ, . Randomized clinical trial of compression plus surgery versus compression alone in chronic venous ulceration (ESCHAR study)-haemodynamic and anatomical changes. Br J Surg. 2005 Mar;92(3):291-7. doi: 10.1002/bjs.4837. PMID: 15584055.15584055
110 Gohel MS, Barwell JR, Wakely C, . The influence of superficial venous surgery and compression on incompetent calf perforators in chronic venous leg ulceration. Eur J Vasc Endovasc Surg. 2005 Jan;29(1):78-82. doi: 10.1016/j.ejvs.2004.09.016. PMID: 15570276.15570276
111 Barwell JR, Davies CE, Deacon J, . Comparison of surgery and compression with compression alone in chronic venous ulceration (ESCHAR study): randomised controlled trial. Lancet. 2004 Jun 5;363(9424):1854-9. doi: 10.1016/s01406736(04)16353-8. PMID: 15183623.15183623
112 van Gent WB, Catarinella FS, Lam YL, . Conservative versus surgical treatment of venous leg ulcers: 10-year follow up of a randomized, multicenter trial. Phlebology. 2015 Mar;30(1 Suppl):35-41. doi: 10.1177/0268355514568848. PMID: 25729066.25729066
113 van Gent WB, Hop WC, van Praag MC, . Conservative versus surgical treatment of venous leg ulcers: a prospective, randomized, multicenter trial. J Vasc Surg. 2006 Sep;44(3):563-71. doi: 10.1016/j.jvs.2006.04.053. PMID: 16950434.16950434
114 Lattimer CR, Kalodiki E, Azzam M, . Interim results on abolishing reflux alongside a randomized clinical trial on laser ablation with phlebectomies versus foam sclerotherapy. Int Angiol. 2013 Aug;32(4):394-403. PMID: 23822942.23822942
115 Lattimer CR, Azzam M, Kalodiki E, . Cost and effectiveness of laser with phlebectomies compared with foam sclerotherapy in superficial venous insufficiency. Early results of a randomised controlled trial. Eur J Vasc Endovasc Surg. 2012 May;43(5):594-600. doi: 10.1016/j.ejvs.2012.01.032. PMID: 22386383.22386383
116 van der Velden SK, Biemans AA, De Maeseneer MG, . Five-year results of a randomized clinical trial of conventional surgery, endovenous laser ablation and ultrasound-guided foam sclerotherapy in patients with great saphenous varicose veins. Br J Surg. 2015 Sep;102(10):1184-94. doi: 10.1002/bjs.9867. PMID: 26132315.26132315
117 Biemans AA, Kockaert M, Akkersdijk GP, . Comparing endovenous laser ablation, foam sclerotherapy, and conventional surgery for great saphenous varicose veins. J Vasc Surg. 2013 Sep;58(3):727-34.e1. doi: 10.1016/j.jvs.2012.12.074. PMID: 23769603.23769603
118 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 1]. Health Technol Assess. 2006 Apr;10(13):1-196, iii-iv. PMID: 16707070.16707070
119 Michaels JA, Brazier JE, Campbell WB, . Randomized clinical trial comparing surgery with conservative treatment for uncomplicated varicose veins. Br J Surg. 2006 Feb;93(2):175-81. doi: 10.1002/bjs.5264. PMID: 16432825.16432825
120 Flessenkamper I, Hartmann M, Hartmann K, . Endovenous laser ablation with and without high ligation compared to high ligation and stripping for treatment of great saphenous varicose veins: Results of a multicentre randomised controlled trial with up to 6 years follow-up. Phlebology. 2016 Oct 22;31(1):23-33. doi: 10.1177/0268355514555547. PMID: 25342648.25342648
121 Flessenkamper I, Hartmann M, Stenger D, . Endovenous laser ablation with and without high ligation compared with high ligation and stripping in the treatment of great saphenous varicose veins: initial results of a multicentre randomized controlled trial. Phlebology. 2013 Feb;28(1):16-23. doi: 10.1258/phleb.2011.011147. PMID: 22451455.22451455
122 Shepherd AC, Ortega-Ortega M, Gohel MS, . COST-EFFECTIVENESS OF RADIOFREQUENCY ABLATION VERSUS LASER FOR VARICOSE VEINS. Int J Technol Assess Health Care. 2015 Jan;31(5):289-96. doi: 10.1017/s0266462315000537. PMID: 26715372.26715372
123 Shepherd AC, Gohel MS, Brown LC, . Randomized clinical trial of VNUS ClosureFAST radiofrequency ablation versus laser for varicose veins. Br J Surg. 2010 Jun;97(6):810-8. doi: 10.1002/bjs.7091. PMID: 20473992.20473992
124 King JT, O’Byrne M, Vasquez M, . Treatment of Truncal Incompetence and Varicose Veins with a Single Administration of a New Polidocanol Endovenous Microfoam Preparation Improves Symptoms and Appearance. Eur J Vasc Endovasc Surg. 2015 Dec;50(6):784-93. doi: 10.1016/j.ejvs.2015.06.111. PMID: 26384639.26384639
125 Obi AT, Reames BN, Rook TJ, . Outcomes associated with ablation compared to combined ablation and transilluminated powered phlebectomy in the treatment of venous varicosities. Phlebology. 2015 Sep 15doi: 10.1177/0268355515604257. PMID: 26376824.26376824
126 Rass K, Frings N, Glowacki P, . Same Site Recurrence is More Frequent After Endovenous Laser Ablation Compared with High Ligation and Stripping of the Great Saphenous Vein: 5 year Results of a Randomized Clinical Trial (RELACS Study). Eur J Vasc Endovasc Surg. 2015 Nov;50(5):648-56. doi: 10.1016/j.ejvs.2015.07.020. PMID: 26319476.26319476
127 Campos W, Jr., Torres IO, da Silva ES, . A prospective randomized study comparing polidocanol foam sclerotherapy with surgical treatment of patients with primary chronic venous insufficiency and ulcer. Ann Vasc Surg. 2015 Aug;29(6):1128-35. doi: 10.1016/j.avsg.2015.01.031. PMID: 26004968.26004968
128 Wozniak W, Mlosek RK, Ciostek P. Assessment of the efficacy and safety of steam vein sclerosis as compared to classic surgery in lower extremity varicose vein management. Wideochir Inne Tech Maloinwazyjne. 2015 Apr;10(1):15-24. doi: 10.5114/wiitm.2015.48573. PMID: 25960788.25960788
129 Morrison N, Gibson K, McEnroe S, . Randomized trial comparing cyanoacrylate embolization and radiofrequency ablation for incompetent great saphenous veins (VeClose). J Vasc Surg. 2015 Apr;61(4):985-94. doi: 10.1016/j.jvs.2014.11.071. PMID: 25650040.25650040
130 Al Shammeri O, AlHamdan N, Al-Hothaly B, . Chronic Venous Insufficiency: prevalence and effect of compression stockings. Int J Health Sci (Qassim). 2014 Jul;8(3):231-6. PMID: 25505858.25505858
131 Carruthers TN, Farber A, Rybin D, . Interventions on the superficial venous system for chronic venous insufficiency by surgeons in the modern era: an analysis of ACS-NSQIP. Vasc Endovascular Surg. 2014 Oct-Nov;48(7-8):482-90. doi: 10.1177/1538574414561226. PMID: 25487248.25487248
132 Bootun R, Lane T, Dharmarajah B, . Intra-procedural pain score in a randomised controlled trial comparing mechanochemical ablation to radiofrequency ablation: The Multicentre Venefit versus ClariVein(R) for varicose veins trial. Phlebology. 2016;31(1):61-5. doi: 10.1177/0268355514551085. PMID: 25193822.25193822
133 Lane T, Bootun R, Dharmarajah B, . A multi-centre randomised controlled trial comparing radiofrequency and mechanical occlusion chemically assisted ablation of varicose veins - Final results of the Venefit versus Clarivein for varicose veins trial. Phlebology. 2016 May 24doi: 10.1177/0268355516651026. PMID: 27221810.27221810
134 van den Bos RR, Malskat WS, De Maeseneer MG, . Randomized clinical trial of endovenous laser ablation versus steam ablation (LAST trial) for great saphenous varicose veins. Br J Surg. 2014 Aug;101(9):1077-83. doi: 10.1002/bjs.9580. PMID: 24981585.24981585
135 Aguilar-Ferrandiz ME, Moreno-Lorenzo C, Mataran-Penarrocha GA, . Effect of a mixed kinesio taping-compression technique on quality of life and clinical and gait parameters in postmenopausal women with chronic venous insufficiency: doubleblinded, randomized controlled trial. Arch Phys Med Rehabil. 2014 Jul;95(7):1229-39. doi: 10.1016/j.apmr.2014.03.024. PMID: 24732169.24732169
136 Sell H, Vikatmaa P, Alback A, . Compression therapy versus surgery in the treatment of patients with varicose veins: A RCT. Eur J Vasc Endovasc Surg. 2014 Jun;47(6):670-7. doi: 10.1016/j.ejvs.2014.02.015. PMID: 24675145.24675145
137 Carpentier PH, Blaise S, Satger B, . A multicenter randomized controlled trial evaluating balneotherapy in patients with advanced chronic venous insufficiency. J Vasc Surg. 2014 Feb;59(2):447-54.e1. doi: 10.1016/j.jvs.2013.08.002. PMID: 24135621.24135621
138 Moreno-Moraga J, Smarandache A, Pascu ML, . 1064 nm Nd:YAG long pulse laser after polidocanol microfoam injection dramatically improves the result of leg vein treatment: a randomized controlled trial on 517 legs with a three-year follow-up. Phlebology. 2014 Dec;29(10):658-66. doi: 10.1177/0268355513502786. PMID: 23989971.23989971
139 Mozafar M, Atqiaee K, Haghighatkhah H, . Endovenous laser ablation of the great saphenous vein versus high ligation: longterm results. Lasers Med Sci. 2014 Mar;29(2):765-71. doi: 10.1007/s10103013-1389-z. PMID: 23942818.23942818
140 Yang L, Wang XP, Su WJ, . Randomized clinical trial of endovenous microwave ablation combined with high ligation versus conventional surgery for varicose veins. Eur J Vasc Endovasc Surg. 2013 Oct;46(4):473-9. doi: 10.1016/j.ejvs.2013.07.004. PMID: 23911734.23911734
141 Todd KL, 3rd, Wright DI. The VANISH-2 study: a randomized, blinded, multicenter study to evaluate the efficacy and safety of polidocanol endovenous microfoam 0.5% and 1.0% compared with placebo for the treatment of saphenofemoral junction incompetence. Phlebology. 2014 Oct;29(9):608-18. doi: 10.1177/0268355513497709. PMID: 23864535.23864535
142 Aguilar-Ferrandiz ME, Castro-Sanchez AM, Mataran-Penarrocha GA, . Effects of kinesio taping on venous symptoms, bioelectrical activity of the gastrocnemius muscle, range of ankle motion, and quality of life in postmenopausal women with chronic venous insufficiency: a randomized controlled trial. Arch Phys Med Rehabil. 2013 Dec;94(12):2315-28. doi: 10.1016/j.apmr.2013.05.016. PMID: 23769763.23769763
143 Serra R, Buffone G, Molinari V, . Low molecular weight heparin improves healing of chronic venous ulcers especially in the elderly. Int Wound J. 2015 Apr;12(2):150-3. doi: 10.1111/iwj.12071. PMID: 23517508.23517508
144 Aguilar-Ferrandiz ME, Castro-Sanchez AM, Mataran-Penarrocha GA, . A randomized controlled trial of a mixed Kinesio taping-compression technique on venous symptoms, pain, peripheral venous flow, clinical severity and overall health status in postmenopausal women with chronic venous insufficiency. Clin Rehabil. 2014 Jan;28(1):69-81. doi: 10.1177/0269215512469120. PMID: 23426563.23426563
145 Liu P, Ren S, Yang Y, . Intravenous catheter-guided laser ablation: a novel alternative for branch varicose veins. Int Surg. 2011 Oct-Dec;96(4):331-6. PMID: 22808616.22808616
146 Shadid N, Ceulen R, Nelemans P, . Randomized clinical trial of ultrasoundguided foam sclerotherapy versus surgery for the incompetent great saphenous vein. Br J Surg. 2012 Aug;99(8):1062-70. doi: 10.1002/bjs.8781. PMID: 22627969.22627969
147 del Rio Sola ML, Antonio J, Fajardo G, . Influence of aspirin therapy in the ulcer associated with chronic venous insufficiency. Ann Vasc Surg. 2012 Jul;26(5):620-9. doi: 10.1016/j.avsg.2011.02.051. PMID: 22437068.22437068
148 Wong IK, Andriessen A, Charles HE, . Randomized controlled trial comparing treatment outcome of two compression bandaging systems and standard care without compression in patients with venous leg ulcers. J Eur Acad Dermatol Venereol. 2012 Jan;26(1):102-10. doi: 10.1111/j.14683083.2011.04327.x. PMID: 22077933.22077933
149 Nordon IM, Hinchliffe RJ, Brar R, . A prospective double-blind randomized controlled trial of radiofrequency versus laser treatment of the great saphenous vein in patients with varicose veins. Ann Surg. 2011 Dec;254(6):876-81. doi: 10.1097/SLA.0b013e318230af5a. PMID: 21934487.21934487
150 Rass K, Frings N, Glowacki P, . Comparable effectiveness of endovenous laser ablation and high ligation with stripping of the great saphenous vein: twoyear results of a randomized clinical trial (RELACS study). Arch Dermatol. 2012 Jan;148(1):49-58. doi: 10.1001/archdermatol.2011.272. PMID: 21931012.21931012
151 Liu X, Jia X, Guo W, . Ultrasoundguided foam sclerotherapy of the great saphenous vein with sapheno-femoral ligation compared to standard stripping: a prospective clinical study. Int Angiol. 2011 Aug;30(4):321-6. PMID: 21747350.21747350
152 Christenson JT, Gueddi S, Gemayel G, . Prospective randomized trial comparing endovenous laser ablation and surgery for treatment of primary great saphenous varicose veins with a 2-year follow-up. J Vasc Surg. 2010 Nov;52(5):1234-41. doi: 10.1016/j.jvs.2010.06.104. PMID: 20801608.20801608
153 Helmy ElKaffas K, ElKashef O, ElBaz W. Great saphenous vein radiofrequency ablation versus standard stripping in the management of primary varicose veins-a randomized clinical trial. Angiology. 2011 Jan;62(1):49-54. doi: 10.1177/0003319710380680. PMID: 20724299.20724299
154 Gale SS, Lee JN, Walsh ME, . A randomized, controlled trial of endovenous thermal ablation using the 810-nm wavelength laser and the ClosurePLUS radiofrequency ablation methods for superficial venous insufficiency of the great saphenous vein. J Vasc Surg. 2010 Sep;52(3):645-50. doi: 10.1016/j.jvs.2010.04.030. PMID: 20638231.20638231
155 Goode SD, Chowdhury A, Crockett M, . Laser and radiofrequency ablation study (LARA study): a randomised study comparing radiofrequency ablation and endovenous laser ablation (810 nm). Eur J Vasc Endovasc Surg. 2010 Aug;40(2):246-53. doi: 10.1016/j.ejvs.2010.02.026. PMID: 20537570.20537570
156 Pares JO, Juan J, Tellez R, . Varicose vein surgery: stripping versus the CHIVA method: a randomized controlled trial. Ann Surg. 2010 Apr;251(4):624-31. doi: 10.1097/SLA.0b013e3181d0d0a3. PMID: 20224376.20224376
157 Hamel-Desnos CM, Guias BJ, Desnos PR, . Foam sclerotherapy of the saphenous veins: randomised controlled trial with or without compression. Eur J Vasc Endovasc Surg. 2010 Apr;39(4):500-7. doi: 10.1016/j.ejvs.2009.11.027. PMID: 20097585.20097585
158 Jull A, Parag V, Walker N, . The prepare pilot RCT of home-based progressive resistance exercises for venous leg ulcers. J Wound Care. 2009 Dec;18(12):497-503. doi: 10.12968/jowc.2009.18.12.45606. PMID: 20081574.20081574
159 Subramonia S, Lees T. Randomized clinical trial of radiofrequency ablation or conventional high ligation and stripping for great saphenous varicose veins. Br J Surg. 2010 Mar;97(3):328-36. doi: 10.1002/bjs.6867. PMID: 20035541.20035541
160 O’Hare JL, Earnshaw JJ. Randomised clinical trial of foam sclerotherapy for patients with a venous leg ulcer. Eur J Vasc Endovasc Surg. 2010 Apr;39(4):495-9. doi: 10.1016/j.ejvs.2009.11.025. PMID: 20006528.20006528
161 Figueiredo M, Araujo S, Barros N, Jr., . Results of surgical treatment compared with ultrasound-guided foam sclerotherapy in patients with varicose veins: a prospective randomised study. Eur J Vasc Endovasc Surg. 2009 Dec;38(6):758-63. doi: 10.1016/j.ejvs.2009.07.015. PMID: 19744867.19744867
162 Houtermans-Auckel JP, van Rossum E, Teijink JA, . To wear or not to wear compression stockings after varicose vein stripping: a randomised controlled trial. Eur J Vasc Endovasc Surg. 2009 Sep;38(3):387-91. doi: 10.1016/j.ejvs.2009.05.025. PMID: 19608438.19608438
163 Almeida JI, Kaufman J, Gockeritz O, . Radiofrequency endovenous ClosureFAST versus laser ablation for the treatment of great saphenous reflux: a multicenter, single-blinded, randomized study (RECOVERY study). J Vasc Interv Radiol. 2009 Jun;20(6):752-9. doi: 10.1016/j.jvir.2009.03.008. PMID: 19395275.19395275
164 Carradice D, Mekako AI, Hatfield J, . Randomized clinical trial of concomitant or sequential phlebectomy after endovenous laser therapy for varicose veins. Br J Surg. 2009 Apr;96(4):369-75. doi: 10.1002/bjs.6556. PMID: 19283745.19283745
165 Klem TM, Schnater JM, Schutte PR, . A randomized trial of cryo stripping versus conventional stripping of the great saphenous vein. J Vasc Surg. 2009 Feb;49(2):403-9. doi: 10.1016/j.jvs.2008.09.016. PMID: 19028042.19028042
166 Abela R, Liamis A, Prionidis I, . Reverse foam sclerotherapy of the great saphenous vein with sapheno-femoral ligation compared to standard and invagination stripping: a prospective clinical series. Eur J Vasc Endovasc Surg. 2008 Oct;36(4):485-90. doi: 10.1016/j.ejvs.2008.06.029. PMID: 18718769.18718769
167 Theivacumar NS, Dellagrammaticas D, Mavor AI, . Endovenous laser ablation: does standard above-knee great saphenous vein ablation provide optimum results in patients with both above- and below-knee reflux? A randomized controlled trial. J Vasc Surg. 2008 Jul;48(1):173-8. doi: 10.1016/j.jvs.2008.01.062. PMID: 18440756.18440756
168 Darwood RJ, Theivacumar N, Dellagrammaticas D, . Randomized clinical trial comparing endovenous laser ablation with surgery for the treatment of primary great saphenous varicose veins. Br J Surg. 2008 Mar;95(3):294-301. doi: 10.1002/bjs.6101. PMID: 18278775.18278775
169 Menyhei G, Gyevnar Z, Arato E, . Conventional stripping versus cryostripping: a prospective randomised trial to compare improvement in quality of life and complications. Eur J Vasc Endovasc Surg. 2008 Feb;35(2):218-23. doi: 10.1016/j.ejvs.2007.08.017. PMID: 17964821.17964821
170 Viarengo LM, Poterio-Filho J, Poterio GM, . Endovenous laser treatment for varicose veins in patients with active ulcers: measurement of intravenous and perivenous temperatures during the procedure. Dermatol Surg. 2007 Oct;33(10):1234-42; discussion 41-2. doi: 10.1111/j.15244725.2007.33259.x. PMID: 17903157.17903157
171 Nelson EA, Prescott RJ, Harper DR, . A factorial, randomized trial of pentoxifylline or placebo, four-layer or single-layer compression, and knitted viscose or hydrocolloid dressings for venous ulcers. J Vasc Surg. 2007 Jan;45(1):134-41. doi: 10.1016/j.jvs.2006.09.043. PMID: 17210398.17210398
172 Schouten R, Mollen RM, Kuijpers HC. A comparison between cryosurgery and conventional stripping in varicose vein surgery: perioperative features and complications. Ann Vasc Surg. 2006 May;20(3):306-11. doi: 10.1007/s10016006-9051-x. PMID: 16779510.16779510
173 Clarke-Moloney M, O’Brien JF, Grace PA, . Health-related quality of life during four-layer compression bandaging for venous ulcer disease: a randomised controlled trial. Ir J Med Sci. 2005 Apr Jun;174(2):21-5. PMID: 16094908.16094908
174 Kahle B, Leng K. Efficacy of sclerotherapy in varicose veins-- prospective, blinded, placebo-controlled study. Dermatol Surg. 2004 May;30(5):723-8; discussion 8. doi: 10.1111/j.1524-4725.2004.30207.x. PMID: 15099314.15099314
175 Zamboni P, Cisno C, Marchetti F, . Minimally invasive surgical management of primary venous ulcers vs. compression treatment: a randomized clinical trial. Eur J Vasc Endovasc Surg. 2003 Apr;25(4):313-8. doi: 10.1053/ejvs.2002.1871. PMID: 12651168.12651168
176 de Roos KP, Nieman FH, Neumann HA. Ambulatory phlebectomy versus compression sclerotherapy: results of a randomized controlled trial. Dermatol Surg. 2003 Mar;29(3):221-6. PMID: 12614412.12614412
177 Vanscheidt W, Rabe E, Naser-Hijazi B, . The efficacy and safety of a coumarin/troxerutin-combination (SB-LOT) in patients with chronic venous insufficiency: a double blind placebo-controlled randomised study. Vasa. 2002 Aug;31(3):185-90. doi: 10.1024/0301-1526.31.3.185. PMID: 12236023.12236023
178 Nikolovska S, Pavlova L, Petrova N, . Pentoxifylline--efficient in the treatment of venous ulcers in the absence of compression? Acta Dermatovenerol Croat. 2002 Mar;10(1):9-13. PMID: 12137725.12137725
179 Coccheri S, Scondotto G, Agnelli G, . Randomised, double blind, multicentre, placebo controlled study of sulodexide in the treatment of venous leg ulcers. Thromb Haemost. 2002 Jun;87(6):947-52. PMID: 12083500.12083500
180 Kumar S, Samraj K, Nirujogi V, . Intermittent pneumatic compression as an adjuvant therapy in venous ulcer disease. J Tissue Viability. 2002 Apr;12(2):42-4, 6, 8 passim. PMID: 12001325.12001325
181 Belcaro G, Nicolaides AN, Ricci A, . Endovascular sclerotherapy, surgery, and surgery plus sclerotherapy in superficial venous incompetence: a randomized, 10year follow-up trial--final results. Angiology. 2000 Jul;51(7):529-34. PMID: 10917577.10917577
182 Elderman JH, Krasznai AG, Voogd AC, . Role of compression stockings after endovenous laser therapy for primary varicosis. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2014;2(3):289-96.26993388
183 De Franciscis S, Gasbarro V, Amato B, . Hemodynamic surgery versus conventional surgery in chronic venous disease: A multicenter retrospective study. Acta Phlebologica. 2013;14(3):109-14.
184 Benarroch-Gampel J, Sheffield KM, Boyd CA, . Analysis of venous thromboembolic events after saphenous ablation. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(1):26-32.26993890
185 Roopram AD, Lind MY, Van Brussel JP, . Endovenous laser ablation versus conventional surgery in the treatment of small saphenous vein incompetence. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(4):357-63.26992756
186 Basela H, Aydina C, Aya Y, . Endovenous laser ablation (EVLA) versus high ligation and striping (HL/S): Two-years follow up. Eastern Journal of Medicine. 2011;17(2):83-7.
187 Wright D, Gobin JP, Bradbury AW, . Varisolve® polidocanol microfoam compared with surgery or sclerotherapy in the management of varicose veins in the presence of trunk vein incompetence: European randomized controlled trial. Phlebology. 2006;21(4):180-90.
188 Franek A, Taradaj J, Polak A, . Efficacy of high voltage stimulation for healing of venous leg ulcers in surgically and conservatively treated patients. Phlebologie. 2006;35(3):127-33.
189 Stötter L, Schaaf I, Bockelbrink A. Comparative outcomes of radiofrequency endoluminal ablation, invagination stripping, and cryostripping in the treatment of great saphenous vein insufficiency. Phlebology. 2006;21(2):60-4.
190 Zamboni P, Cisno C, Marchetti F, . Haemodynamic CHIVA correction surgery versus compression for primary venous ulcers: First year results. Phlebology. 2004;19(1):28-34.
191 Guest M, Smith JJ, Tripuraneni G, . Randomized clinical trial of varicose vein surgery with compression versus compression alone for the treatment of venous ulceration. Phlebology. 2003;18(3):130-6.
192 Vandongen YK, Stacey MC. Graduated compression elastic stockings reduce lipodermatosclerosis and ulcer recurrence. Phlebology. 2000;15(1):33-7.
193 Gibson K, Kabnick L. A multicenter, randomized, placebo-controlled study to evaluate the efficacy and safety of Varithena(R) (polidocanol endovenous microfoam 1%) for symptomatic, visible varicose veins with saphenofemoral junction incompetence. Phlebology. 2016 Mar 24doi: 10.1177/0268355516635386. PMID: 27013511.27013511
194 Vasquez M, Gasparis AP. A multicenter, randomized, placebo-controlled trial of endovenous thermal ablation with or without polidocanol endovenous microfoam treatment in patients with great saphenous vein incompetence and visible varicosities. Phlebology. 2016 Mar 7doi: 10.1177/0268355516637300. PMID: 26957489.26957489
195 Noppeney T, Storck M, Nüllen H, . Perioperative quality assessment of varicose vein surgery: Commission for quality assessment of the German Society for Vascular Surgery. Langenbeck’s Archives of Surgery. 2016;401(3):375-80.
196 Wang H, Chen Q, Fei Z, . Hemodynamic classification and CHIVA treatment of varicose veins in lower extremities (VVLE). Int J Clin Exp Med. 2016;9(2):2465-71.
197 Rabe E, Schliephake D, Otto J, . Sclerotherapy of telangiectases and reticular veins: a double-blind, randomized, comparative clinical trial of polidocanol, sodium tetradecyl sulphate and isotonic saline (EASI study). Phlebology. 2010 Jun;25(3):124-31. doi: 10.1258/phleb.2009.009043. PMID: 20483861.20483861
198 Belcaro G, Dugall M, Corsi M. Superficial venous incompetence: Low-cost outpatient mini-surgery, sclerotherapy and combined procedure as a management plan. Costs and efficacy. A 20-year, follow-up registry. Minerva Chir. 2015 Jun 5. PMID: 26046959.26046959
199 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 2]. Health Technol Assess. 2006;10(13):1-196, iii-iv. PMID: 16707070.16707070
200 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 3]. Health Technol Assess. 2006;10(13):1-196, iii-iv.
201 Yin M, Shi H, Ye K, . Clinical Assessment of Endovascular Stenting Compared with Compression Therapy Alone in Post-thrombotic Patients with Iliofemoral Obstruction. Eur J Vasc Endovasc Surg. 2015 Jul;50(1):101-7. doi: 10.1016/j.ejvs.2015.03.029. PMID: 25920630.25920630
202 Holmes CE, Bambace NM, Lewis P, . Efficacy of a short course of complex lymphedema therapy or graduated compression stocking therapy in the treatment of post-thrombotic syndrome. Vasc Med. 2014 Feb;19(1):42-8. doi: 10.1177/1358863x14521883. PMID: 24558028.24558028
203 Garg N, Gloviczki P, Karimi KM, . Factors affecting outcome of open and hybrid reconstructions for nonmalignant obstruction of iliofemoral veins and inferior vena cava. J Vasc Surg. 2011 Feb;53(2):383-93. doi: 10.1016/j.jvs.2010.08.086. PMID: 21146346.21146346
204 Kahn SR, Shrier I, Shapiro S, . Sixmonth exercise training program to treat post-thrombotic syndrome: a randomized controlled two-centre trial. CMAJ. 2011 Jan 11;183(1):37-44. doi: 10.1503/cmaj.100248. PMID: 21098066.21098066
205 Ginsberg JS, Hirsh J, Julian J, . Prevention and treatment of postphlebitic syndrome: results of a 3-part study. Arch Intern Med. 2001 Sep 24;161(17):2105-09. PMID: 11570939.11570939
206 O’Sullivan GJ, Semba CP, Bittner CA, . Endovascular management of iliac vein compression (May-Thurner) syndrome. J Vasc Interv Radiol. 2000 JulAug;11(7):823-36. PMID: 10928517.10928517
207 Yin M, Huang X, Cui C, . The effect of stent placement for May-Thurner syndrome combined with symptomatic superficial venous reflux disease. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2015;3(2):168-72.26993835
208 Raju S, Kirk OK, Jones TL. Endovenous management of venous leg ulcers. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(2):165-72.26992338