# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
AV: Arteriovenous
AVF: American Venous Forum
AVP: ambulatory venous pressure
AVVQ: Aberdeen Varicose Vein Questionnaire
AVVSS: Aberdeen Varicose Vein Severity Score
CA: Cyanoacrylate
CCVUQ: Charing Cross Venous Ulcer Questionnaire
CEAP: Clinical, Etiologic, Anatomic, Pathophysiologic
CHIVA: Cure conservatrice et Hémodynamique de l’Insuffisance Veineuse en Ambulatoire
CI: confidence interval
CIVIQ: Chronic Venous Insufficiency Questionnaire
CIVIQ-2: Chronic Venous Insufficiency Questionnaire-2
CIVIQ-20: Chronic Venous Insufficiency Questionnaire-20
CMS: Centers for Medicare and Medicaid Services
CTV: computed tomography venography
DUS: duplex ultrasound
DVT: deep vein thrombosis
EHC: Effective Health Care
EHIT: endovascular heat-induced thrombosis
EMA: endovenous microwave ablation
EQ-5D: EuroQol 5D
EQ-5D-3L: EuroQol 5D 3L
EQ VAS: EuroQol Visual Analogue Scale
EVLA: endovenous laser ablation
EVLA ABK: endovenous laser ablation above and below the knee
EVLA AK: endovenous laser ablation above the knee
EVSA: endovenous steam ablation
GRADE: Grading of Recommendations Assessment, Development and Evaluation
GSV: great saphenous vein
HR: hazard ratio
ICTRP: International Clinical Trials Registry Platform
IQR: interquartile range
IVUS: Intravascular ultrasound
KQ(s): key question(s)
LE: lower extremity
LECVD: lower extremity chronic venous disease
MOCA: mechanochemical endogenous ablation
MRI: magnetic resonance imaging
MRV: magnetic resonance venography
MVO: maximum venous outflow
Nd:YAG: neodymium-doped yttrium aluminum garnet

NR: not reported
NS: not statistically significant
OR: odds ratio
PAD: peripheral artery disease
PE(s): pulmonary embolism(s)
PEM: polidocanol endovenous microfoam
PICOTS: populations, interventions, comparators, outcomes, timing, settings
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QUADAS-2: Quality Assessment of Diagnostic Accuracy Studies-2
RCT(s): Randomized controlled trial(s)
RFA: radiofrequency ablation
SD: standard deviation
SE: standard error
SEPS: subfascial endoscopic perforating vein surgery
SF-12: Short Form 12-item Health Survey
SF-36: Short Form 36-item Health Survey
SOE: strength of evidence
SSV: small saphenous vein
STS: Saphenous Treatment Score
SVS: Society of Vascular Surgery
TEP: technical expert panel
UK: United Kingdom
VAS: visual analog scale
VCSS: Venous Clinical Severity Score
VDS: Venous Disability Score
VEINES-QOL: Venous Insufficiency Epidemiological and Economic Study Qualityof-Life questionnaire
VRT: venous refilling time
VSDS: Venous Segmental Disease Score
VTE: chronic venous insufficiency/incompetence
VVSymQ: Varicose Veins Symptoms Questionnaire
WHO: World Health Organization