# Acknowledgments

The authors thank Megan von Isenburg, M.S.L.S., for help with the literature search and retrieval, Samantha Bowen, Ph.D., and Robyn E. Schmidt, B.A. for assistance with project coordination, and Rebecca N. Gray, D.Phil., and Liz Wing, M.A., for editorial assistance.