# Technical Expert Panel

In designing the methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

Riyaz Bashir, M.D., F.A.C.C., R.V.T.*

Temple University School of Medicine

Philadelphia, PA

Juan Diaz-Cartelle, M.D.*

Boston Scientific

Boston, MA

Michael Jaff, D.O.*

Newton-Wellesley Hospital

Newton, MA

Thom Rooke, M.D.*

Mayo Clinic College of Medicine

Rochester, MN

Cynthia Shortell, M.D.

Duke University Medical Center

Durham, NC

George Sopko, M.D, M.P.H.

National Heart, Lung, and Blood Institute (NHLBI)

Bethesda, MD

Jeff Weitz, M.D., F.R.S.C., F.R.C.P.C., F.A.C.P.*

McMaster University

Hamilton, ON

*This Technical Expert Panel member also provided review of the draft report.

## Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

John Blebea, M.D., M.B.A.

University of Oklahoma College of Medicine — Tulsa

Tulsa, OK

Akhilesh K. Sista, M.D.

New York University-Langone School of Medicine

New York, NY