# Discussion

## Key Findings and Strength of Evidence

In this comparative effectiveness review, we reviewed 136 articles representing 111 studies of diagnostic and treatment choices for patients with lower extremity chronic venous disease (LECVD). We summarize the key findings in Table 38, followed by a brief description for each KQ.

Table 38 Key Findings

Key Question | N Studies and Patients | Findings
KQ 1 Narrative Review of Diagnostic Methods and Criteria for Adult Patients with LECVD | 10 observational studies involving 769 patients | - Very few comparative studies of diagnostic testing methods for LECVD in the recent literature, with the majority of the comparative studies of diagnostic testing methods for LECVD published prior to 2000 (and therefore not included in this review).; - Extreme heterogeneity of patients, comparisons, and outcomes reported in the included diagnostic studies.; - Insufficient evidence for any specific diagnostic test method for any of the outcomes studied.
KQ 2 Treatments for Adult Patients with LE Varicose Veins and/or LE Chronic Venous Insufficiency/Incompetence/Reflux | 93 studies (87 RCTs, 6 observational) involving 127,011 patients | - For comparisons between surgical and endovascular interventions:; ○ No long-term difference in effectiveness between RFA and high ligation plus stripping, but RFA was associated with better short-term outcomes (≤30 days), such as less periprocedural pain (SOE=low), faster improvement in symptom scores (SOE=low), and fewer adverse events when compared with high ligation plus stripping (SOE=low).; ○ No difference in effectiveness between EVLA and surgery, though EVLA was associated with less periprocedural bleeding (SOE=moderate).; ○ No other significant differences in adverse events (SOE=low).; ○ No difference in effectiveness between sclerotherapy and surgery (SOE=low).; - For comparisons between EVLA and foam sclerotherapy, groups receiving EVLA and foam sclerotherapy both demonstrated improvement in quality-of-life scores and the Venous Clinical Severity Score, however there were no statistically significant differences in improvement between groups (SOE=low for intermediate-term outcomes).; - Insufficient evidence to support findings for comparisons between EVLA and EVLA plus phlebectomy.; - For comparisons between EVLA and endovenous radiofrequency:; ○ Groups receiving EVLA and endovenous radiofrequency both demonstrated improvement in quality-of-life scores; however, there were no statistically significant differences in improvement between groups (SOE=low).; ○ Both groups demonstrated improvement in the Venous Clinical Severity Score. There was a significant between-group difference in favor of the EVLA group in the short term (SOE=low).; ○ The RFA group had statistically significantly less periprocedural pain and fewer occurrences of superficial venous thrombosis (statistically significant p-value) and deep venous thrombosis (p-value NR), when compared with the EVLA group (SOE=low).; - Insufficient evidence to support findings for comparisons between different surgical interventions. The comparative effectiveness of surgical and hybrid procedures is limited by a low number of studies, inconsistency in the procedures utilized, and outcomes assessed.; - For comparisons between medical therapy and placebo, there is limited evidence published since 2000 to suggest that pentoxifylline is effective relative to placebo for reducing venous ulcers (SOE=low).; - Insufficient evidence to support findings all other comparisons.
KQ3 Treatments for Adult Patients with LE Chronic Venous Thrombosis/ Obstruction | 8 studies (3 RCTs, 5 observational) involving 804 patients | - KQ 3a, Effectiveness of interventions: Given overall variable study quality, inconsistent selection of endpoints, and small sample sizes, insufficient strength of evidence limits ability to make any conclusions regarding effectiveness of any of the studied interventions.; - KQ 3b, Diagnostic methods: Post-thrombotic syndrome is diagnosed for the purpose of clinical studies through a variety of ways including patient symptoms standardized to a vein-specific quality-of- life score, imaging (most commonly ultrasound), or a combination of the two assessments.; - KQ 3c, Modifiers of effectiveness: There was insufficient evidence to make any conclusions about modifiers of effectiveness of the comparators in the clinical trials.; - KQ 3d, Safety concerns: Study design limitations do not allow for any conclusive findings regarding the safety of endovenous stenting in patients with post- thrombotic syndrome.

### KQ 1: Narrative Review of Diagnostic Methods and Criteria for Adult Patients with LECVD

Our review of diagnostic testing methods for LECVD demonstrated that very few comparative studies exist in the literature published since 2000. Based on our investigative team’s clinical expertise and our nonsystematic review of the literature prior to 2000, it is clear that after a complete medical history and physical examination, the use of diagnostic imaging is particularly important to confirm the diagnosis, determine the etiology and anatomy of the LE venous abnormality, and plan endovenous and/or surgical interventions for LECVD. Over time, duplex ultrasound (DUS) has supplanted invasive imaging modalities (e.g., ascending and descending phlebography or venography) as the primary choice for diagnostic testing in all adult patients with LECVD. While DUS was considered the gold standard comparison in the majority of included studies of this review, invasive phlebography/venography and surgical confirmation were also used as gold standards.

The studies evaluating diagnostic methods in patients with LECVD were, in general, heterogeneous, of fair quality, and had small sample sizes. The patients in the studies included asymptomatic and symptomatic patients, patients with LE varicose veins, LE chronic venous insufficiency/incompetence/reflux, LE venous ulceration, and LE chronic venous obstruction/thrombosis. Finally, the outcomes assessed varied across studies based on the location of the disease (e.g., great saphenous vein [GSV], popliteal vein, site of prior venous ligation). Due to these factors, no meta-analyses were performed on this group of studies.

The diagnostic modalities assessed in this narrative review include medical history and clinical examination, ambulatory plethysmography, DUS, magnetic resonance venography (MRV), computed tomography venography (CTV), and invasive phlebography or venography. Ten observational studies assessed these diagnostic methods in the evaluation of patients with LECVD.

In one included study,^73^ ambulatory plethysmography was compared to DUS alone, DUS plus MRV, and DUS plus CTV. Sensitivity ranged between 35 percent and 64 percent and specificity ranged between 47 percent and 88 percent; however, the gold standard was unclear for this study, thus lowering the quality of this evidence. Another study evaluated ambulatory plethysmography as compared with DUS.^68^ The sensitivity of ambulatory strain-gauge plethysmography was very low (4 percent in femoral and saphenous veins; 5 percent in popliteal veins), while specificity was 100 percent in both venous systems. In the Society of Vascular Surgery (SVS)/American Venous Forum (AVF) consensus guidelines, the selective use of ambulatory plethysmography for diagnosis of simple varicose veins (Clinical, Etiologic, Anatomic, Pathophysiologic [CEAP] class C_2_) is GRADE 2C (weak recommendation; benefits are closely balanced with risks and burden based on low quality evidence), while its use in patients with advanced LECVD (CEAP class C_3_-C_6_) is GRADE 1B.^75^

Eight studies evaluated the use of DUS with various other imaging modalities (described below) in the diagnosis of LECVD.^65-68,70-72,74^ There was significant heterogeneity in the populations studied and clinical indication for diagnostic testing, and limited conclusions can be drawn from these studies. Although there is limited evidence that it is an effective firstline test, the SVS/AVF consensus guidelines recommend the use of DUS as a ubiquitous imaging test for the diagnosis of patients with suspected LECVD (GRADE 1A, strong evidence -- benefits clearly outweigh the risks, burden, and costs based on high quality evidence).

One study^69^ evaluated MRV versus another diagnostic modality (invasive venography and intravascular ultrasound [IVUS]) in the diagnosis of LE chronic venous obstruction. MRV was 100 percent sensitive for the diagnosis of proximal venous obstruction, but specificity was only 22.8 percent and the false-positive rate was 41.5 percent.

One study^67^ evaluated CTV versus another diagnostic modality (DUS) in the diagnosis of LECVD. The sensitivity of CTV for the diagnosis of GSV insufficiency was 98.2 percent and small saphenous vein (SSV) insufficiency was 53.3 percent, while the specificity for GSV insufficiency was 83.3 percent and for SSV insufficiency was 94.9 percent.

Seven studies evaluated the use of invasive pniebography or venography with another imaging modality in the diagnosis of LECVD.^65,66,68-70,72,74^ There was significant heterogeneity in the populations studied and clinical indication for diagnostic testing, and limited conclusions can be drawn from these studies. The SVS/AVF consensus guidelines recommend the use of invasive venography or phlebography in patients who are undergoing invasive treatment of LECVD (GRADE 1B). Adjunctive use of IVUS during invasive venography is also recommended in patients with suspected proximal chronic venous obstruction or post-thrombotic syndrome (GRADE 1B).

### KQ 2: Treatments for Adult Patients with LE Varicose Veins and/or LE Chronic Venous Insufficiency/Incompetence/Reflux

Ninety-three studies (87 RCTs, 6 observational; 127,011 patients) were identified that assessed the effectiveness of exercise training, medical therapy, weight reduction, compression therapy, skin/wound care, endovenous intervention, and/or surgical intervention on functional outcomes, quality of life, and safety events in patients with LE varicose veins and/or LE chronic venous insufficiency/incompetence/reflux/ulcers.

Table 39 summarizes the SOE by treatment comparison within KQ 2 that were graded as low, moderate, or high. The most frequently reported endpoints included quality-of-life scores, Venous Clinical Severity Score (VCSS) scores, periprocedural pain, and rates of recurrence and re-intervention. Adverse events were reported in most studies, however, there was dramatic variation in which adverse events were reported in individual studies, thus limiting the ability to perform meta-analysis on these outcomes. Seven studies (6 RCTs, 1 observational) reported variations in the treatment effectiveness by subgroup including CEAP classification, severity of disease, age, anatomic segment affected, and presence of ulcer. There were no studies reporting results by the following subgroups: Race/ethnicity, sex, body weight, Villalta score, VCSS classification, and known malignancy.

Table 39 KQ 2: Summary strength of evidence for major outcomes

Outcome (Timeframe) Strength of Evidence | Studies (N and Design) N Patients or Limbs | Findings
Venous stripping plus ligation vs. radiofrequency ablation (RFA)
Clinical Symptom Scores (VCSS) (Short-, Intermediate-, and Long-term) Low | 3 RCTs: 356 | For one study, the mean decrease in Venous Clinical Severity Score (VCSS) at 50 days follow-up was 5.1 (standard deviation [SD] 1.5) for RFA and 4.4 (SD 1.1) for surgery (p=0.19).^91^ One study^97^ reported mean VCSS scores at several time points but only found a significant difference, with lower symptoms scores in the RFA compared to high ligation plus stripping, at 3 days and 1 week postintervention. However, this difference was not apparent at 2-year follow-up (RFA 0.48, standard error [SE] 0.293, 0.69 vs. high ligation plus stripping 0.76 SE 0.60,1.0; p=not statistically significant [NS]).^97^ A separate study reported mean VCSS scores at 3 years and also found no difference between groups (RFA mean 0.44, SD 1.82 vs. high ligation plus stripping mean 0.3, SD 1.5; p=NS).^98^
Reduction in LE Pain (Short- and Intermediate-term) Low | 1 RCT: 60 1 RCT: NR | Two RCTs^98,189^ reported less pain on a visual analog scale (VAS) in the RFA arms vs. surgery arms. One study^98^ reported that mean VAS scores were lower in the RFA arm than the surgery arm, indicating less pain in the RFA group at 10 days’ follow-up (RFA mean=1.21, SD 1.72 vs. surgery mean=2.25, SD 2.23; no p-value reported). The other study reported significantly lower cumulative VAS scores over 6 weeks in the RFA arm vs. surgery arm but did not Indicate the number of time points included in the cumulative score.^189^
Adverse Events (Surgical Site Infection) (Short- and Long-term) Low | 2 RCTs, 1 Obs: 2,850 | Surgical site infection rates were higher in the ligation plus stripping groups compared to the RFA groups in all studies reporting this outcome. In a multinational study (80 patients), 5.6% of patients in the ligation plus stripping group and 0% of the patients in the RFA group experienced surgical site Infections at 3 days postoperation.^97^ A larger (190 patients) but poor-quality study reported three out of 90 patients who underwent surgery had a perlprocedural surgical site infection, whereas none of the patients who underwent RFA had any procedure- related infections.^153^ A retrospective observational study compared patients who underwent RFA (1,188 patients) to those who underwent any type of surgical correction for venous incompetence/varlcose veins (ligation, ligation plus stripping, phlebectomy, or ligation plus excision) (2,580 patients). Those undergoing a surgical Intervention had a higher rate of surgical site infection (adjusted OR 2.56; 95% Cl 1.19-5.50; p=0.016).^131^
Adverse Events (Thrombophlebitis) (Short-, Intermediate-, and Long-term) Low | 3 RCTs: 695 | Two RCTS reported lower rates of superficial thrombophlebitis in the surgery group compared with the RFA group; in a poor-quality study, 6.8% of patients randomized to RFA vs. 0% of patients in surgery were found to have superficial thrombophlebitis,^153^ whereas a good-quality study reported 9.9% of the RFA group vs. 4.2% of the surgery group had superficial thrombophlebitis (Fisher exact test p=0.006 across the four arms; no p-value reported for arm-to-arm comparison).^98^ One study^91^ reported one out of 15 RFA patients vs. zero out of 13 surgery patients reported an incidence of superficial thrombophlebitis at 3 years’ follow-up.
Venous ligation plus stripping vs. EVLA
Vein recurrence^a^ Repeat Intervention (Long-term) Low | 5 RCTs: 1,261 | Five studies evaluated long-term superficial thrombophlebitis.^98,105,117,126,152^ The findings of these studies were imprecise and Inconsistent demonstrating no difference in superficial thrombophlebitis between the two strategies (OR = 1.009, 95% Cl = 0.686 to 1.484) (Figure 6)
Improvement Hemodynamics Low | 5 RCTs: 887 | Five studies representing 887 patients were combined in a meta-analysis to explore improvement in hemodynamics.^84,94,117,126,152^ The analysis suggested improvement in reflux/incompetence for surgery compared to EVLA (OR = 0.408, 95% Cl 0.149 to 1.121) (Figure 7).
Clinical symptom scores (VCSS) Low | 3 RCTs: 487 | We synthesized three studies representing 487 patients for treatment effect on long-term VCSS score.^87,98,152^ There was no significant difference between treatment strategies (standard difference in means = 0.021,95% Cl = -0.186 to 0.229) (Figure 8).
Clinical symptom scores (CEAP) Moderate | 4 RCTs: 867 | We also explored the CEAP after 12 months in 4 studies representing 867 patients.^101,117,121,139^ No difference was found (standard difference in means = 0.061, 95% Cl -0.096 to 0.219) (Figure 9).
Patient-Reported Quality of Life (EQ-5D) Low | 4 RCTs: 1,436 | Four studies^89,103,117,185^ reported EuroQol 5D (EQ-5D) scores as an outcome at various time points postintervention. None of the studies reported a statistically significant difference between the surgery and EVLA groups at any time point.
Patient-Reported Quality of Life (AVVQ-Short-term) Low | 4 RCTs: 583 | We synthesized four studies representing 583 patients which evaluated short-term AVVQ effects.^103,105,139,185^ These studies showed a -0.014 standardized difference in means (95% Cl -0.340 to 0.311) showing no difference between strategies (Figure 10).
Patient-Reported Quality of Life (AVVQ-Intermediate-term) Low | 4 RCTs: 426 | Four studies representing 426 patients explored the impact on AVVQ over an intermediate time horizon.^105,139,168,185^ Again there was no different in AVVQ scores (standard difference in means = -0.011,95% Cl 0-0.212 to 0.190) (Figure 11).
Patient-Reported Quality of Life (AVVQ-Long-term) Moderate | 6 RCTs: 663 | We synthesized data from 6 studies (663 patients) which evaluated long-term quality of life with the AVVQ.^98,103,105,139,152,168^ These studies also consistently found no difference between treatment strategies (standard difference in means = 0.063, 95% Cl -0.122 to 0.247) (Figure 12).
Reduction in LE Pain Low | 4 RCTs: 778 | Four studies representing 778 patients were synthesized quantitatively to explore reduction in LE pain as measured by a visual analog scale.^98,105,150,185^ These studies demonstrated a -0.148 standardized difference in means (95% Cl -0.531 to 0.236) showing no difference between treatment strategies (standard difference in means = -0.148, 95% Cl -0.531 to 0.236) (Figure 13).
Adverse Events (Bleeding risk) Moderate | 3 RCTs: 822 | We were able to perform a meta-analysis on three studies representing 822 patients that evaluated bleeding (hematoma/ecchymosis).^120,121,152,186^ This analysis demonstrated a statistically significant benefit of EVLA compared with surgery regarding reduction in bleeding risk (OR = 2.823, 95% Cl = 1.324 to 6.022) (Figure 14).
Venous stripping plus ligation vs. sclerotherapy
Vein recurrence^a^ Low | 3 RCTs: 395 1 RCT: 96 limbs | We synthesized evidence from 4 RCTs (3 RCTs with 395 patients, 1 RCT with 96 limbs) that explored long-term vein recurrence.^98,127,176,181^ These studies did not demonstrate a difference between strategies (OR = 1.54, 95% Cl 0.461 to 5.143) and were both inconsistent and imprecise (Figure 15).
Patient-Reported Quality of Life (AVVQ) Low | 3 RCTs: 583 | Three good-quality studies^88,89,98,127^ reported AVVQ as an outcome at various time points ranging from baseline to three years follow-up. All studies showed decreased scores at follow-up, indicating an improvement in symptom scores but no difference between groups.
Patient-Reported Quality of Life (EQ-5D) Moderate | 3 RCTs: 900 | We synthesized evidence from 3 RCTs (900 patients) that explored the long-term change quality of life as measured by EQ-5D.^88,89,117,118^ These studies did not demonstrate a difference between strategies (difference in means = 0, 95% Cl -0.028 to 0.029) (Figure 16).
Reduction of LE Pain Low | 3 RCTs: 1,498 1 RCT: NR | Four RCTs^88^,^88,89,98,187,199^ reported VAS pain scores at various time points ranging from baseline to 1 year. Three studies^98,187,199^ reported significantly lower pain scores in the sclerotherapy group when compared with the surgery group.
Adverse Events (Hematoma) Low | 3 RCTs: 1,142 1 RCT: 96 limbs | We synthesized evidence from 4 RCTs (3 RCTs with 1,142 patients, 1 RCT with 96 limbs)^82,146,176,187^ that explored hematomas as an outcome of interest. These inconsistent and imprecise studies did not demonstrate a difference between strategies (OR = 1.010, 95% Cl 0.245 to 4.163) (Figure 17).
EVLA vs. sclerotherapy
Changes on standardized symptom scores (Intermediate-term) Low | 2 RCTs: 885 | VCSS improved in both groups. No statistically difference between groups.^89,114^
Patient-Reported QOL (Intermediate-term) Low | 2 RCTs: 885 | There was a significant between-groups difference regarding effect size in adjusted data of AVVQ at 6 weeks (p=0.032). There was a significant between-groups difference regarding median within group change of AVVQ at 3 months (p=0.01) both demonstrating a benefit of EVLA.^89,114^
Patient-Reported QOL (Long-term) Low | 2 RCTs: 580 | QOL improved in both group. No statistically difference between groups^98,114^.
Qualitative reduction in LE pain (Short-term) Low | 2 RCTs: 885 | The foam sclerotherapy group reported less pain versus the EVLA group at 10 days (1.60 versus 2.58, respectively). There was a significant between-groups difference in pain in favor of foam sclerotherapy group at 07 days (p=0.005).^89,114^
EVLA vs. RFA
Bleeding (Short-term) Low | 2 RCTs: 249 1 Obs: 979 limbs | According to Shepherd et al., the number of patients with hematoma was 2 in EVLA group and was 0 in RFA group. According to the observational study (Obi) the number of patients with hematoma was 45 in EVLA group and 5 in RFA group. There was a significant between-groups difference regarding hematoma in favor of RFA group (p=<0.001).^122,123,125,154^ Gale et al. reported the number of patients with bruising at 1 week. There was a significant more bruising in the EVLA group at 1 week (p=0.01).^154^
Changes on standardized symptom scores (Short-term) Low | 2 RCTs: 205 1 Obs: 979 limbs | VCSS improved in both group. Demonstrating statistically difference in favor of EVLA group.^125,154,163^
Changes on standardized symptom scores (Intermediate-term) Low | 3 RCTs: 336 | VCSS improved in both group. No statistically difference between groups.^122,123,154,163^
Changes on standardized symptom scores (Long-term) Low | 2 RCTs: 249 | VCSS improved in both group. No statistically difference between groups.^122,123,154^
Patient-Reported QOL (Short-term) Low | 3 RCTs: 372 | QOL improved in both group. No statistically difference between groups.^122,123,149,163^
Patient-Reported QOL (Intermediate-term) Low | 4 RCTs: 490 | QOL improved in both group. No statistically difference between groups^122,123,149,154,163^
Qualitative reduction in LE pain (Short-term) Low | 2 RCTs: 285 | Demonstrating statistically significance difference between groups in favor of RFA arm (p=0.001). At 7 days the median pain was 13,5 in the EVLA group and was 0 in the RFA group. RFA showed better improvement of pain score than the EVLA group at 10 days (-12.3 versus -6.3, respectively). There was a significant between-groups difference at 10 days (p=0.01).^122,123,149^
Endovascular treatment vs. placebo
Changes on standardized symptom scores (Intermediate-term) Moderate | 3 RCTs: 621 | Two good-quality RCTs^124,141^ demonstrated a statistically significance difference of VCSS in favor of 0.5% polidocanol endovenous group (p<0.0001) and 1% polidocanol endovenous group (p<0.0001) when compared with placebo group. Three good-quality studies^124,141,193^ also reported Varicose Veins Symptoms Questionnaire (VVsymQ) or modified VEINES-Sym (m- VEINES-Sym) scores at 8 weeks. After converting to effect sizes, the summary effect of these studies demonstrated a statistically significant standardized difference in means of 0.81 (95% Cl, 0.57 to 1.05) favoring 1% polidocanol (Figure 18).
Improvement in LE venous hemodynamics/reflux severity (Intermediate-term) Moderate | 3 RCTs: 465 | Absence of reflux: In two RCTs, there was a significant between-groups difference in favor of 0.5% polidocanol endovenous group (p=0.00043) and 1% polidocanol endovenous group (p=0.0009) when compared with placebo group. In the second RCT, there was a significant between-groups difference in favor of pooled (0.5%, 1% and 2%) polidocanol endovenous group (p<0.001) when compared with of 0.125% polidocanol endovenous group. In a third RCT, in the foam sclerotherapy group the number of patients with occlusion was 11 at 4 weeks. In the placebo group the number of patients with occlusion was 0 at 4 weeks.^124,141,174^
Patient-Reported QOL (Intermediate-term) Moderate | 3 RCTs: 621 | The three good-quality RCTs^124,141,193^ presented mean within-group changes for the modified or unmodified Venous Insufficiency Epidemiological and Economic Study Quality-of-Life questionnaire (mVEINES-QOL and VEINES-QOL) scores at 8 weeks for each group. The summary effect of these studies was a statistically significant standardized difference in means of 0.81 (95% Cl, 0.57 to 1.05) favoring 1% polidocanol (Figure 19).
Invasive surgery vs. invasive surgery
Qualitative reduction in LE pain (Short-term) Low | 1 RCT: 40 1 RCT: NR | High ligation/stripping vs. High ligation/cryostripping^169^–No significant difference between procedures at 24 hours. High ligation/stripping vs. High ligation/cryostripping^172^–No significant difference between procedures at 7, 14, and 28 days.
Invasive surgery vs. compression
Death (Long-term) Low | 2 RCTs: 526 1 RCT: 196 limbs | High ligation/stripping vs. compression^108,111^–16 percent in the surgery group versus 19 percent in the compression group (p=0.245) at 3 years. High ligation/stripping vs. compression^191^–No deaths in either group over 6 months. High ligation/stripping/SEPS vs. compression^112,113^–A total of 23 patients died within 28 months; these patients contributed 8 limbs to the surgical group and 17 to the compression group (both legs were randomized for 2 patients), p=NR.
Improvement in LE venous hemodynamics/reflux severity (Intermediate-term) Low | 2 RCTs: 258 | High ligation/stripping vs. compression^108,111^–Number of legs with incompetent calf perforating veins dropped from 51 to 41 percent at 3 months among surgery patients (p<0.001), but increased from 42 to 46 percent among compression patients (p=0.144). No between-group comparison reported. CHIVA vs. compression^175,190^–By 6 months, venous volume, venous filling index, and residual volume fraction improved significantly in the CHIVA group (all p<0.001); no improvements observed in the compression group. No between-group statistical comparisons reported.
Recurrent Ulceration (Long-term) Low | 2 RCTs: 127 1 RCT: 196 limbs | High ligation/stripping vs. compression^108,111^–Recurrence rate was 12 percent in the surgery group versus 28 percent with compression alone (p<0.0001). High ligation/stripping/SEPS vs. compression^112,113^–At long-term follow-up, 22 of 45 limbs in the surgery group had recurrent ulceration versus 33 of 35 with compression (p=NR). CHIVA vs. compression^175,190^–A significantly higher number of patients in the compression arm (9 out of 24 patients) had recurrent ulcerations compared to 2 out of 27 surgery patients (p≤0.005).

a Vein recurrence refers to the establishment of patency of the venous system; such recurrence often requires repeat intervention.

Abbreviations: AVVQ=Aberdeen Varicose Vein Questionnaire; CEAP=Clinical, Etiologic, Anatomic, Pathophysiologic; CHIVA= Cure conservatrice et Hémodynamique de l’Insuffisance Veineuse en Ambulatoire; CI=confidence interval; CIVIQ- 2=Chronic Venous Insufficiency Questionnaire-2; DVT=deep vein thrombosis; EQ-5D=EuroQol 5D; EVLA=endovenous laser ablation; GSV=great saphenous vein; KQ=key question; LE=lower extremity; N=number; OR=odds ratio; QOL=quality of life; RCTs=randomized controlled trials; RFA=radiofrequency ablation; SD=standard deviation; SEPS= subfascial endoscopic perforating vein surgery; SF-36=Short-Form 36-item survey; SOE=strength of evidence; VAS=visual analog scale; VCSS=Venous Clinical Severity Score; VEINES-QOL=Venous Insufficiency Epidemiological and Economic Study Quality-of- Life questionnaire

### KQ 3: Treatments for Adult Patients with LE Chronic Venous Thrombosis/Obstruction

Eight studies (3 RCTs, 5 observational; 804 patients) were identified that assessed the effectiveness of exercise training, medical therapy, weight reduction, compression therapy, skin/wound care, endovenous intervention, and/or surgical intervention on functional outcomes, quality of life, and safety events in patients with LE chronic venous obstruction/thrombosis. Studies that assessed individual treatment modalities or combinations of treatment modalities were analyzed, however differences in the treatment comparisons, outcome measures, and follow-up time points eliminated the possibility that study results could be pooled for analysis of direct comparisons. There were no studies reporting results by the following subgroups: Age, race/ethnicity, sex, body weight, CEAP classification, VCSS classification, severity of disease, anatomic segment affected, presence of ulcer, and known malignancy.

Unfortunately given the small number of studies, heterogeneity in outcomes and interventions assessed, diverse populations evaluated, and inconsistency in findings, the evidence was insufficient to support any findings.

## Findings in Relationship to What is Already Known

The SVS/AVF have published a comprehensive set of consensus guidelines on LECVD,^75^ and venous ulcers,^77^ and the United Kingdom’s (UK’s) National Institute for Health and Care Excellence (NICE) has published a clinical guideline on varicose veins.^78^

For KQ 1, which addresses the diagnostic modalities used in patients with LECVD, our findings offer little in addition to the SVS/AVF guidelines as very few comparative studies exist in the published literature since 2000. There was insufficient evidence to confirm or refute the recommendation to perform DUS for confirmation of LECVD or to plan invasive intervention.

For KQ 2, which addresses treatment strategies for patients with LE varicose veins and LE chronic venous insufficiency/incompetence/reflux, our findings are consistent with the SVS/AVF and NICE guidelines. For surgical intervention (ligation plus stripping) versus endovenous intervention (radiofrequency ablation [RFA], endovenous laser ablation [EVLA], endovenous steam ablation [EVSA], or sclerotherapy), our findings were similar to findings in the NICE systematic review showing no significant differences between treatment modalities for the following outcomes: quality of life, VCSS score, and rates of recurrence and re-intervention.

For KQ 3, which addresses treatment strategies for patients with LE chronic venous thrombosis/obstruction, no clinical guidelines exist in the literature and very few topic reviews exist. With only 8 relevant studies included in this systematic review, there is insufficient evidence to make clear recommendations regarding treatment options. With low SOE (due to a single RCT with small sample size), patients with post-thrombotic syndrome appear to benefit from an exercise training program based on a statistically significant improvement in quality of life and a non-statistically significant improvement in Villalta symptom score.^204^

## Challenges in Evaluating the Existing Literature in LECVD Patients

Comparing diagnostic and treatment choices in patients with LECVD has the following challenges:

- Population differences: Inclusion and exclusion criteria have varied among studies, and stratification based on symptom status (specifically LE varicose veins, LE chronic venous insufficiency, both) is important but lacking. Furthermore, very few studies evaluated a cohort of patients with LE chronic venous obstruction/thrombosis, and most studies established a cohort of patients with acute DVT and followed these patients long-term. These studies were excluded from the current systematic review.
- Evolution in interventional techniques: Improvements specifically in endovenous techniques have made comparisons between treatment strategies more challenging. We were unable to account for these differences.
- Endpoint differences: These differences include variable reporting of functional and quality of life endpoints and adverse events in the evaluation of patients with LECVD. This prohibited the quantitative analysis of study results for multiple treatment comparisons.
- Descriptive characteristics of included patients: Very few studies included descriptive characteristics of diagnostic testing or disease severity (e.g., CEAP classification) to guide inclusion of patients or determine modifiers of effectiveness of various treatments.
- Length of follow-up: Study follow-up was heavily weighted towards short-term followup, and there was variable reporting of duration of follow-up. While study outcomes were grouped into short-, intermediate-, and long-term follow-up, this prohibited the quantitative analysis of study results for multiple treatment comparisons and multiple timepoints.
- Study design: While a significant number of RCTs exist in LECVD, many did not properly document/ensure allocation concealment and blinding of outcomes assessors. Additionally, especially among studies of surgical and endovenous interventions, few studies employed patient blinding (sham procedures). This resulted in an overall increase in the likelihood of bias within the literature.

## Applicability

We used 2000 as the start date for the literature search to improve the applicability of the findings to current clinical practice. In doing so, we acknowledge that earlier comparative studies of diagnostic modalities and treatment choices were not included in this review. Including older studies with outdated gold standards for diagnostic methods (e.g., ascending and descending phlebography) may have biased the results against an accepted standard (DUS). Including older studies with suboptimal background therapy (e.g., compression therapy) may have biased the results of endovenous and/or surgical intervention to favor active treatment over suboptimal usual care treatment.

In the analysis of all patients with LECVD, the majority of studies were single-center studies conducted outside of the United States. There were no studies that specifically evaluated the role of new or novel diagnostic tests in patients with LECVD. There were also no studies that specifically evaluated the role of long-term medical therapy (e.g., oral anticoagulants) in patients with LE chronic venous obstruction/thrombosis.

Table 40 shows the potential issues with applicability in included studies of patients with LECVD.

Table 40 Potential issues with applicability of included studies

Issues | KQ 1 N=10 | KQ 2 N=93 | KQ 3 N=8 | Total N=111
Population (P)
Narrow eligibility criteria and exclusion of those with comorbidities | 0 | 4 | 1 | 5
More complex patients than typical of the community | 0 | 1 | 1 | 2
Run-in period with high exclusion rate for non-adherence or side effects | 0 | 2 | 0 | 2
Narrow or unrepresentative severity, stage of illness, or comorbidities | 0 | 4 | 0 | 4
Intervention (I)
Diagnostic tools used differently than as recommended or commonly used in practice | 0 | 1 | 0 | 1
Dosing not reflective of current practice | 0 | 2 | 0 | 2
Co-interventions that are likely to modify the effectiveness of therapy | 0 | 12 | 2 | 14
Highly selected intervention team or level of training/proficiency not widely available | 0 | 5 | 1 | 6
Follow-up not reflective of current practice | 0 | 4 | 1 | 5
Comparator (C)
Diagnostic tools used differently than as recommended or commonly used in practice | 0 | 1 | 0 | 1
Comparator unclear | 0 | 2 | 1 | 3
Inadequate comparison therapy or use of a substandard alternative therapy | 0 | 1 | 1 | 2
Outcomes (O)
Composite outcomes that mix outcomes of different significance | 0 | 3 | 0 | 3
Short-term follow-up | 0 | 25 | 0 | 25
Surrogate outcomes | 0 | 8 | 0 | 8
Timing (T)
Duration of participant follow-up was inadeguate | 0 | 15 | 1 | 16
Setting (S)
Study conducted solely outside the United States | 6 | 85 | 4 | 95
Study was conducted only at a single site | 7 | 50 | 7 | 64

Abbreviation: KQ=key question

## Implications for Clinical and Policy Decisionmaking

LECVD is an increasingly prevalent condition in the United States due to an aging and obese population. There is a significant need for comparative safety and effectiveness studies due to the increasing prevalence, multiple potential treatment options, and high costs to the healthcare system. The current analysis provides an important evidence review that must be put in context with current clinical practice so that it may inform both future research and clinical and policy decisionmaking.

The findings for diagnostic testing in LECVD add little to the argument that noninvasive imaging costs are substantial and continue to rise for patients with this condition. However, given the low sensitivity of ambulatory plethysmography and the general acceptance of DUS as the gold standard, it seems reasonable to concede that DUS is an acceptable first diagnostic test for LECVD. An unanswered research question for diagnostic testing remains, Which patients warrant testing? The answer to this question (and multiplier for cost analyses) will drive overall costs to the healthcare system.

Regarding the treatment of patients with LE varicose veins and LE chronic venous insufficiency/incompetence/reflux, this review found that several therapies—surgical intervention, endovenous intervention, and compression therapy—were effectiv6e at improving functional measures and quality-of-life measures. In patients with symptomatic LE chronic venous insufficiency/incompetence/reflux, the current findings that endovenous intervention is associated with less periprocedural pain and complications when compared with surgical intervention (e.g., high ligation plus stripping) reinforces that this should be first line therapy. A major concern is the lack of data to support guidelines’ recommendations for the treatment of patients with lower CEAP scores (C_1_ and C_2_), as the prevalence of asymptomatic disease drives costs. Additionally, with increasing innovation of endovenous intervention, more contemporary, well-performed multicenter RCTs and registry analyses of actual utilization are needed to determine efficacy and effectiveness. Finally, whether the treatments studied are cost effective was beyond the scope of this review.

Regarding treatment of patients with chronic obstruction/thrombosis, this review highlights the lack of evidence the guide long-term oral anticoagulant use in these patients. Many such patients are being under-treated (3 months) while other patients are being treated with lifelong anticoagulants. With novel oral anticoagulants, particularly the patients in the lifelong treatment group has huge implications for payers. Additionally, the diagnostic testing strategy for these patients is extremely varied and needs to be understood before treatment is begun. Patients with iliofemoral DVT should be treated differently if the patient has proximal venous obstruction versus not. Finally, since endovenous intervention for iliofemoral DVT is becoming more common and the use of thrombolytics in this group has increased, there is a need for effectiveness data (but more importantly safety data) for this approach.

## Limitations of the Systematic Review Process

The current review was limited to English-language–only studies and focused on those that compared two treatment modalities. After full-text review, we noted that there were 86 RCTs in KQ 2 (assessment of LE chronic venous insufficiency/incompetence/reflux), and after discussion with our Agency for Healthcare Research and Quality (AHRQ) Task Order Officer, we then abstracted data from large observational studies (N=4) for this KQ that reported outcomes in >500 patients. As such, the findings for KQ 2 are biased towards randomized comparisons, and it is possible that information from observational studies would have provided additional information for this population. Note that the update of the final report added nine additional studies (three to KQ 1 and six to KQ 2).

There are several other limitations to the available evidence for the treatment of LECVD. First, many treatment comparisons are within similar treatment modalities (i.e., endovenous therapy with compound A versus compound B, surgery with technique A versus technique B). While these comparisons may be meaningful, there is a significant need for treatment strategy studies (i.e., study of compression therapy prior to endovenous and/or surgical intervention). Specifically, we were not able to assess the effectiveness of treatment strategies that were delivered if another modality had a suboptimal result or failed. Many studies did not designate whether subjects were asymptomatic or symptomatic (especially those studies including patients undergoing treatment for varicose veins where the patients may have perceived symptoms despite not having classic symptoms such as pain, paresthesia, or heaviness). Furthermore, the literature did not fully address whether patients with varicose veins only (i.e., no reflux) should be treated differently than patients with more severe forms of venous insufficiency/incompetence/reflux. The literature was also insufficient to allow complete evaluation of patients with multiple venous issues (e.g., varicose veins, venous insufficiency, and venous obstruction/thrombosis) as many patients have multiple components of this disease.

Regarding endpoints, there are numerous and heterogeneous measures reported, often with no clearly agreed upon definitions for patients with LECVD. The time points for follow-up are variable and often the ascertainment is not standardized. Finally, there are little data on important subgroups of harms.

## Research Recommendations

The current literature search for LECVD revealed many single-center studies that were conducted outside of the United States. Very few multicenter, multinational studies were found during this systematic review. From the studies that were included, there was a notable variation in (1) outcome measures used to assess procedural success, symptom status, and quality life, (2) follow-up assessment time points, and (3) type of outcomes reported (i.e., surrogate and hard clinical endpoints). Therefore, there are numerous areas of evidence gaps and areas for potential future research in LECVD. An improvement in the methodology of upcoming trials in these areas will increase the strength of evidence of the findings. Specifically, measuring outcomes that are (1) important to patients (e.g. quality of life, patient perception) and (2) able to be collected within the context of clinical care (e.g. office practice) will be imperative to improve the clinical care of these patients. We note that there are a number of trials planned, ongoing, or pending publication investigating diagnostic imaging and/or treatment modalities for LECVD, which upon completion may provide valuable data to address some of the identified gaps.

### KQ 1 Research Gaps

For KQ 1, the primary limitation of the available evidence was the low number of studies that directly compared diagnostic treatment modalities. While clinical practice has shifted in favor of using DUS as the gold standard for diagnosis of LECVD, assessment of severity and location of disease, and preparation for invasive treatment, the study of existing diagnostic technology and novel technology needs further investment and investigation. Furthermore, as endovenous intervention is performed more frequently, the study of periprocedural noninvasive imaging and invasive imaging to establish appropriate use criteria and best clinical practices for which patients should be imaged/studied and how they should be imaged/studied is needed.

### KQ 2 Research Gaps

Due to conceptual heterogeneity in design of the available studies (compression therapies utilized, surgical and endovenous interventions utilized, outcomes selected, outcome definitions, outcome timing, and analytic/statistical approaches) and a general paucity of studies pertaining to most comparisons, there is a general need for high-quality, adequately powered comparative effectiveness studies of “best practice” procedures using standardized consensus outcomes at clinically-relevant timepoints. Additionally, there is a paucity of studies investigating efficacy and safety in clinical and socioeconomically important subgroups such as anatomic subclasses, CEAP subclasses, and women. As a result, future studies will also need to incorporate subanalyses of these important subgroups.

In terms of the heterogeneity of the studies, the primary limitation of the available evidence for treatment of patients with LE chronic venous insufficiency/incompetence/reflux was the heterogeneity of outcomes assessing functional and quality of life measures for this KQ. Furthermore, while mechanical compression therapies are routinely used postoperatively as an adjunct to invasive interventions for the treatment of LE chronic venous insufficiency/incompetence/reflux and for treatment of venous ulceration, there is little evidence to inform decisions about which of the many types of compression therapies to prescribe or the optimal dosing and duration of compression therapy for chronic venous insufficiency with or without venous ulcers.

Lastly, with the profusion of available treatment strategies (surgery, endovascular intervention, hybrid intervention, compression therapy, and medical therapy) future studies of the comparative effectiveness of these [underlined: treatment strategies] will be necessary to guide clinicians and patients.

### KQ 3 Research Gaps

For KQ 3, the primary limitation of the available evidence was the low number of studies that directly compared treatment options in patients with LE venous obstruction/thrombosis. Few high-quality studies exist comparing the available treatment options that are routinely used in clinical practice in the United States (e.g., long-term oral anticoagulation, iliac and inferior vena cava angioplasty and stenting, thrombolysis) making the evidence base insufficient for the comparative effectiveness of these interventions and highlighting the need for future studies. Additionally, the literature on patients being treated for LE chronic venous thrombosis is extremely sparse, as most cohorts have been established at the time of acute deep vein thrombosis (DVT) and have not studied patients at intermediate- or long-term timepoints. More RCTs or prospective cohort studies with assessment of functional capacity, quality of life, and additional venous outcomes (e.g., severity of edema, severity of reflux, wound healing) are needed.

### Underreporting of Subgroup Results across All KQs

Across all KQs, the underreporting of results for subgroups that may modify the comparative effectiveness was common. Given the limited space in publications, it would be helpful to have online, supplementary appendices that report the outcomes by age, race, sex, venous symptom severity, and comorbidities. The representation of women and the reporting of race/ethnicity were also low in these studies. Future studies that oversample for women and minority populations are needed to address subpopulation questions.

## Conclusions

The available evidence for treatment of patients with LECVD is limited by heterogeneous studies that provide comparisons of multiple treatment options, varied outcomes measured, and disparate timepoints of outcome assessment. In addition, surrogate outcomes are often reported and patient-reported outcomes are infrequently measured despite the fact that the American Venous Forum guidelines give measurement of patient-reported outcomes a Class 1B recommendation. Very little comparative effectiveness data has been identified to study new and existing diagnostic testing modalities for patients with LECVD. Several advances in care in endovenous interventional therapy have not been rigorously tested, and very few studies on conservative measures (e.g., lifestyle modification, compression therapy, exercise training) exist in the recent literature published since 2000. Additionally, the potential additive effects of many of these therapies are unknown. The presence of significant clinical heterogeneity of these results makes conclusions for clinical outcomes uncertain and provides an impetus for further research to improve the care of patients with LECVD.