# Methods

The methods for this systematic review follow the Agency for Healthcare Research and Quality’s (AHRQ’s) Methods Guide for Effectiveness and Comparative Effectiveness Reviews^8^ (hereafter referred to as the Methods Guide) and the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.^9^ See the review protocol (http://www.ahrq.gov/sites/default/files/wysiwyg/research/findings/ta/topicrefinement/lecvd_protocol.pdf) for full details.

## Protocal Development

The topic of this report and the key questions (KQs) arose through nomination by the Centers for Medicare and Medicaid Services (CMS). The EPC drafted the protocol and the protocol was reviewed by AHRQ, CMS, and the technical expert panel (TEP). The TEP was recruited to provide high-level content and methodological expertise throughout the development of the review. The TEP represented clinician/researchers and scientific experts in areas of cardiovascular/endovascular medicine, interventional cardiology, radiology, vascular surgery, and thrombosis; payers; and Federal agencies. The finalized protocol is posted on the AHRQ website.^10^ The PROSPERO registration is CRD42016035669.

## Literature Search Strategy

### Search Strategy

To identify relevant published literature, we searched PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews, limiting the search to articles published from January 1, 2000, to June 30, 2016. The timeframe of 2000 forward represents contemporary treatment strategies in the field and corresponds to timings where significant changes in the availability of endovascular techniques occurred within the peripheral vascular treatment community. An experienced search librarian guided all searches.

We supplemented the electronic searches with a manual search of citations from a set of key primary and review articles.^11-51^ The reference lists for identified pivotal articles were manually hand-searched and cross-referenced against our database, and additional relevant articles not already under consideration were retrieved for screening. All citations were imported into an electronic bibliographical database (EndNote^®^ Version X7; Thomson Reuters, Philadelphia, PA).

As a mechanism to ascertain publication bias in recent studies, we searched ClinicalTrials.gov to identify completed but unpublished studies (we also explored the possibility of publication bias specifically in our quantitative synthesis of the included literature through meta-analysis techniques). Other gray literature databases searched were the National Guidelines Clearinghouse and the World Health Organization (WHO) International Clinical Trials Registry Platform (ICTRP) search portal. Both registry sources (ClinicalTrials.gov and the WHO ICTRP) and the results from the National Guidelines Clearinghouse were used to identify relevant articles from completed studies. Search dates and search terms used for all of the above sources are provided in Appendix A. Additional gray literature was solicited through the AHRQ Effective Health Care (EHC) website and a notice posted in the Federal Register.

### Inclusion and Exclusion Criteria

We specified our inclusion and exclusion criteria based on the PICOTS (populations, interventions, comparators, outcomes, timing, settings) identified for each question. Table 4 summarizes the inclusion and exclusion criteria used in the review.

Table 4 Inclusion and exclusion criteria

PICOTS Element | Inclusion Criteria | Exclusion Criteria
Populations | KQ 1: Adults (over age 18) with the diagnosis of LE varicose veins, LE chronic venous/insufficiency/incompetence/reflux, and/or LE chronic venous thrombosis/obstruction (including post-thrombotic syndrome) KQ 2: Asymptomatic or symptomatic adults (over age 18) with the diagnosis of LE varicose veins and/or LE chronic venous insufficiency/incompetence/reflux KQ 3: Asymptomatic or symptomatic adults (over age 18) with the diagnosis of LE chronic venous thrombosis/obstruction (including post-thrombotic syndrome) Subgroups of interest for KQs 2-3:; - Age; - Race/ethnicity; - Sex; - Body weight; - CEAP classification; - VCSS classification; - Villalta score; - Severity of disease; - Anatomic segment affected (e.g., iliofemoral, infrainguinal); - Known malignancy; - Presence of LE ulcer | Individuals younger than 18 years of age. Studies including both adults and patients under 18 were excluded unless data for the adult population was reported separately. Individuals with acute venous disease (including acute DVT). Studies with mixed populations of both acute and chronic disease were excluded unless data for the patients with chronic disease was reported separately. Pregnant women
Interventions | KQ 1: Any standard chronic venous disease diagnostic strategy, including: air plethysmography, LE DUS (with and without compression), invasive venography, MRV, computed tomographic venography, D-dimer testing KQ 2: Lifestyle interventions (e.g., smoking cessation, leg elevation, weight reduction, exercise), medical therapy, local skin care/wound care, mechanical compression therapy, and invasive procedures (i.e., surgical and endovascular procedures); - Medical therapies: diuretics, aspirin, pentoxifylline, prostacyclins, zinc sulfate; - Invasive surgical/endovascular procedures: sclerotherapy (liquid, foam, glue), RFA, thermal ablation, chemical ablation, ambulatory phlebectomy, transilluminated powered phlebectomy, venous ligation, venous excision; KQ 3: Lifestyle interventions (e.g., smoking cessation, leg elevation, weight reduction, exercise), medical therapy, local skin care/wound care, mechanical compression therapy, and invasive procedures (i.e., surgical and endovascular procedures); - Medical therapies: anticoagulants including warfarin, apixaban, rivaroxaban, edoxaban, and dabigatran; diuretics; - Invasive surgical/endovascular procedures: endovenous angioplasty/stenting, ultrasound accelerated thrombolysis for chronic DVT (EkoSonic® endovascular system), surgical thromboembolectomy
Comparators | KQ 1: Specific diagnostic modalities listed above were compared with one another KQs 2-3: Specific treatments were compared to other included treatments as described above or to no treatment (placebo or usual care) | Same treatment comparisons that vary by characteristics such as dose, timing, manufacturer, compression level, or energy level. Comparisons between interventions for local skin care/wound care.
Outcomes | KQ 1:; - Accuracy of diagnostic strategy, as measured by:; ○ Sensitivity; ○ Specificity; ○ Positive predictive value; ○ Negative predictive value; ○ Inter-rater reliability; ○ Internal consistency; ○ Test-retest reliability; ○ False positives; ○ False negatives; ○ Positive likelihood ratio; ○ Negative likelihood ratio; KQs 2-3:; - Changes on standardized symptom scores (Villalta score, CEAP classification, and VCSS score); - Qualitative reduction in LE edema; - Qualitative reduction in LE pain; - Improvement in LE venous hemodynamics/reflux severity as measured by air plethysmography, DUS, or invasive venography; - Venous wound healing; - Recurrent ulceration; - Patient-reported quality of life (including AVVQ); - Repeat intervention; - LE amputation; - Adverse effects of treatment, including:; ○ Adverse drug reactions; ○ Bleeding (including intracranial bleeding); ○ Venous wound infection; ○ Contrast nephropathy; ○ Radiation-related injuries; ○ Exercise-related harms; ○ Periprocedural complications (vessel dissection, vessel perforation, and AV fistula); ○ Superficial thrombophlebitis; ○ Venous thrombosis/occlusion (including stent thrombosis),; ○ Venous thromboembolic events (including PE); - Death
Timing | Studies with all durations of follow-up were included in the review, incorporating short-term (≤30 days), intermediate-term (31 days to 6 months), and long-term (>6 months) events
Settings | All clinical settings, Including Inpatient and outpatient (KQ 1 only)
Study design | - Original data; - RCTs, prospective and retrospective observational studies with comparator; - RCTs: sample size ≥20 subjects; - Observational studies: sample size ≥20 subjects for KQs 1 and 3; for KQ 2, sample size ≥500 subjects relevant to the KQ 2 population | Editorials, nonsystematic reviews, letters, case series, case reports, abstract only, articles that have been retracted or withdrawn
Publications | - English language only; - Published on or after January 1,2000; - Relevant systematic reviews, meta-analyses, or methods articles (used for background only)^a^ | Non-English language articles^b^

a Systematic reviews and meta-analyses were excluded from direct abstraction; those representing key sources were hand-searched as potential sources of additional citations to consider in the review.

b Non-English language articles were excluded due to: (1) the high volume of literature available in English language publications, (2) the focus of our review on applicability to populations in the United States, and (3) the scope of our KQs.

Abbreviations: AV=arteriovenous; AVVQ=Aberdeen Varicose Vein Questionnaire; CEAP=Clinical, Etiologic, Anatomic, Pathophysiologic; DUS=duplex ultrasound; DVT=deep vein thrombosis; KQ(s)=key question(s); LE=lower extremity; MRV=magnetic resonance venography; PE=pulmonary embolism; PICOTS=populations, interventions, comparators, outcomes, timing, settings; RCTs=randomized controlled trials; RFA=radiofrequency ablation; VCSS=Venous Clinical Severity Score

### Study Selection

For citations retrieved from PubMed, Embase, and the Cochrane Database of Systematic Reviews, two reviewers independently screened each title and abstract for potential relevance to the research questions using prespecified inclusion/exclusion criteria described in Table 4. Citations included by either reviewer underwent full-text screening.

At the full-text screening stage, two reviewers independently reviewed the full text of each article and indicated a decision to include or exclude the article for data abstraction. When paired reviewers arrived at different decisions about whether to include or exclude an article, or about the reason for exclusion, we reconciled the difference through review and discussion among investigators. Articles meeting eligibility criteria were included for data abstraction. We did not contact study authors for additional data. All screening results were tracked using the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada).

Appendix C provides a list of all articles included for data abstraction. Appendix D provides a list of articles excluded at the full-text screening stage, with reasons for exclusion.

### Data Extraction

The investigative team created abstraction forms that were programmed using the DistillerSR software. The abstraction forms were pilot-tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. Based on their clinical and methodological expertise, a pair of researchers were assigned to abstract data from each of the eligible articles. One researcher abstracted the data and the second over-read the article and the accompanying abstraction to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion if consensus could not be reached. We linked related studies to avoid duplication of patient cohorts.

We designed the data abstraction forms to collect the data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (intermediate, final, and adverse events outcomes). Particular attention was given to describing the details of the treatment (e.g., timing of therapy relative to venous thrombosis event, pharmacotherapy dosing, duration of pharmacotherapy, anatomic segment of interventional therapies), patient characteristics (e.g., symptom status via CEAP and Villalta scores, presence or absence of LE venous wounds, history of malignancy, age), and study design (e.g., randomized controlled trial [RCT] versus observational) that could be related to outcomes. Comparators were described carefully because treatment standards may have changed during the period covered by the review. The safety outcomes were framed to help identify adverse events, including those from drug therapies (such as bleeding), LE venous wound infections, and those resulting from procedural complications (including access site complications wound infections).

## Quality Assessment of Individual Studies

We assessed methodological quality, or risk of bias, for each individual study based on the Cochrane Risk of Bias tool for RCTs,^52^ and the Newcastle-Ottawa Scale for observational studies.^53^ Briefly, we rated each study as being of good, fair, or poor quality based on its adherence to well-accepted standard methodologies. For each study, one investigator assigned a summary quality rating, which was then reviewed by a second investigator; disagreements were resolved by consensus or by a third investigator if agreement could not be reached. Table 5 describes the overall study quality assessment ratings. Individual study quality ratings are provided in Appendix F.

Table 5 Definitions of overall quality ratings

Rating | Definition
Good (low risk of bias) | These studies had the least bias, and the results were considered valid. These studies adhered to the commonly held concepts of high quality, Including the following: a clear description of the population, setting, approaches, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytical methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
Fair (moderate risk of bias) | These studies were susceptible to some bias, but not enough to invalidate the results. They did not meet all the criteria required for a rating of good quality because they had some deficiencies, but no flaw was likely to cause major bias. The study may have been missing Information, making It difficult to assess limitations and potential problems.
Poor (high risk of bias) | These studies had significant flaws that might have invalidated the results. They had serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

The grading was outcome-specific such that a given study that analyzed its primary outcome well but did an incomplete analysis of a secondary outcome could be assigned a different quality grade for each of the two outcomes. Studies of different designs were graded within the context of their respective designs. Thus, RCTs were graded as good, fair, or poor, and observational studies were separately graded as good, fair, or poor (Appendix B).

For studies relevant to KQ 1, we also applied the Quality Assessment of Diagnostic Accuracy Studies-2 (QUADAS-2) tool for assessment of diagnostic accuracy studies.^54,55^ Table 6 describes the overall study quality assessment ratings used for this evidence.

Table 6 Definitions of overall quality ratings based on QUADAS-2 assessments

Rating | Definition
Low risk of bias | No major features that risk biased results. RCTs are considered a high-quality study design, but studies that include consecutive patients representative of the intended sample for whom diagnostic uncertainty exists may also meet this standard. A "low risk" study avoids the multiple biases to which medical test studies are subject (e.g., use of an inadequate reference standard, verification bias), and key study features are clearly described, including the comparison groups, outcomes measurements, and characteristics of patients who failed to have actual state (diagnosis or prognosis) verified.
Medium risk of bias | Susceptible to some bias, but flaws not sufficient to invalidate the results. The study does not meet all the criteria required for a rating of low risk, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
High risk of bias | Significant flaws imply biases of various types that may invalidate the results. The study has significant biases determined a priori to be major or "fatal" (i.e., likely to make the results either uninterpretable or invalid).

Abbreviations: QUADAS-2=Quality Assessment of Diagnostic Accuracy Studies-2; RCTs=randomized controlled trials

## Data Synthesis

We began by summarizing key features of the included studies for each KQ. To the degree that data were available, we abstracted information on study design; patient characteristics; clinical settings; interventions; and intermediate, final, and adverse event outcomes. We ordered our findings by treatment comparison and then within these comparisons by outcome with longterm final outcomes emphasized.

We reviewed and highlighted studies using a hierarchy-of-evidence approach. The best evidence available was the focus of our synthesis for each key question. If high quality evidence was not available, we described any lower quality evidence we were able to identify, but we underscored the issues that made it lower quality and the uncertainties in our findings. We assessed and stated whether the inclusion of lower quality studies would change any of our conclusions and performed sensitivity analyses excluding this evidence where appropriate.

We then determined the feasibility of completing a quantitative synthesis (i.e., metaanalysis). Feasibility was dependent on the volume of relevant literature (we required 3 appropriate studies to consider meta-analysis), conceptual homogeneity of the studies, and completeness of the reporting of results. If the above criteria were met and a meta-analysis was appropriate, we used random-effects models to synthesize the available evidence quantitatively. We tested for heterogeneity using graphical displays and test statistics (Q and I^2^ statistics), while recognizing that the ability of statistical methods to detect heterogeneity may have been limited. For comparison, we also performed fixed-effect meta-analyses. We present summary estimates, standard errors, and confidence intervals. We anticipated that intervention effects may be heterogeneous. We hypothesized that the methodological quality of individual studies, study type, the characteristics of the comparator, and patients’ underlying clinical presentation would be associated with the intervention effects. If there were sufficient studies, we performed subgroup analyses and/or meta-regression analyses to examine these hypotheses. We performed quantitative and qualitative syntheses separately by study type and discussed their consistency qualitatively.

## Strength of the Body of Evidence

We graded the strength of evidence (SOE) for each outcome assessed; thus, the SOE for two separate outcomes in a given study may be graded differently. The SOE was assessed using the approach described in AHRQ’s Methods Guide.^8,56,57^ in brief, the approach requires assessment of five domains: study limitations (previously named risk of bias), consistency, directness, precision, and reporting bias, which includes publication bias, outcome reporting, and analysis reporting bias, as described in detail above. Additional domains used when appropriate (most relevant to observational studies) were coherence, dose-response association, impact of plausible residual confounders, and strength of association (magnitude of effect). When the body of evidence for a particular outcome included both RCTs and observational studies, we graded each study type separately using design-specific criteria. In considering the overall strength of the entire body of evidence, we considered the extent to which the observational evidence was consistent with RCT data, particularly with regard to direction and magnitude of effect. Because of the risk of unmeasured confounding, observational studies generally would not contribute to estimates of the magnitude of effect, and judgment about the precision of the effect, when RCT data were available. If there were other issues (such as differences in when and where RCTs were performed compared to observational studies, and how these differences might affect applicability), this would generally lead to increased uncertainty about the magnitude and precision of any treatment effect.^58^ These domains were considered qualitatively, and a summary rating of high, moderate, or low SOE was assigned for each outcome after discussion by two reviewers. In some cases, high, moderate, or low ratings were impossible or imprudent to make, for example, when no evidence was available or when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn. In these situations, a grade of "insufficient" was assigned. This four-level rating scale consists of the definitions given in Table 7.

Table 7 Definition of SOE ratings

Rating | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Applicability

We assessed applicability across our KQs using the method described in AHRQ’s Methods Guide.^8,59^ In brief, this method uses the PICOTS format as a way to organize information relevant to applicability. The most important issue with respect to applicability is whether the outcomes were different across studies that recruit different populations (e.g., age groups, risk factors, comorbidities, characteristics of disease, U.S. vs. non-U.S. settings) or used different methods to implement the interventions of interest; that is, important characteristics were those that affected baseline (control group) rates of events, intervention group rates of events, or both. We used a checklist applied to each abstracted study to guide the assessment of applicability (Appendix B). For each study, one investigator assigned a summary quality rating, which was then reviewed by a second investigator; disagreements were resolved by consensus or by a third investigator if agreement could not be reached. We then used these data across KQs to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population in comparison to the target population, characteristics of the intervention used in comparison with care models currently in use, the possibility of treatment intervention learning curves, and clinical relevance and timing of the outcome measures. We summarize issues of applicability qualitatively.

## Peer Review and Public Commentary

Experts in the fields of cardiology, radiology, thrombosis, vascular medicine, vascular surgery, and public health were invited to provide external peer review of the draft report. AHRQ, CMS, and members of the TEP were also given the opportunity to provide comments. In addition, the draft report was posted on the AHRQ website for public comment from July 8, 2016, to August 3, 2016. We have addressed all reviewer comments, revising the text as appropriate, and have documented our responses in a disposition of comments report that will be made available 3 months after the Agency posts the final report on the EHC website. A list of peer reviewers submitting comments on the draft report is provided in the front matter of this report.