# Introduction

## Background

Lower extremity chronic venous disease (LECVD) is a heterogeneous term that encompasses a variety of conditions that are typically classified based on the CEAP classification, which defines LECVD based on Clinical, Etiologic, Anatomic, and Pathophysiologic parameters. This review focuses on treatment strategies for patients with LECVD, which is defined as patients who have had signs or symptoms of lower extremity (LE) venous disease for at least 3 months. Patients with LECVD can be asymptomatic or symptomatic, and they can exhibit a myriad of signs including varicose veins, telangiectasias, LE edema, skin changes, and/or ulceration. The etiology of LECVD includes venous dilation, venous reflux, (venous) valvular incompetence, mechanical compression (e.g., May-Thurner syndrome), and post-thrombotic syndrome. Because severity of disease and treatment are influenced by anatomic segment, LECVD is also categorized by anatomy (iliofemoral vs. infrainguinal veins) and type of veins (superficial veins, perforating veins, and deep veins). Finally, the pathophysiology of LECVD is designated typically as due to the presence of venous reflux, chronic unresolved thrombosis, and/or obstruction.

LECVD is common in the United States, where 25 million people have varicose veins, 2.5 million people have chronic venous insufficiency/incompetence, and the annual prevalence of venous thromboembolism (VTE, including both pulmonary embolism [PE] and deep vein thrombosis [DVT]) is approximately 1 million people.^1^ While the majority of patients with LECVD are asymptomatic, serious complications can occur, including LE amputation, acute and chronic VTE, chronic thromboembolic pulmonary hypertension, and mortality.^2^ A serious and common issue with LECVD is the formation of venous leg ulceration, affecting approximately 600,000 patients in the United States, and placing a burden on patients in terms of quality of life, pain, and social isolation. Furthermore, costs for the care of LECVD have increased substantially in the last few decades, with estimates in the United States of between $150 million and $1 billion per year.^3,4^ Definitions of selected terms are provided in Table 1.

Table 1 Definitions of terms

Term | Definition
Venous obstruction | Defined as partial or complete blockage of venous flow in any venous segment; can result from internal blockage (e.g.,thrombosis) or external compression of the vein
Venous reflux | Used to describe any retrograde venous flow in any venous segment; typically classified as (a) primary/idiopathic, (b)secondary (typically due to trauma, thrombosis, ormechanical/chemical/thermal etiologies), or (c) congenital
Venous thrombosis | Defined as the formation of a blood clot in any segment of the venous system; typically classified as deep or superficial
Chronic venous insufficiency/incompetence | Reserved for advanced venous disease, indicated by C3-C6 on the CEAP classification, and defined as morphologicalabnormalities of the venous system that lead to symptoms/signs(specifically, moderate-severe LE edema, skin changes, and/orvenous ulcers)
Post-thrombotic syndrome | Describes chronic venous symptoms and/or signs that occur as a result of DVT and its sequelae

Abbreviations: CEAP=Clinical, Etiologic, Anatomic, Pathophysiologic; DVT=deep vein thrombosis; LE=lower extremity

### Diagnosis

Adding complexity to a heterogeneous disorder, a multitude of diagnostic tests are currently used to diagnose acute and chronic venous disease.^5^ A high index of suspicion and good clinical judgment often lead clinicians to diagnose acute and chronic venous disease using physical examination alone. After performing a thorough history and physical examination, venous duplex ultrasound (DUS); B-mode imaging and pulsed Doppler ultrasound with and without compression) is the most common diagnostic test performed. Other noninvasive tests (air plethysmography, computed tomography venography [CTV], magnetic resonance venography [MRV]) are also used to confirm the diagnosis and evaluate for anatomic or structural abnormalities. Contrast venography (also termed invasive venography, ascending or descending venography, and phlebography) and intravascular ultrasound (IVUS) are commonly utilized invasive tests, and their use is often reserved for patients undergoing endovascular or surgical management of LECVD.

#### Adverse Effects of Diagnosis

The diagnosis of LECVD as the underlying cause of LE edema, skin changes, and/or ulceration often leads clinicians and patients down a pathway of invasive procedures in an attempt to correct the problem. Hence, a misdiagnosis of LECVD could lead to unnecessary invasive procedures for venous abnormalities or underdiagnosis of other treatable conditions that mimic LECVD, such as peripheral artery disease (PAD; e.g., critical limb ischemia), lymphedema, or congestive heart failure. Eliminating PAD as an underlying cause of symptoms (e.g., ulceration) is important because (a) untreated critical limb ischemia due to PAD often leads to LE amputation, and (b) compression therapy for LECVD is contraindicated in the presence of significant obstructive arterial disease.

### Classification of LECVD

The most common classification scheme for LECVD is the CEAP classification, shown in Table 2.^6,7^

Table 2 Clinical, Etiologic, Anatomic, Pathophysiologic(CEAP) classification for chronic venous disease

Clinical (C)^a^ | Etiologic (E) | Anatomic (A) | Pathophysiologic (P)
C_0_ No visible sign of venous disease | E_c_ Congenital | A_s_ Superficial | P_r_ Reflux
C_1_ Telangectasia or reticular veins | E_p_ Primary | A_d_ Deep | P_o_ Obstruction, chronic unresolved thrombosis
C_2_ Varicose veins | E_s_ Secondary (e.g., post-thrombotic, trauma) | A_p_ Perforator | P_r,o_ Reflux and obstruction
C_3_ Edema | E_n_ No venous cause identified | A_n_ No venous location identified | P_n_ No venous pathophysiology identified
C_4_ Changes in skin and subcutaneous tissue A Pigmentation oreczema B Lipodermatosclerosis or atrophie blanche | - | - | -
C_5_ Healed ulcer | - | - | -
C_6_ Active ulcer | - | - | -

a The descriptor A (asymptomatic) and S (symptomatic) is placed after the C (clinical classification).

### Treatment Strategies

The treatment of LECVD varies tremendously and can be divided into noninvasive and invasive therapies. Noninvasive approaches include therapies that improve venous circulation and reduce LE edema (e.g., compression devices, medical therapy [e.g., diuretics], and exercise), therapies that prevent thromboembolic complications (e.g., anticoagulation), and therapies that specifically address skin changes and ulceration (e.g., wound care). When these more conservative measures fail, invasive therapies are often recommended and include endovascular intervention (e.g., ablation, angioplasty) and/or surgical management (e.g., venous ligation, venous excision). Table 3 lists and briefly describes all of the treatments considered in this review. While compression therapy is the mainstay of treatment for LECVD, the use of endovascular and surgical techniques has increased dramatically over the last decade. The wide variation in how patients are treated around the United States suggests that the present systematic review is warranted. This review formally evaluates the evidence supporting the harms and benefits of all the treatments listed in Table 3 and will allow more evidence-based and consistent care for patients. For this review, we considered all adult patients with LECVD (asymptomatic and symptomatic), all diagnostic tests, and all forms of treatment.

Table 3 Available treatments for LECVD

Name of Treatment | Description of Treatment
Noninvasive Interventions
Exercise Training | Supervised or unsupervised (home) exercise training that aims to improve ankle range of motion and calf muscle pump function
Medical Therapy - Diuretics | Medications used to remove fluid from the body through the kidneys
Medical Therapy - Anticoagulants | Blood thinning medications used to prevent blood clot formation or treat in situ blood clots
Weight Reduction | Reduction in body weight with lifestyle modifications (e.g., diet, exercise) or bariatric surgery
Compression Therapy | The use of stockings, bandages, and/or pneumatic compression devices to improve venous function.
Skin/Wound Care | The delivery of active or interactive substances (e.g., growth factors, antibiotics) to the skin or wound of the LE
Endovenous Interventions
Endovenous laser ablation (EVLA) | Removal or destruction of a vein or vein segment by means of laser
Mechanochemical ablation | Removal or destruction of a vein or vein segment by mechanochemical means
Radiofrequency ablation (RFA) | Removal or destruction of a vein or vein segment by means of radiofrequency energy
Cyanoacrylate embolization | Occlusion of a vein or vein segment by means of injection of cyanoacrylate (CA)
Sclerotherapy (liquid or foam) | Obliteration of a vein or vein segment by chemical introduction (liquid or foam)
Surgical Interventions
High Ligation | Ligation and division typically of the great saphenous vein (GSV) at its junction with the common femoral vein, including ligation and divisionof GSV branches
Stripping | Removal of a long vein segment, usually segments of the GSV or the small saphenous vein (SSV)
Phlebectomy | Removal of a vein segment through a small skin incision
Cure Conservatrice et Hemodynamique de I’lnsufficience Veineuse enAmbulatoire (CHIVA) | Conservative and ambulatory treatment of varicose veins that preserves the architecture of the venous structure through selectivesurgical ligation of venous structures
Cryostripping | A surgical procedure in which a rigid cryoprobe is inserted into the GSV, the GSV is frozen with liquid nitrous oxide, and the probe is thenused to remove the GSV

Abbreviations: CA=cyanoacrylate; CHIVA=Cure conservatrice et Hemodynamique de l’Insuffisance Veineuse en Ambulatoire; EVLA=endovenous laser ablation; GSV=great saphenous vein; LE=lower extremity; LECVD=lower extremity chronic venous disease; RFA=radiofrequency ablation; SSV=small saphenous vein

After patients are diagnosed with LECVD and an initial treatment strategy is determined, symptoms are monitored clinically with subjective and objective measures as specified in the CEAP classification score and the Venous Clinical Severity Score (VCSS). More specifically, pretreatment and post-treatment vascular laboratory testing is compared, including venous refilling time (VRT) and/or ambulatory venous pressure (AVP). Patients with venous insufficiency/incompetence/reflux typically undergo air plethysmography and DUS. Patients undergoing treatment for chronic venous thrombosis/obstruction normally undergo measurements of venous flow via DUS or venography for assessment of patency and/or amount of reflux.

While symptoms and venous hemodynamics are important, outcomes such as ulcer healing, prevention of recurrences of LE ulcers, and need for LE amputation are often measured at intermediate-term (6-12 months) and long-term (>12 months) time points. Similarly, quality-of life scores (e.g., Aberdeen Varicose Vein Questionnaire [AVVQ] and VCSS) and need for repeat intervention are also measured at similar time points.

#### Adverse Effects of Treatment

The adverse effects of treatments for patients with LECVD depend on the specific type of treatment utilized. Complications from invasive (endovenous and surgical) interventions include bleeding, infection, vessel dissection and perforation, venous thrombosis/thromboembolic events, and death. Adverse effects of noninvasive treatments include bleeding due to antithrombotic medications, exercise-related harms, and venous thrombosis/thromboembolic events. Adverse effects of undertreatment may include decreased patient quality of life, venous ulceration, failure to heal venous ulceration, superinfection and potentially amputation.

## Scope and Key Questions

### Scope of the Review

This systematic review focuses on the diagnosis and management of LECVD in outpatient and inpatient settings where care is coordinated by primary care physicians, vascular surgeons, vascular medicine specialists, cardiologists, and/or radiologists. All adult patients with LECVD are included in the analyses.

#### Rationale and Context

There is substantial variation in how patients with LECVD are diagnosed and treated. In the past in the United States, general surgeons and vascular surgeons often diagnosed and treated patients with LECVD; now, however, primary care physicians, cardiologists, vascular medicine specialists, interventional radiologists, and others with and without formal training in venous care also diagnose and manage these patients. Other reasons for differences in diagnostic and treatment strategies exist and include: patient characteristics and preferences, reimbursement rates for diagnostic tests and treatment modalities, and the clinical care location of these diagnostic tests and invasive procedures (as this dictates reimbursement, specifically when physicians own the office-based clinics or ambulatory surgery centers where the procedures are performed). The evidence supporting the optimal diagnosis and treatment of peripheral venous disease is uncertain and a systematic review of the evidence base is timely both in terms of its potential impact on clinical care and on policy. As such, this systematic review was proposed as a large Technology Assessment by the Centers for Medicare and Medicaid Services (CMS). The main goal of this systematic review is to assess the clinical effectiveness and safety of each diagnostic testing modality and treatment modality for LECVD and identify whether specific patient or treatment characteristics are associated with improved outcomes.

Controversies around the treatment of LECVD include the following:

- In many instances, patients present with a combination of signs/symptoms (e.g., venous obstruction and thrombosis; venous obstruction and reflux) that lead to overlap in nomenclature and classification.
- Population inclusion and exclusion criteria have varied among studies, and stratification based on symptom status, presence of wounds, and other patient-specific factors is important.
- Measurement of outcomes has been variable in clinical studies of treatment strategies of patients with LECVD.
- There is a lack of data regarding the proportion of patients that progress from asymptomatic LECVD to symptomatic LECVD (especially leg pain and venous ulceration).
- There is a lack of data regarding the safety of treatment modalities in patients with LECVD.
- Improvements in both surgical and endovenous technologies have made direct comparison between “state-of-the-art” strategies more challenging.
- There is a lack of data regarding the use of disease-specific quality-of-life surveys and health outcomes in the care of LECVD.
- There is a lack of data focusing on LECVD in the Medicare and Medicaid population. How generalizable is existing evidence to this population of interest?

### Key Questions (KQs)

KQ 1: Narrative review of the diagnostic methods and diagnostic criteria for all adult patients (symptomatic and asymptomatic) with LE varicose veins, LE chronic venous insufficiency/incompetence/reflux, and/or LE chronic venous thrombosis/obstruction (including post-thrombotic syndrome).

KQ 2: Regarding treatments for all adult patients (symptomatic and asymptomatic) with [underlined: LE varicose veins and/or LE chronic venous insufficiency/incompetence/reflux]:

2a. What is the comparative effectiveness of exercise, medical therapy, weight reduction, mechanical compression therapy, and invasive procedures (i.e., surgical and endovascular procedures) on health outcomes?

2b. What diagnostic method(s) and criteria were used in each study?

2c. How does the comparative effectiveness of treatment vary by patient characteristics, including age, sex, risk factors, comorbidities, characteristics of disease, anatomic segment affected, and characteristics of the therapy (e.g., exercise intensity, type of mechanical compression)?

2d. What are the comparative safety concerns associated with each treatment strategy (e.g., adverse drug reactions, bleeding)? Do the safety concerns vary by patient subgroup (age, sex, race, risk factors, comorbidities, anatomic segment, or disease severity)?

KQ 3: Regarding treatments for all adult patients (symptomatic and asymptomatic) with [underlined: LE chronic venous thrombosis/obstruction (including post-thrombotic syndrome)]:

3a. What is the comparative effectiveness of exercise, medical therapy, mechanical compression therapy, and invasive procedures (i.e., surgical and endovascular procedures) on health outcomes?

3b. What diagnostic method(s) and criteria were used in each study?

3c. How does the comparative effectiveness of treatment vary by patient characteristics, including age, sex, risk factors, comorbidities, characteristics of disease, anatomic segment affected, and characteristics of the therapy (e.g., exercise intensity, type of mechanical compression)?

3d. What are the comparative safety concerns associated with each treatment strategy (e.g., adverse drug reactions, bleeding)? Do the safety concerns vary by patient subgroup (age, sex, race, risk factors, comorbidities, anatomic segment, or disease severity)?

#### Analytic Framework

The analytic framework presented in Figure 1 illustrates the population, interventions, outcomes, and adverse effects that guided the literature search and synthesis. This figure shows how adults without known chronic venous disease may be diagnosed and treated, and how treatment is associated with a range of potential adverse effects and outcomes. Separate KQs were developed regarding the accuracy of various diagnostic strategies, and the effectiveness and risk of adverse events associated with pharmacologic, lifestyle, and invasive therapies.

Figure 1 Analytic framework

Abbreviations: AV=arteriovenous; CEAP=Clinical, Etiologic, Anatomic, Pathophysiologic; KQ=key question; LE=lower extremity; PE=pulmonary embolism; VCSS=Venous Clinical Severity Score

## Organization of This Report

The remainder of the report details our methodology and presents the results of our literature synthesis, with summary tables and strength of evidence grading for major comparisons and outcomes. In the discussion section, we offer our conclusions, summarized findings, and other information that may be relevant to translating this work for clinical practice and future research.

Appendices provide further details on our methods and the studies we assessed, as follows:

- Appendix A. Exact Search Strings
- Appendix B. Data Abstraction Elements
- Appendix C. List of Included Studies
- Appendix D. List of Excluded Studies
- Appendix E. Key to Included Primary and Companion Articles
- Appendix F. Characteristics of Included Studies

A list of abbreviations and acronyms is provided at the end of the report.