# Appendix F Characteristics of Included Studies

Appendix Table F-1 Study Characteristics—KQ 1

Author, Year | Study Details | Diagnostic Method(s) | Outcomes Results
Antoch, 2002^1^ | Study Design: observational Quality: Fair QUADAS-2: Medium risk of bias Location: UK/Europe [underlined: Populatlon] Symptom Status: Unclear/NR Condltlon(s): LE chronic venous Insufficiency/reflux/Incompetency Total N: 50 N Completed: 50 % Female: Unclear/NR Mean Age: 51 | Color doppler ultrasonagraphy vs. Ascending phlebography vs. Surgical Evaluation (gold standard) | For color doppler ultrasound: Sensitivity=80%; Specificity=74%, Accuracy not reported Individually; Ascending phlebography: Sensitivity=66%; Clinical examination: Sensitivity=79%
Depalma, 2000^2^ | Study Design: observational Quality: Fair QUADAS-2: Medium risk of bias Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous Insufficiency/reflux/Incompetency Total N: 33 N Completed: 33 % Female: 0% Mean Age: 55 | Color doppler ultrasound vs. Ascending and descending phlebography (gold standard) | For complete occlusion: Sensitivity=100%; Specificity=100%; For postphlebetic changes: Sensitivity=63%; Specificity=100%; PPV=100%; NPV=53%; For reflux detection: Sensitivity=82%; Specificity=75%; PPV=96%; NPV=37%; For saphenous reflux: Sensitivity=95%; Specificity= 100%
Kayilioglu, 2016^3^ | Study Design: observational Quality: Good QUADAS-2: Low risk of bias Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE venous thrombosis/ obstruction; PTS Total N: 86 N Completed: 86 % Female: 26.7% Mean Age: 40.3 | Doppler ultrasound vs. Venography + IVUS (gold standard) | Sensitivity=62.5%; Specificity=71.0%; PPV=73.0%; NPV=60.0%
Kurstjens, 2016^4^ | Study Design: observational Quality: Fair QUADAS-2: Low risk of bias Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic; Asymptomatic Condition(s): LE venous thrombosis/ obstruction; PTS Total N: 262 N Completed: 248 % Female: 62.5% Mean Age: 45.5 | Air Plethysmography vs. Doppler ultrasound + MRV vs. Doppler ultrasound + CTV (3 limbs) vs. Doppler ultrasound (10 limbs) (gold standard unclear) | outflow fraction by APG: Sensitivity=34.8%, Specificity=87.5%, PPV=89.9%, NPV=29.6%, LR(+)=2.78, LR(-)=0.75 Ejection fraction by APG: Sensitivity=64.3%, Specificity=48.3%, PPV=78.8%, NPV=31.2%, LR(+)=1.24, LR(-)=0.74 Residual volume fraction by APG: Sensitivity=44.7%, Specificity=46.7%, PPV=71.4%, NPV=22.1%, LR(+)=0.84, LR(-)=1.19"
Lee, 2008^5^ | Study Design: observational Quality: Fair QUADAS-2: Medium risk of bias Location: Asia [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins Total N: 100 N Completed: 100 % Female: 55% Mean Age: 54.9 | 3-D CTV vs. Doppler Sonography (gold standard) | GSV: Sensitivity=98.2%; Specificity=83.3%; SSV: Sensitivity=53.3%; Specificity=94.9%
Mantoni, 2002^6^ | Study Design: observational Quality: Fair QUADAS-2: Medium risk of bias Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE chronic venous insufficiency/reflux/Incompetency Total N: 39 N Completed: 38 % Female: 39% Mean Age: 67 | Ascending phlebography vs. Descending phlebography vs. Continuous wave Doppler vs. Ambulatory strain gauge plethysmography vs. Triplex ultrasound (TUS) (gold standard) | For common and superficial venous system: Sensitivity=86%(AP), 70%(CWD), 4%(ASGP); Specificity=0%(AP), 38%(CWD), 100%(ASGP). For popliteal vein: Sensitivity=83%(AP), 48%(CWD), 5%(ASGP); Specificity=17%(AP), 75%(CWD), 100%(ASGP)
Massenburg, 2015^7^ | Study Design: observational Quality: Fair QUADAS-2: Medium risk of bias Location: U.S. [underlined: Population] Symptom Status: Symptomatic; LE venous thrombosis/obstruction Total N: 46 N Completed: 46 % Female: 58%, 64% Mean Age: 64, 59 | Magnetic resonance venography vs. Invasive venography + IVUS (gold standard) | Sensitivity=100%; Specificity=22.7%; PPV=58.5%; NPV=100%; False Positive rate=41.5%
Meyer, 2000^8^ | Study Design: observational Quality: Poor QUADAS-2: High risk of bias Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 87 N Completed: 87 % Female: 50.4% Mean Age: 56 | Duplex ultrasound vs. Ascending phlebography vs. Surgical evaluation (gold standard) | Cockett I (p=1.0); Cockett II (p= 0.569); Cockett III (p=1.0)
Mousa, 2016^9^ | Study Design: observational Quality: Fair QUADAS-2: Medium risk of bias Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE venous thrombosis/ obstruction; PTS Total N: 36 N Completed: 36 % Female: 72.2% Median Age: 61.2 | Doppler ultrasound vs. Venography + IVUS (gold standard) | The area under the curve for using CFV reflux vales (by VDUS) to predict IVUS iliac stenosis was 0.77 (P=.001) determined by RoC curve analysis
Rabahie, 2011^10^ | Study Design: observational Quality: Fair QUADAS-2: Medium risk of bias Location: Latin America [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 30 N Completed: 30 % Female: 90% Mean Age: 53.7 | Color doppler ultrasound vs. Surgical evaluation (gold standard) | GSV: Sensitivity=70.3%; False-negative rate=29.7%

Abbreviations: CTV=computed tomography venography; IVUS=intravascular ultrasound; GSV=great saphenous vein; LE=lower extremity; MRV=magnetic resonance venography; NR=not reported; PTS=Post-thrombotic Syndrome

Appendix Table F-2 Study Characteristics—KQ 2

Author, Year Trial Companion Articles | Study Details^*^ | Interventions | Diagnostic Method(s) and Criteria | outcomes (Subgroups analyzed)
Abela, 2008^11^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/Incompetency Total N: 82 N Completed: 82 % Female: 61% Median Age: 44 | High Ligation + Invagination Stripping vs. High Ligation + Foam Sclerotherapy | Clinical assessment; Ultrasound | Bleeding
Aguilar-Ferrandiz, 2013^12^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/Incompetency Total N: 123 N Completed: 123 % Female: 100%, 100% Mean Age: 66.05, 63.32 | Mixed Klneslo Taping vs. Placebo Taping | Clinical assessment | Patient-reported QOL (Including AVVQ); Changes on standardized symptom scores; Qualitative reduction In LE edema; Recurrent ulceration; Qualitative reduction In LE pain
Aguilar-Ferrandiz, 2014^13^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 120 N Completed: 104 % Female: 100%, 100% Mean Age: 64.4, 66.48 | Mixed Kineslo Taping vs. Placebo Taping | Clinical assessment | Patient-reported QOL); Changes on standardized symptom scores; Qualitative reduction In LE edema; Improvement in LE venous hemodynamlcs/reflux severity; Qualitative reduction In LE pain
Aguilar-Ferrandiz, 2014^14^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic; Asymptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 130 N Completed: 130 % Female: 100%, 100% Mean Age: 64.4, 66.48 | Mixed Klnesio Taping vs. Placebo Taping | Clinical assessment | Changes on standardized symptom scores; Patient-reported QOL
Al Shammeri, 2014^15^ | Study Design: RCT Quality: Poor Location: Middle East [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 100 N Completed: 75 % Female: 75.4% Mean Age: 43.9 | Compression Stockings vs. Standard Medical Therapy | Unclear/NR | Changes on standardized symptom scores
Almeida, 2009^16^ RECOVERY | Study Design: RCT Quality: Poor Location: U.S.,UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 69 N Completed: 69 % Female: 82.9%, 75.6% Mean Age: 51.6, 52.4 | EVLA vs. RFA | Ultrasound | Thrombophlebitis; Changes on standardized symptom scores; Patient-reported QOL; Venous thromboembolic events; Thrombophlebitis
Barwell, 2004^17^ ESCHAR Companions: Gohel, 2007^18^ Gohel, 2005^19^ Gohel, 2005^20^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 500 N Completed: 460 % Female: 60%, 56% Median Age: 74, 72 | Mechanical Compression vs. Surgical Stripping + Avulsions + Compression | Clinical assessment; Ultrasound | Venous wound healing; Death; Venous wound Infection; Venous thrombosis; Bleeding; Improvement in LE venous hemodynamlcs/reflux severity
Basela, 2011^21^ | Study Design: RCT Quality: Poor Location: Middle East [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 174 N Completed: 174 % Female: 40%, 40% Mean Age: 32.8, 34.45 | High Ligation + Stripping vs. EVLA | Clinical assessment; Ultrasound | Bleeding; Qualitative reduction In LE edema; Radiation-related injuries; Improvement in LE venous hemodynamlcs/reflux severity; Thrombophlebitis; Venous wound Infection
Belcaro. 2000^22^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 150 N Completed: 121 % Female: 44%, 48% Mean Age: 52,53 | High Ligation + Stripping vs. Liquid/Foam Sclerotherapy | Ultrasound | Improvement in LE venous hemodynamics/reflux severity
Belcaro, 2003^23^ VEDICO Companions: Belcaro, 2003^24^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins Total N: 887 N Completed: 749 % Female: 67%, 69%, 68%, 70%, 69%, 68% Mean Age: 44.4, 45, 44, 45, 42, 42 | Ligation + Stripping vs. High Ligation + Stripping vs. Stripping vs. Foam Sclerotherapy +/- Ligation | Ultrasound | Improvement in LE venous hemodynamics/reflux severity
Belcaro, 2015^25^ | Study Design: observational Quality: Poor Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 852 N Completed: 711 % Female: 55.7%, 53.9%, 52.2%, 43.9% Mean Age: 43.2, 44.2, 43.7, 44.7 | Mini-ligation vs. Ligation + Stripping vs. Compression Sclerotherapy vs. Mini-ligation + Sclerotherapy. | Ultrasound | Improvement in LE venous hemodynamlcs/reflux severity; Repeat Intervention, Venous thrombosis
Benarroch-Gampel, 2013^26^ | Study Design: observational Quality: Fair Location: U.S. [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE chronic venous Insufficiency/reflux/incompetency Total N: 3,874 N Completed: 3,874 % Female: 70.9%, 29% Mean Age: 53.8, 51.8 | EVLA +/- Phlebectomy vs. RFA +/- Phlebectomy | Unclear/NR | Venous thromboembolic events (Anatomic Segment)
Biemans, 2013^27^ MAGNA Trial Companions: van der Velden, 2015^28^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 240 N Completed: 223 % Female: 69%, 68%, 68% Mean Age: 49, 56 | EVLA vs. Foam Sclerotherapy vs. High Ligation + Stripping | Ultrasound | Venous wound infection; Venous thromboembolic events; Periprocedural complications; Repeat intervention; Venous thrombosis; Patient-reported QOL; Changes on standardized symptom scores
Bountouroglou, 2006^29^ Companions: Kalodiki, 2012^30^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 73 N Completed: 59 % Female: 74%, 59% Median Age: 49, 47 | Surgical Stripping + Venous ligation vs. Foam sclerotherapy + venous ligation | Unclear/NR | Periprocedural complications; Bleeding; Repeat intervention; Venous thromboembolic events; Improvement in LE venous hemodynamics/reflux severity; Thrombophlebitis; Changes on standardized symptom scores; Patient-reported QOL
Brittenden, 2014^31^ CLASS Companions: Brittenden, 2015^32^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 798 N Completed: 670 % Female: 57.1%, 56.6%, 56.4% Mean Age: 49.7, 49, 49.2 | High Ligation + Stripping vs. EVLA vs. Foam Sclerotherapy | Ultrasound | Patient-reported QOL; Changes on standardized symptom score;s Improvement in LE venous hemodynamics/reflux severity
Campos, 2015,^33^ | Study Design: RCT Quality: Good Location: Latin America [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 58 N Completed: 51 % Female: 82%, 65% Mean Age: 46.7, 52 | High Ligation + Stripping vs. Foam Sclerotherapy + Ligation | Ultrasound | Venous wound healing; Recurrent ulceration; Changes on standardized symptom scores; Patient-reported QOL
Carpentier, 2014^34^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 425 N Completed: 390 % Female: 56%, 57% Mean Age: 65.1, 63.5 | Bathing therapy (Balneotherapy) vs. Waitlist Control Group | Clinical assessment; Ultrasound | Recurrent ulceration; Exercise-related harms; Venous thromboembolic events; Changes on standardized symptom scores; Patient-reported QOL (CEAP Classification)
Carradice, 2009^35^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 50 N Completed: 41 % Female: 68%, 84% Mean Age: 51.1, 52.4 | EVLA vs. EVLA + Phlebectomy | Ultrasound | Patient-reported QOL; Changes on standardized symptom scores; Repeat Intervention
Carradice, 2011^36^ HELP-1 Companions: Carradice, 2011^37^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 280 N Completed: 237 % Female: 66%, 61% Mean Age: 49 | Phlebectomy + Surgical Stripping + Ligation vs. EVLA + Phlebectomy | Ultrasound | Patient-reported QOL; Changes on standardized symptom scores; Perlprocedural complications; Bleeding; Thrombophlebitis; Qualitative reduction In LE pain; Venous thromboembolic events
Carruthers, 2014^38^ | Study Design: observational Quality: Fair Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): Unclear/NR Total N: 4,366 N Completed: 4,366 % Female: 66.4% Mean Age: 52.4 | High Ligation + Stripping vs. RFA vs. EVLA | ICD-9 codes | Periprocedural complications; Venous thrombosis
Christenson, 2010^39^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 204 N Completed: 200 % Female: NR Mean Age: 46.3, 44.6 | Ligation +Stripping vs. Foam Sclerotherpy | Ultrasound, CEAP grade 2-6 | Changes on standardized symptom scores; Patient-reported QOL; Improvement in LE venous hemodynamics/reflux severity; Repeat Intervention; Qualitative reduction In LE pain; Venous thromboembolic events; Bleeding; Periprocedural complications; Thrombophlebitis; Radiation-related injuries
Clarke-Moloney, 2005^40^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous Insufficiency/reflux/incompetency Total N: 200 N Completed: 180 % Female: NR Age: NR | Compression vs. Compression | Clinical assessment | Patient-reported QOL; Venous wound healing
Coccheri, 2002^41^ SUAVIS | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous Insufficiency/reflux/incompetency Total N: 235 N Completed: 230 % Female: 56%, 52% Mean Age: 63.18, 64.18 | Sulodexlde + Compression vs. Placebo + Compression | Clinical assessment | Venous wound healing
Darwood, 2008^42^ | Study Design: RCT Quality: Poor Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 136 N Completed: 103 % Female: 45%, 38%, 36% Median Age: 42, 52, 49 | High Ligation + Stripping vs. EVLA | Ultrasound | Improvement In LE venous hemodynamics/reflux severity; Thrombophlebitis; Periprocedural complications; Bleeding; Qualitative reduction in LE pain; Patient-reported QOL; Changes on standardized symptom scores
De Franciscis, 2013^43^ | Study Design: observational Quality: Poor Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 11,026 N Completed: 11,026 % Female: 68%, 59% Median Age: 45, 46.5 | RFA +/- Phlebectomy vs. EVLA +/- Phlebectomy | Clinical assessment; Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Qualitative reduction In LE pain; Qualitative reduction In LE edema
de Roos, 2003^44^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins Total N: 82 N Completed: 80 % Female: 98% Mean Age: 42.1 | Phlebectomy vs. Liquid Sclerotherapy | Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Bleeding; Thrombophlebitis; Repeat Intervention
del Rio Sola, 2012^45^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous Insufficiency/reflux/Incompetency Total N: 51 N Completed: 51 % Female: 44%, 68% Mean Age: 60.5, 58.59 | Aspirin + Compression vs. Compression | Clinical assessment | Recurrent Ulceration
Dlsselhoff, 2008^46^ Companions: Dlsselhoff, 2009^47^ Dlsselhoff, 2011^48^ | Study Design: RCT Quality: Good; Fair for 5 year outcomes Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/Incompetency Total N: 120 N Completed: 111 % Female: 68%, 70% Mean Age: 46, 49 | EVLA vs. Cryostrlpplng | Ultrasound | Changes on standardized symptom scores; Qualitative reduction in LE pain; Improvement In LE venous hemodynamics/reflux severity; Venous thrombosis; Repeat Intervention
Elderman, 2014^49^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 111 N Completed: 79 % Female: 82%, 80% Mean Age: 54.87, 50.93 | EVLA vs. EVLA + Compression | Clinical assessment; Ultrasound | Patient-reported QOL; Qualitative reduction in LE pain
Figueiredo, 2009^50^ | Study Design: RCT Quality: Fair Location: Latin America [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins Total N: 60 N Completed: 56 % Female: 79%, 85% Mean Age: 49, 53 | High Ligation + Stripping vs. Foam Sclerotherapy | CEAP great C5EpAsPr (healed venous ulcer) | Changes on standardized symptom scores
Flessenkamper, 2013^51^ REVAS Companions: Flessenkamper, 2016^52^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 449 N Completed: 449 % Female: 70% Mean Age: 48 | High Ligation + Stripping vs. EVLA vs. EVLA + Ligation | Clinical assessment; Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Changes on standardized symptom scores; Venous thrombosis; Periprocedural complications; Qualitative reduction in LE pain; Bleeding
Franek, 2006^53^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous Insufficiency/reflux/incompetency Total N: 110 N Completed: 110 % Female: 63%, 52% Mean Age: 65, 61 | Compression + drug therapy vs. High Ligation + Stripping + Phlebectomy + Compression + Drug Therapy | Clinical assessment; Ultrasound | Venous wound healing
Gale, 2010^54^ | Study Design: RCT Quality: Fair Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous Insufficiency/reflux/Incompetency Total N: 118 N Completed: 106 % Female: 75%, 63%, 83% Mean Age: 49, 46, 54 | EVLA vs. RFA | Ultrasound | Venous thrombosis; Improvement In LE venous hemodynamics/reflux severity; Changes on standardized symptom scores; Patient-reported QOL; Periprocedural complications; Repeat Intervention
Gibson, 2016^55^ Varlthena 013 | Study Design: RCT Quality: Good Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins, LE chronic venous Insufficiency/reflux/Incompetency Total N: 77 N Completed: 77 % Female: 80.5% Mean Age: 45.1 | Varlthena 1% (Foam Sclerotherapy) vs. Placebo saline Injections | CEAP grade 2-5 | Venous thrombosis; Changes on standardized symptom scores; Patient-reported QOL; Qualitative reduction In LE pain; Qualitative reduction In LE edema
Goode, 2010^56^ LARA | Study Design: RCT Quality: Poor Location: UK/Europe [underlined: Population] Symptomatic; Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 66 N Completed: 66 % Female: 68%, 65% Mean Age: 48.6, 45 | EVLA vs. RFA | Ultrasound | Improvement in LE venous hemodynamics/reflux severity
Guest, 2003^57^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 76 N Completed: 76 % Female: 59%, 67% Mean Age: 68, 67 | High Ligation + Stripping or SEPS vs. Compression | Clinical assessment; Ultrasound | Death; Venous wound Infection; Venous wound healing; Patient-reported QOL
Hamel-Desnos, 2010^58^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic; Condition(s): LE varicose veins Total N: 60 N Completed: 60 % Female: 97%, 87% Mean Age: 53, 61 | Foam Sclerotherapy vs. Foam Sclerotherapy + Compression | Clinical assessment; Ultrasound | Changes on standardized symptom scores
Helmy ElKaffas, 2011^59^ | Study Design: RCT Quality: Poor Location: Africa [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 180 N Completed: 178 % Female: 47%, 50% Mean Age: 33.1, 34.9 | High Ligation + Stripping vs. RFA | Ultrasound | Thrombophlebitis; Bleeding; Venous thromboembolic events; Changes on standardized symptom scores; Improvement in LE venous hemodynamics/reflux severity; Qualitative reduction in LE pain; Periprocedural complications
Houtermans-Auckel, 2009^60^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 104 N Completed: 96 % Female: 63%, 73% Mean Age: 49, 50 | GSV Stripping + Elastic Bandaging for 3 days vs. Elastic bandaging for 4 weeks | Clinical assessment; Ultrasound | Qualitative reduction In LE edema; Changes on standardized symptom scores
Jull, 2009^61^ | Study Design: RCT Quality: Fair Location: Australla/N.Z. [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 40 N Completed: 39 % Female: 68% Mean Age: 54.6 | Exercise + Compression vs. Usual Care + Compression | Clinical assessment | Venous wound healing; Exercise-related harms
Kahle, 2004^62^ | Study Design: RCT Quality: Poor Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 25 N Completed: 25 % Female: 72% Mean Age: 55.5 | Compression vs. Sclerotherapy + Compression | Ultrasound | Improvement in LE venous hemodynamics/reflux severity
Kalteis, 2008^63^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 100 N Completed: 95 % Female: 79%, 71% Mean Age: 46, 46.5 | Compression + Stripping vs. Compression + EVLA | Ultrasound | Bleeding; Patient-reported QOL; Qualitative reduction in LE pain; Qualitative reduction In LE edema; Thrombophlebitis; Improvement in LE venous hemodynamics/reflux severity; Venous thrombosis; Changes on standardized symptom scores; Repeat Intervention
King, 2015^64^ VANISH-1 | Study Design: RCT Quality: Good Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 284 N Completed: 279 % Female: 74.6% Mean Age: 48.9 | Sclerotherapy vs. Placebo | Ultrasound | Changes on standardized symptom scores; Improvement in LE venous hemodynamics/reflux severity; Patient-reported QOL
Klem, 2009^65^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 536 N Completed: 445 % Female: 79%, 71% Mean Age: 56, 54 | High Ligation + Stripping vs. High Ligation + Cryostripping | Clinical assessment; Ultrasound | Patient-reported QOL; Changes on standardized symptom scores
Kumar, 2002^66^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous Insufficiency/reflux/incompetency Total N: 100 N Completed: 92 % Female: NR Mean Age: 72, 65, 73, 69 | Compression vs. Compression | Clinical assessment | Venous wound healing; Recurrent ulceration
Lane, 2016^67^ Companions: Bootun, 2016^68^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 170 N Completed: 121 % Female: 58.8% Median Age: 50 | Mechanical Endovenous Ablation (MoCA) vs. RFA | Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Patient-reported QOL; Changes on standardized symptom scores; Thrombophlebitis; Venous thrombosis (including stent thrombosis)
Lattimer, 2013^69^ Companions: Lattimer, 2012^70^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 110 N Completed: 90 % Female: 61%, 54% Mean Age: 47.3, 49.6 | EVLA vs. Sclerotherapy | Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Patient-reported QOL; Changes on standardized symptom scores; Venous thrombosis; Repeat Intervention; Qualitative reduction In LE pain; Bleeding; Periprocedural complications;
Liu, 2011^71^ | Study Design: RCT Quality: Fair Location: Asia [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 134 N Completed: 134 % Female: 57%, 52% Mean Age: 39.58, 41.02 | EVLA vs. EVLA + Phlebectomy | Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Thrombophlebitis; Qualitative reduction In LE edema; Venous wound Infection; Qualitative reduction In LE pain; Periprocedural complications; Bleeding; Thrombophlebitis
Liu, 2011^72^ | Study Design: RCT Quality: Poor Location: Asia [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous Insufficiency/reflux/incompetency Total N: 60 N Completed: 54 % Female: NR Age: NR | Stripping + Ligation vs. Foam Sclerotherapy + Ligation | Ultrasound | Changes on standardized symptom scores; Patient-reported QOL; Improvement in LE venous hemodynamics/reflux severity; Periprocedural complications; Bleeding; Thrombophlebitis; Repeat intervention
Lurie, 2003^73^ EVoLVeS Companions: Lurie, 2011^74^ Lurie, 2005^75^ | Study Design: RCT Quality: Fair Location: U.S., UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 85 N Completed: 80 % Female: 73%, 72% Mean Age: 49, 47 | High Ligation + Stripping vs. RFA | Ultrasound | Periprocedural complications; Patient-reported QOL; Improvement in LE venous hemodynamics/reflux severity; Changes on standardized symptom scores; Bleeding; Venous wound infection; Venous thrombosis
Menyhei, 2008^76^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 160 N Completed: 146 % Female: 66%, 70% Median Age: 47, 46 | High Ligation + Stripping vs. High Ligation + Cyrostripping | Clinical assessment; Ultrasound | Patient-reported QOL
Michaels, 2006^77^ REACTIV | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic; Asymptomatic Condition(s): LE varicose veins Total N: 77 N Completed: 52 % Female: 93%, 83% Mean Age: 47, 45.1 | High Ligation + Stripping vs. Foam Sclerotherapy + Ligation | Clinical assessment; Ultrasound | Venous wound infection; Patient-reported QOL; Qualitative reduction in LE pain; Repeat intervention
Michaels, 2006^78^ REACTIV Companions: Michaels, 2006^79^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic; Asymptomatic Condition(s): LE varicose veins Total N: 246 N Completed: 182 % Female: 71%, 79% Mean Age: 49.5, 49 | High Ligation + Stripping vs. Conservative Therapy | Clinical assessment; Ultrasound | Venous wound infection; Patient-reported QOL; Qualitative reduction in LE pain
Michaels, 2006^80^ REACTIV | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic; Asymptomatic Condition(s): LE varicose veins Total N: 34 N Completed: 34 % Female: 68% Mean Age: 47.5 | Lifestyle Intervention vs. Sclerotherapy with Sodium Tetradecylsuflate | Clinical assessment; Ultrasound | Patient-reported QOL; Qualitative reduction in LE pain
Moreno-Moraga, 2014^81^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins Total N: 320 N Completed: 298 % Female: NR Age: NR | Foam Sclerotherapy vs. YAG Laser + Foam Sclerotherapy | Ultrasound | Periprocedural complications; Qualitative reduction In LE pain; Patient-reported QOL; Improvement in LE venous hemodynamics/reflux severity (Severity of Disease)
Morrison, 2015^82^ VeCLoSE Trial | Study Design: RCT Quality: Fair Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 242 N Completed: 222 % Female: 77%, 82% Mean Age: 49, 50.5 | Cyanoacrylate embolization vs. RFA | Ultrasound | Changes on standardized symptom scores; Patient-reported QOL; Qualitative reduction In LE pain; Thrombophlebitis; Bleeding
Mozafar, 2014^83^ | Study Design: RCT Quality: Poor Location: Middle East [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins Total N: 65 N Completed: 65 % Female: 73.3%, 71.4% Age: NR | High Ligation + Stripping vs. EVLA | Unclear/NR | Qualitative reduction In LE pain; Patient-reported QOL; Recurrent ulceration; Venous thrombosis; Changes on standardized symptom scores
Nelson, 2007^84^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins Total N: 245 N Completed: 245 % Female: 67% Mean Age: 70 | Pentoxifylline vs. Bandages/Wound Care | Clinical assessment | Venous wound healing; Adverse drug reactions
Nlkolovska, 2002^85^ | Study Design: RCT Quality: Poor Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 80 N Completed: 80 % Female: 45%, 48% Mean Age: 61.5, 61.2 | Pentoxifylline + Local Therapy vs. Local Therapy | Clinical assessment | Recurrent ulceration
Noppeney, 2016^86^ | Study Design: observational Quality: Poor Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): Unclear/NR Total N: 89,647 N Completed: 36,096 % Female: 69.3% Mean Age: 52.8 | Surgery (venous ligation plus stripping) vs. RFA vs. EVLA | Not Reported | Periprocedural Complications
Nordon, 2011^87^ Evlt Versus Vnus Endovenous Randomised Trial study | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins Total N: 159 N Completed: 138 % Female: 68%, 57% Mean Age: 46.7, 46.9 | EVLA vs. RFA | Ultrasound | Improvement In LE venous hemodynamics/reflux severity; Qualitative reduction in LE pain; Thrombophlebitis; Venous thrombosis; Patient-reported QOL; Periprocedural complications
obi, 2015^88^ | Study Design: observational Quality: Poor Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 979 N Completed: 979 % Female: 71% Mean Age: 52.4 | RFA vs. EVLA + Compression | Ultrasound | Changes on standardized symptom scores; Venous thromboembolic events; Venous wound Infection; Venous thrombosis; Bleeding; Periprocedural complications;
o’Hare, 2010^89^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 40 N Completed: 33 % Female: NR Median Age: 69 | 4 Layer Compression vs. 4 Layer Compression + Sclerotherapy | Ultrasound | Venous wound healing; Venous thromboembolic events; Improvement in LE venous hemodynamics/reflux severity
Pares, 2010^90^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins Total N: 501 N Completed: 501 % Female: 66%, 66%, 80% Mean Age: 49.54, 50, 48.76 | RFA +/- Phlebectomy vs. EVLA +/- Phlebectomy | Clinical assessment; Ultrasound | Improvement In LE venous hemodynamics/reflux severity; Venous thromboembolic events;) Periprocedural complications; Thrombophlebitis; Death; Bleeding
Pronk, 2010^91^ Companions: Gauw, 2016^92^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 130 legs N Completed: 130 legs % Female: 78%, 74% Mean Age: 50, 49 | Foam sclerotherapy + surgical stripping vs. EVLA + Foam Sclerotherapy | Ultrasound | Qualitative reduction in LE pain; Patient-reported QOL; Venous thromboembolic events; Venous thrombosis; Changes on standardized symptom scores; Improvement In LE venous hemodynamics/reflux severity; Repeat intervention (CEAP Classification)
Rabe, 2010^93^ EASI Study | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins Total N: 316 N Completed: 266 % Female: 97.5% Mean Age: 43.5 | Polidocanol (Foam Sclerotherapy) vs. Sodium Tetradecyl Sulphate (Foam Sclerotherapy) vs. Placebo saline injections | Ultrasound | Periprocedural complications; Bleeding
Rasmussen, 2007^94^ Companions: Rasmussen, 2010^95^ Rasmussen, 2013^96^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 121 N Completed: 88 % Female: 73%, 66% Mean Age: 54, 53 | High Ligation + Stripping vs. EVLA | Ultrasound | Thrombophlebitis; Patient-reported QOL; Repeat intervention; Changes on standardized symptom scores; Improvement In LE venous hemodynamics/reflux severity
Rasmussen, 2011^97^ Companions: Rasmussen, 2013^98^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 500 N Completed: 433 % Female: 72%, 70%, 76%, 77% Mean Age: 52, 51, 51, 50 | High Ligation + Stripping vs. EVLA vs. Sclerotherapy vs. RFA | Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Venous thrombosis; Venous thromboembolic events; Bleeding; Qualitative reduction in LE pain; Changes on standardized symptom scores; Patient-reported QOL; Repeat intervention
Rass, 2012^99^ RELACS Companions: Rass, 2015^100^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 400 N Completed: 346 % Female: 67%, 70% Mean Age: 47.9, 48 | High Ligation + Stripping vs. EVLA | Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Patient-reported QOL; Qualitative reduction in LE pain; Venous thrombosis; Thrombophlebitis; Bleeding; Venous wound infection; Changes on standardized symptom scores; Repeat intervention;
Rautio, 2002^101^ Companions: Perala, 2005^102^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 33 N Completed: 28 % Female: 93%, 92% Mean Age: 33, 38 | Surgical Stripping vs. Endovenous obliteration | Ultrasound | Changes on standardized symptom scores; Patient-reported QOL; Repeat intervention; Thrombophlebitis
Roopram, 2013^103^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 189 N Completed: 175 % Female: 73%, 54% Mean Age: 51 | High Ligation + Stripping vs. EVLA | Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Qualitative reduction in LE pain; Patient-reported QOL
Samuel, 2013^104^ HELP-2 Companions: Nandhra, 2015^105^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 106 N Completed: 106 % Female: 75.5%, 64.2% Mean Age: 47.5, 47.8 | High Ligation + Stripping vs. EVLA | Unclear/NR | Improvement in LE venous hemodynamics/reflux severity; Patient-reported QOL; Qualitative reduction in LE pain
Schouten, 2006^106^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 40 N Completed: 40 % Female: 75%, 70% Mean Age: 39.5, 46.5 | High Ligation + Stripping vs. High Ligation + Cryostripping | Ultrasound | Bleeding; Periprocedural complications; Thrombophlebitis; Qualitative reduction in LE pain; Exercise-related harms
Sell, 2014^107^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 153 N Completed: 145 % Female: 90%, 86% Mean Age: 46, 48 | High Ligation + Stripping +/- Phlebectomy/Exclslon vs. Compression | Clinical assessment; Ultrasound | Changes on standardized symptom scores; Patient-reported QOL
Serra, 2015^108^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 284 N Completed: 284 % Female: 78% Mean Age: 69.5 | Nadroparin vs. No Anticoagulants | Clinical assessment; Ultrasound | Venous wound healing; Recurrent ulceration (Age)
Shadid, 2012^109^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 460 N Completed: 390 % Female: 74%, 72% Mean Age: 55.8, 54.6 | Foam Sclerotherapy vs. High Ligation + Stripping +/- Phlebectomy | Clinical assessment; Ultrasound | Changes on standardized symptom scores; Patient-reported QOL; Repeat intervention; Improvement in LE venous hemodynamics/reflux severity; Periprocedural complications; Bleeding; Qualitative reduction In LE pain; Thrombophlebitis; Venous thromboembolic events (Anatomic Segment)
Shepherd, 2010^110^ VALVV Companions: Shepherd, 2015^111^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 131 N Completed: 115 % Female: 70%, 66% Mean Age: 49, 48 | RFA vs. EVLA + Compression | Ultrasound | Patient-reported QOL; Changes on standardized symptom scores; Qualitative reduction In LE pain; Venous thromboembolic events; Bleeding;) Periprocedural complications
Stötter, 2006^112^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 60 N Completed: 57 % Female: 70%, 75%, 70% Age: NR | High Ligation + Stripping vs. RFA | Clinical assessment; Ultrasound | Improvement In LE venous hemodynamics/reflux severity; Qualitative reduction in LE pain; Bleeding
Subramonia, 2010^113^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 93 N Completed: 88 % Female: 72%, 66% Median Age: 47, 45 | High Ligation + Stripping vs. RFA | Ultrasound | Patient-reported QOL
Theivacumar, 2008^114^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 65 N Completed: 65 % Female: 59%, 62%, 55% Median Age: 40, 42, 46 | EVLA vs. EVLA + Sclerotherapy | Unclear/NR | Patient-reported QOL; Repeat intervention; Improvement In LE venous hemodynamics/reflux severity
Todd, 2014^115^ VANISH-2 | Study Design: RCT Quality: Good Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 235 N Completed: 230 % Female: 72.8% Mean Age: 50.8 | Sclerotherapy vs. Placebo | Ultrasound | Changes on standardized symptom scores; Improvement In LE venous hemodynamics/reflux severity; Patient-reported QOL
van den Bos, 2014^116^ LAST | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 237 N Completed: 227 % Female: 57.5%, 65.2% Mean Age: 55, 56 | EVLA vs. Thermal Ablation | Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Changes on standardized symptom scores; Patient-reported QOL; Venous thrombosis; Thrombophlebitis; Bleeding
van Gent, 2006^117^ Companions: van Gent, 2015^118^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 170 (200 limbs) N Completed: 143 (196 limbs) % Female: NR Mean Age: 64, 68 | SEPS + High Ligation + Stripping vs. Conservative/ Compression | Clinical assessment; Ultrasound | Death; Recurrent ulceration; Venous wound healing (Presence of LE Ulcer)
Vandongen, 2000^119^ | Study Design: RCT Quality: Poor Location: Australia/N.Z. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 153 N Completed: 78 % Female: 54% Mean Age: 67 | Below-Knee Compression Stockings vs. No Compression Therapy | Clinical assessment; Ultrasound (76% of patients) | Recurrent Ulceration
Vanscheidt, 2002^120^ | Study Design: RCT Quality: Good Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 254 N Completed: 226 % Female: 79% Mean Age: 55.1 | Medication vs. Placebo + Compression | Clinical assessment; Ultrasound | Adverse drug reactions; Qualitative reduction In LE pain; Qualitative reduction In LE edema
Vasquez, 2016^121^ Varithena 017 | Study Design: RCT Quality: Fair Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins, LE chronic venous insufficiency/reflux/incompetency Total N: 118 N Completed: 112 % Female: 69% Mean Age: 52 | Thermal Ablation + 0.5% Polldocanol microfoam (PEM) vs. Thermal Ablation + 1% Polldocanol microfoam vs. Thermal Ablation + placebo injection | CEAP grade 2-5; Clinical assessment | Venous thrombosis; Changes on standardized symptom scores; Patient-reported QOL; Thrombophlebitis; Repeat intervention; Improvement In LE venous hemodynamics/reflux severity
Viarengo, 2007^122^ | Study Design: RCT Quality: Fair Location: Latin America [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 52 N Completed: 52 % Female: 72%, 78% Mean Age: 60.7, 57.4 | Compression vs. EVLA + Compression | Ultrasound | Venous wound healing; Qualitative reduction in LE pain; Thrombophlebitis; Venous thromboembolic events; Periprocedural complications; Recurrent ulceration
Wang, 2016^123^ | Study Design: RCT Quality: Fair Location: Asia [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 150 N Completed: 150 % Female: 36% Mean Age: 46.5 | High Ligation + Stripping vs. EVLA vs. CHIVA | CEAP grade 2-6 | Improvement In LE venous hemodynamics/reflux severity; Thrombophlebitis; Bleeding
Wong, 2012^124^ | Study Design: RCT Quality: Good Location: Asia [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 321 N Completed: 276 % Female: 36% Mean Age: 71.7 | Mechanical Compression vs. Placebo/Control therapy | Clinical assessment; Ultrasound | Qualitative reduction in LE pain; Patient-reported QOL; Venous wound healing
Wozniak, 2015^125^ | Study Design: RCT Quality: Fair Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 102 N Completed: 102 % Female: 83%, 78% Mean Age: 51.44, 53.04 | High Ligation + Stripping vs. Thermal Ablation (Steam) | CEAP grades 2-6 | Qualitative reduction In LE edema; Changes on standardized symptom scores; Venous thrombosis; Venous thromboembolic events; Improvement in LE venous hemodynamics/reflux severity
Wright, 2006^126^ | Study Design: RCT Quality: Poor Location: UK/Europe [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 710 N Completed: 645 % Female: 68%, 64%, 75% Mean Age: 50.4, 49, 49.6 | High Ligation + Stripping vs. Foam Sclerotherapy + Ligation vs. Liquid/Foam Sclerotherapy | Clinical assessment; Ultrasound | Improvement in LE venous hemodynamics/reflux severity; Qualitative reduction In LE pain; Venous thrombosis; Bleeding
Yang, 2013^127^ | Study Design: RCT Quality: Fair Location: Asia [underlined: Population] Symptom Status: Symptomatic Condition(s): LE varicose veins; LE chronic venous insufficiency/reflux/incompetency Total N: 200 N Completed: 183 % Female: 51%, 55% Median Age: 59, 58 | High Ligation + Stripping +/- Phlebectomy vs. High Ligation + Endovenous Microwave Therapy | Clinical assessment; Ultrasound | Periprocedural complications; Repeat intervention; Patient-reported QOL; Changes on standardized symptom scores
Zamboni, 2003^128^ Companions: Zamboni, 2004^129^ | Study Design: RCT Quality: Poor Location: UK/Europe [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 45 N Completed: 45 % Female: 60% Mean Age: 63 | CHIVA + Compression vs. Compression | Clinical assessment; Ultrasound | Repeat intervention; Venous wound healing; Recurrent ulceration; Improvement in LE venous hemodynamics/reflux severity

* = Multiple values are listed for percent female and age in instances where baseline data is reported by study arm rather than for the total population.

Abbreviations: CEAP=Clinical, Etiologic, Anatomic, Pathophysiologic; CHIVA=Cure conservatrice et Hémodynamique de l’Insuffisance Veineuse en Ambulatoire; EVLA = Endovenous Laser Ablation; LE=lower extremity; NR=not reported; QOL=quality of life; RFA=Radiofrequency Ablation; SEPS=subfascial endoscopic perforating vein surgery

Appendix Table F-3 Study Characteristics—KQ 3

Author, Year | Study Details^*^ | Interventions | Diagnostic Method(s) and Criteria | outcomes (Subgroups analyzed)
Garg, 2011^130^ | Study Design: observational Quality: Fair Location: U.S. [underlined: Population] Symptom Status: Unclear/NR Condition(s): LE venous thrombosis/obstruction; PTS Total N: 60 N Completed: 60 % Female: 56 Mean Age: 43 | Palma vein Procedure vs. Endophlebectomy and patch angioplasty with stent | obstruction of Iliofemoral veins and IVC, using MRV, ultrasound or CTV | Improvement in LE venous hemodynamics/reflux severity
Ginsberg, 2001^131^ | Study Design: RCT Quality: Poor Location: Canada [underlined: Population] Symptom Status: Symptomatic Condition(s): PTS Total N: 35 N Completed: Unclear/NR % Female: 60% Mean Age: 46, 51.6, 54.6, 39.5 | Compression Therapy (thigh and calf) vs. Placebo/Control (thigh and calf) | Postphlebitic syndrome, Chronic (>1 month in duration), typical symptoms including pain and swelling >= 6 months after proximal DVT. | Death
Holmes, 2014^132^ | Study Design: RCT Quality: Good Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE venous thrombosis/obstruction; PTS Total N: 31 N Completed: 31 % Female: 53%, 62% Mean Age: 47, 49 | Complex lymphedema therapy (CLT) vs. Compression therapy | Prior history of DVT and clinical diagnosis of PTS | Changes on standardized symptom scores Patient-reported QOL
Kahn, 2011^133^ | Study Design: RCT Quality: Good Location: Canada [underlined: Population] Symptom Status: Symptomatic Condition(s): PTS Total N: 43 N Completed: 39 % Female: 55% Mean Age: 44.9, 48.14 | Patient Education vs. Exercise Training | Symptomatic DVT >= 6 months, and symptoms with Villalta score >= 5 | Changes on standardized symptom scores Patient-reported QOL
O’Sullivan, 2000^134^ | Study Design: Observational Quality: Poor Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): PTS Total N: 20 N Completed: 20 % Female: 77% Mean Age: 43 | Stent + Lysis vs. Stent | Ultrasound, CTV, MRV, or invasive venography showing L iliac vein thrombosis +/- involvement of femoral and popliteal segments. Also needed symptoms with at least one of the following: edema, pain, venous claudication, and/or phlegmasia. | Changes on standardized symptom scores, Improvement in LE venous hemodynamics/reflux severity
Raju, 2013^135^ | Study Design: Observational Quality: Poor Location: U.S. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/incompetency Total N: 192 N Completed: 192 % Female: 50% Age:59 | EVLA vs. EVLA + Stent vs. Stent | Patients with CEAP6 (failed conservative therapy). Swelling, pain; venography + intravascular ultrasound were used to look for obstruction. | Venous wound healing
Yin, 2015^136^ | Study Design: Observational Quality: Fair Location: Asia. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE venous thrombosis/obstruction; PTS Total N: 216 N Completed: 216 % Female: 59% Median Age: 46, 42 | Endovascular Stent vs. Compression Therapy | PTS with iliofemoral obstruction (>50% stenosis or occlusion on venography) and mod/severe symptoms (Vilialta score >=10) | Changes on standardized symptom scores Qualitative reduction in LE edema Qualitative reduction in LE pain (subgroup: Villalta Score)
Yin, 2015^137^ | Study Design: Observational Quality: Fair Location: Asia. [underlined: Population] Symptom Status: Symptomatic Condition(s): LE chronic venous insufficiency/reflux/ incompetency; PTS Total N: 207 N Completed: 207 % Female: 66% Mean Age: 50.1, 51.9 | EVLA vs. EVLA + Stent | Phlebography and ultrasound were used to diagnose May-Thurner syndrome | Recurrent ulceration Improvement in LE venous hemodynamics/reflux severity Patient-reported QOL

* = Multiple values are listed for percent female and age in instances where baseline data is reported by study arm rather than for the total population.

Abbreviations: Abbreviations: CEAP=Clinical, Etiologic, Anatomic, Pathophysiologic; CHIVA=Cure conservatrice et Hémodynamique de l’Insuffisance Veineuse en Ambulatoire; CTV=computed tomography venography; DVT=deep vein thrombosis; EVLA = Endovenous Laser Ablation; IVUS=intravascular ultrasound; LE=lower extremity; MRV=magnetic resonance venography; NR=not reported; QOL=quality of life; PTS=Post-thrombotic Syndrome

## References to Appendix F:

1 Antoch G, Pourhassan S, Hansen O, . Comparison of colour Doppler ultrasonography, ascending phlebography and clinical examination in the diagnosis of incompetent calf perforating veins. Br J Surg. 2002 Feb;89(2):192-3. doi: 10.1046/j.0007-1323.2001.02003.x. PMID: 11856132.11856132
2 Depalma RG, Kowallek DL, Barcia TC, . Target selection for surgical intervention in severe chronic venous insufficiency: comparison of duplex scanning and phlebography. J Vasc Surg. 2000 Nov;32(5):913-20. doi: 10.1067/mva.2000.110347. PMID: 11054223.11054223
3 Kayilioglu SI, Koksoy C, Alacayir I. Diagnostic value of the femoral vein flow pattern for the detection of an iliocaval venous obstruction. J Vasc Surg Venous Lymphat Disord. 2016 Jan;4(1):2-8. doi: 10.1016/j.jvsv.2015.08.002. PMID: 26946889.26946889
4 Kurstjens RL, de Wolf MA, Alsadah SA, . The value of hemodynamic measurements by air plethysmography in diagnosing venous obstruction of the lower limb. J Vasc Surg Venous Lymphat Disord. 2016 Jul;4(3):313-9. doi: 10.1016/j.jvsv.2016.01.005. PMID: 27318051.27318051
5 Lee W, Chung JW, Yin YH, . Threedimensional CT venography of varicose veins of the lower extremity: image quality and comparison with doppler sonography. AJR Am J Roentgenol. 2008 Oct;191(4):1186-91. doi: 10.2214/ajr.07.3471. PMID: 18806163.18806163
6 Mantoni M, Larsen L, Lund JO, . Evaluation of chronic venous disease in the lower limbs: comparison of five diagnostic methods. Br J Radiol. 2002 Jul;75(895):578-83. doi: 10.1259/bjr.75.895.750578. PMID: 12145130.12145130
7 Massenburg BB, Himel HN, Blue RC, . Magnetic resonance imaging in proximal venous outflow obstruction. Ann Vasc Surg. 2015 Nov;29(8):1619-24. doi: 10.1016/j.avsg.2015.06.083. PMID: 26315799.26315799
8 Meyer T, Cavallaro A, Lang W. Duplex ultrasonography in the diagnosis of incompetent Cockett veins. Eur J Ultrasound. 2000 Jun;11(3):175-80. PMID: 10874192.10874192
9 Mousa AY, Broce M, Yacoub M, . Validation of venous duplex ultrasound imaging in determining iliac vein stenosis after standard treatment of active chronic venous ulcers. J Vasc Surg Venous Lymphat Disord. 2016 Jul;4(3):307-12. doi: 10.1016/j.jvsv.2016.02.002. PMID: 27318050.27318050
10 Rabahie GN, Waisberg DR, Martins LC, . Comparative study among the physical examination, echo-color Doppler mapping and operative approaching in the recurrent lower extremity varicose veins from the saphenofemoral junction. Jornal Vascular Brasileiro. 2011;10(3):198-204.
11 Abela R, Liamis A, Prionidis I, . Reverse foam sclerotherapy of the great saphenous vein with sapheno-femoral ligation compared to standard and invagination stripping: a prospective clinical series. Eur J Vasc Endovasc Surg. 2008 Oct;36(4):485-90. doi: 10.1016/j.ejvs.2008.06.029. PMID: 18718769.18718769
12 Aguilar-Ferrandiz ME, Castro-Sanchez AM, Mataran-Penarrocha GA, . Effects of kinesio taping on venous symptoms, bioelectrical activity of the gastrocnemius muscle, range of ankle motion, and quality of life in postmenopausal women with chronic venous insufficiency: a randomized controlled trial. Arch Phys Med Rehabil. 2013 Dec;94(12):2315-28. doi: 10.1016/j.apmr.2013.05.016. PMID: 23769763.23769763
13 Aguilar-Ferrandiz ME, Castro-Sanchez AM, Mataran-Penarrocha GA, . A randomized controlled trial of a mixed Kinesio taping-compression technique on venous symptoms, pain, peripheral venous flow, clinical severity and overall health status in postmenopausal women with chronic venous insufficiency. Clin Rehabil. 2014 Jan;28(1):69-81. doi: 10.1177/0269215512469120. PMID: 23426563.23426563
14 Aguilar-Ferrandiz ME, Moreno-Lorenzo C, Mataran-Penarrocha GA, . Effect of a mixed kinesio taping-compression technique on quality of life and clinical and gait parameters in postmenopausal women with chronic venous insufficiency: doubleblinded, randomized controlled trial. Arch Phys Med Rehabil. 2014 Jul;95(7):1229-39. doi: 10.1016/j.apmr.2014.03.024. PMID: 24732169.24732169
15 Al Shammeri O, AlHamdan N, Al-Hothaly B, . Chronic Venous Insufficiency: prevalence and effect of compression stockings. Int J Health Sci (Qassim). 2014 Jul;8(3):231-6. PMID: 25505858.25505858
16 Almeida JI, Kaufman J, Gockeritz O, . Radiofrequency endovenous ClosureFAST versus laser ablation for the treatment of great saphenous reflux: a multicenter, single-blinded, randomized study (RECOVERY study). J Vasc Interv Radiol. 2009 Jun;20(6):752-9. doi: 10.1016/j.jvir.2009.03.008. PMID: 19395275.19395275
17 Barwell JR, Davies CE, Deacon J, . Comparison of surgery and compression with compression alone in chronic venous ulceration (ESCHAR study): randomised controlled trial. Lancet. 2004 Jun 5;363(9424):1854-9. doi: 10.1016/s01406736(04)16353-8. PMID: 15183623.15183623
18 Gohel MS, Barwell JR, Taylor M, . Long term results of compression therapy alone versus compression plus surgery in chronic venous ulceration (ESCHAR): randomised controlled trial. BMJ. 2007 Jul 14;335(7610):83. doi: 10.1136/bmj.39216.542442.BE. PMID: 17545185.17545185
19 Gohel MS, Barwell JR, Earnshaw JJ, . Randomized clinical trial of compression plus surgery versus compression alone in chronic venous ulceration (ESCHAR study)-haemodynamic and anatomical changes. Br J Surg. 2005 Mar;92(3):291-7. doi: 10.1002/bjs.4837. PMID: 15584055.15584055
20 Gohel MS, Barwell JR, Wakely C, . The influence of superficial venous surgery and compression on incompetent calf perforators in chronic venous leg ulceration. Eur J Vasc Endovasc Surg. 2005 Jan;29(1):78-82. doi: 10.1016/j.ejvs.2004.09.016. PMID: 15570276.15570276
21 Basela H, Aydina C, Aya Y, . Endovenous laser ablation (EVLA) versus high ligation and striping (HL/S): Two-years follow up. Eastern Journal of Medicine. 2011;17(2):83-7.
22 Belcaro G, Nicolaides AN, Ricci A, . Endovascular sclerotherapy, surgery, and surgery plus sclerotherapy in superficial venous incompetence: a randomized, 10year follow-up trial--final results. Angiology. 2000 Jul;51(7):529-34. PMID: 10917577.10917577
23 Belcaro G, Cesarone MR, Di Renzo A, . Foam-sclerotherapy, surgery, sclerotherapy, and combined treatment for varicose veins: a 10-year, prospective, randomized, controlled, trial (VEDICO trial). Angiology. 2003 May-Jun;54(3):307-15. PMID: 12785023.12785023
24 Belcaro G, Cesarone M, Di Renzo A, . Treatments for varicose veins: Surgery, sclerotherapy, foamsclerotherapy and combined (surgery+sclerotherapy) options. A 10-year, prospective, randomised, controlled, follow-up study. The VEDICO* trial and EST (European Sclerotherapy Trial). Angeiologie. 2003;55(1):29-36.
25 Belcaro G, Dugall M, Corsi M. Superficial venous incompetence: Low-cost outpatient mini-surgery, sclerotherapy and combined procedure as a management plan. Costs and efficacy. A 20-year, follow-up registry. Minerva Chir. 2015 Jun 5 PMID: 26046959.26046959
26 Benarroch-Gampel J, Sheffield KM, Boyd CA, . Analysis of venous thromboembolic events after saphenous ablation. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(1):26-32.26993890
27 Biemans AA, Kockaert M, Akkersdijk GP, . Comparing endovenous laser ablation, foam sclerotherapy, and conventional surgery for great saphenous varicose veins. J Vasc Surg. 2013 Sep;58(3):727-34.e1. doi: 10.1016/j.jvs.2012.12.074. PMID: 23769603.23769603
28 van der Velden SK, Biemans AA, De Maeseneer MG, . Five-year results of a randomized clinical trial of conventional surgery, endovenous laser ablation and ultrasound-guided foam sclerotherapy in patients with great saphenous varicose veins. Br J Surg. 2015 Sep;102(10):1184-94. doi: 10.1002/bjs.9867. PMID: 26132315.26132315
29 Bountouroglou DG, Azzam M, Kakkos SK, . Ultrasound-guided foam sclerotherapy combined with sapheno-femoral ligation compared to surgical treatment of varicose veins: early results of a randomised controlled trial. Eur J Vasc Endovasc Surg. 2006 Jan;31(1):93-100. doi: 10.1016/j.ejvs.2005.08.024. PMID: 16233981.16233981
30 Kalodiki E, Lattimer CR, Azzam M, . Long-term results of a randomized controlled trial on ultrasound-guided foam sclerotherapy combined with saphenofemoral ligation vs standard surgery for varicose veins. J Vasc Surg. 2012 Feb;55(2):451-7. doi: 10.1016/j.jvs.2011.08.040. PMID: 22104345.22104345
31 Brittenden J, Cotton SC, Elders A, . A randomized trial comparing treatments for varicose veins. N Engl J Med. 2014 Sep 25;371(13):1218-27. doi: 10.1056/NEJMoa1400781. PMID: 25251616.25251616
32 Brittenden J, Cotton SC, Elders A, . Clinical effectiveness and cost-effectiveness of foam sclerotherapy, endovenous laser ablation and surgery for varicose veins: results from the Comparison of LAser, Surgery and foam Sclerotherapy (CLASS) randomised controlled trial. Health Technol Assess. 2015 Apr;19(27):1-342. doi: 10.3310/hta19270. PMID: 25858333.25858333
33 Campos W, Jr., Torres IO, da Silva ES, . A prospective randomized study comparing polidocanol foam sclerotherapy with surgical treatment of patients with primary chronic venous insufficiency and ulcer. Ann Vasc Surg. 2015 Aug;29(6):1128-35. doi: 10.1016/j.avsg.2015.01.031. PMID: 26004968.26004968
34 Carpentier PH, Blaise S, Satger B, . A multicenter randomized controlled trial evaluating balneotherapy in patients with advanced chronic venous insufficiency. J Vasc Surg. 2014 Feb;59(2):447-54.e1. doi: 10.1016/j.jvs.2013.08.002. PMID: 24135621.24135621
35 Carradice D, Mekako AI, Hatfield J, . Randomized clinical trial of concomitant or sequential phlebectomy after endovenous laser therapy for varicose veins. Br J Surg. 2009 Apr;96(4):369-75. doi: 10.1002/bjs.6556. PMID: 19283745.19283745
36 Carradice D, Mekako AI, Mazari FA, . Randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg. 2011 Apr;98(4):501-10. doi: 10.1002/bjs.7394. PMID: 21283981.21283981
37 Carradice D, Mekako AI, Mazari FA, . Clinical and technical outcomes from a randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1117-23. doi: 10.1002/bjs.7615. PMID: 21638277.21638277
38 Carruthers TN, Farber A, Rybin D, . Interventions on the superficial venous system for chronic venous insufficiency by surgeons in the modern era: an analysis of ACS-NSQIP. Vasc Endovascular Surg. 2014 Oct-Nov;48(7-8):482-90. doi: 10.1177/1538574414561226. PMID: 25487248.25487248
39 Christenson JT, Gueddi S, Gemayel G, . Prospective randomized trial comparing endovenous laser ablation and surgery for treatment of primary great saphenous varicose veins with a 2-year follow-up. J Vasc Surg. 2010 Nov;52(5):1234-41. doi: 10.1016/j.jvs.2010.06.104. PMID: 20801608.20801608
40 Clarke-Moloney M, O’Brien JF, Grace PA, . Health-related quality of life during four-layer compression bandaging for venous ulcer disease: a randomised controlled trial. Ir J Med Sci. 2005 Apr Jun;174(2):21-5. PMID: 16094908.16094908
41 Coccheri S, Scondotto G, Agnelli G, . Randomised, double blind, multicentre, placebo controlled study of sulodexide in the treatment of venous leg ulcers. Thromb Haemost. 2002 Jun;87(6):947-52. PMID: 12083500.12083500
42 Darwood RJ, Theivacumar N, Dellagrammaticas D, . Randomized clinical trial comparing endovenous laser ablation with surgery for the treatment of primary great saphenous varicose veins. Br J Surg. 2008 Mar;95(3):294-301. doi: 10.1002/bjs.6101. PMID: 18278775.18278775
43 De Franciscis S, Gasbarro V, Amato B, . Hemodynamic surgery versus conventional surgery in chronic venous disease: A multicenter retrospective study. Acta Phlebologica. 2013;14(3):109-14.
44 de Roos KP, Nieman FH, Neumann HA. Ambulatory phlebectomy versus compression sclerotherapy: results of a randomized controlled trial. Dermatol Surg. 2003 Mar;29(3):221-6. PMID: 12614412.12614412
45 del Rio Sola ML, Antonio J, Fajardo G, . Influence of aspirin therapy in the ulcer associated with chronic venous insufficiency. Ann Vasc Surg. 2012 Jul;26(5):620-9. doi: 10.1016/j.avsg.2011.02.051. PMID: 22437068.22437068
46 Disselhoff BC, der Kinderen DJ, Kelder JC, . Randomized clinical trial comparing endovenous laser with cryostripping for great saphenous varicose veins. Br J Surg. 2008 Oct;95(10):1232-18. doi: 10.1002/bjs.6351. PMID: 18763255.18763255
47 Disselhoff BC, Buskens E, Kelder JC, . Randomised comparison of costs and costeffectiveness of cryostripping and endovenous laser ablation for varicose veins: 2-year results. Eur J Vasc Endovasc Surg. 2009 Mar;37(3):357-63. doi: 10.1016/j.ejvs.2008.11.013. PMID: 19111485.19111485
48 Disselhoff BC, der Kinderen DJ, Kelder JC, . Five-year results of a randomized clinical trial comparing endovenous laser ablation with cryostripping for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1107-11. doi: 10.1002/bjs.7542. PMID: 21633948.21633948
49 Elderman JH, Krasznai AG, Voogd AC, . Role of compression stockings after endovenous laser therapy for primary varicosis. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2014;2(3):289-96.26993388
50 Figueiredo M, Araujo S, Barros N, Jr., . Results of surgical treatment compared with ultrasound-guided foam sclerotherapy in patients with varicose veins: a prospective randomised study. Eur J Vasc Endovasc Surg. 2009 Dec;38(6):758-63. doi: 10.1016/j.ejvs.2009.07.015. PMID: 19744867.19744867
51 Flessenkamper I, Hartmann M, Stenger D, . Endovenous laser ablation with and without high ligation compared with high ligation and stripping in the treatment of great saphenous varicose veins: initial results of a multicentre randomized controlled trial. Phlebology. 2013 Feb;28(1):16-23. doi: 10.1258/phleb.2011.011147. PMID: 22451455.22451455
52 Flessenkamper I, Hartmann M, Hartmann K, . Endovenous laser ablation with and without high ligation compared to high ligation and stripping for treatment of great saphenous varicose veins: Results of a multicentre randomised controlled trial with up to 6 years follow-up. Phlebology. 2016 Oct 22;31(1):23-33. doi: 10.1177/0268355514555547. PMID: 25342648.25342648
53 Franek A, Taradaj J, Polak A, . Efficacy of high voltage stimulation for healing of venous leg ulcers in surgically and conservatively treated patients. Phlebologie. 2006;35(3):127-33.
54 Gale SS, Lee JN, Walsh ME, . A randomized, controlled trial of endovenous thermal ablation using the 810-nm wavelength laser and the ClosurePLUS radiofrequency ablation methods for superficial venous insufficiency of the great saphenous vein. J Vasc Surg. 2010 Sep;52(3):645-50. doi: 10.1016/j.jvs.2010.04.030. PMID: 20638231.20638231
55 Gibson K, Kabnick L. A multicenter, randomized, placebo-controlled study to evaluate the efficacy and safety of Varithena(R) (polidocanol endovenous microfoam 1%) for symptomatic, visible varicose veins with saphenofemoral junction incompetence. Phlebology. 2016 Mar 24doi: 10.1177/0268355516635386. PMID: 27013511.27013511
56 Goode SD, Chowdhury A, Crockett M, . Laser and radiofrequency ablation study (LARA study): a randomised study comparing radiofrequency ablation and endovenous laser ablation (810 nm). Eur J Vasc Endovasc Surg. 2010 Aug;40(2):246-53. doi: 10.1016/j.ejvs.2010.02.026. PMID: 20537570.20537570
57 Guest M, Smith JJ, Tripuraneni G, . Randomized clinical trial of varicose vein surgery with compression versus compression alone for the treatment of venous ulceration. Phlebology. 2003;18(3):130-6.
58 Hamel-Desnos CM, Guias BJ, Desnos PR, . Foam sclerotherapy of the saphenous veins: randomised controlled trial with or without compression. Eur J Vasc Endovasc Surg. 2010 Apr;39(4):500-7. doi: 10.1016/j.ejvs.2009.11.027. PMID: 20097585.20097585
59 Helmy ElKaffas K, ElKashef O, ElBaz W. Great saphenous vein radiofrequency ablation versus standard stripping in the management of primary varicose veins-a randomized clinical trial. Angiology. 2011 Jan;62(1):49-54. doi: 10.1177/0003319710380680. PMID: 20724299.20724299
60 Houtermans-Auckel JP, van Rossum E, Teijink JA, . To wear or not to wear compression stockings after varicose vein stripping: a randomised controlled trial. Eur J Vasc Endovasc Surg. 2009 Sep;38(3):387-91. doi: 10.1016/j.ejvs.2009.05.025. PMID: 19608438.19608438
61 Jull A, Parag V, Walker N, . The prepare pilot RCT of home-based progressive resistance exercises for venous leg ulcers. J Wound Care. 2009 Dec;18(12):497-503. doi: 10.12968/jowc.2009.18.12.45606. PMID: 20081574.20081574
62 Kahle B, Leng K. Efficacy of sclerotherapy in varicose veins-- prospective, blinded, placebo-controlled study. Dermatol Surg. 2004 May;30(5):723-8; discussion 8. doi: 10.1111/j.1524-4725.2004.30207.x. PMID: 15099314.15099314
63 Kalteis M, Berger I, Messie-Werndl S, . High ligation combined with stripping and endovenous laser ablation of the great saphenous vein: early results of a randomized controlled study. J Vasc Surg. 2008 Apr;47(4):822-9; discussion 9. doi: 10.1016/j.jvs.2007.10.060. PMID: 18295441.18295441
64 King JT, O’Byrne M, Vasquez M, . Treatment of Truncal Incompetence and Varicose Veins with a Single Administration of a New Polidocanol Endovenous Microfoam Preparation Improves Symptoms and Appearance. Eur J Vasc Endovasc Surg. 2015 Dec;50(6):784-93. doi: 10.1016/j.ejvs.2015.06.111. PMID: 26384639.26384639
65 Klem TM, Schnater JM, Schutte PR, . A randomized trial of cryo stripping versus conventional stripping of the great saphenous vein. J Vasc Surg. 2009 Feb;49(2):403-9. doi: 10.1016/j.jvs.2008.09.016. PMID: 19028042.19028042
66 Kumar S, Samraj K, Nirujogi V, . Intermittent pneumatic compression as an adjuvant therapy in venous ulcer disease. J Tissue Viability. 2002 Apr;12(2):42-4, 6, 8 passim. PMID: 12001325.12001325
67 Lane T, Bootun R, Dharmarajah B, . A multi-centre randomised controlled trial comparing radiofrequency and mechanical occlusion chemically assisted ablation of varicose veins - Final results of the Venefit versus Clarivein for varicose veins trial. Phlebology. 2016 May 24doi: 10.1177/0268355516651026. PMID: 27221810.27221810
68 Bootun R, Lane T, Dharmarajah B, . Intra-procedural pain score in a randomised controlled trial comparing mechanochemical ablation to radiofrequency ablation: The Multicentre Venefit versus ClariVein(R) for varicose veins trial. Phlebology. 2016;31(1):61-5. doi: 10.1177/0268355514551085. PMID: 25193822.25193822
69 Lattimer CR, Kalodiki E, Azzam M, . Interim results on abolishing reflux alongside a randomized clinical trial on laser ablation with phlebectomies versus foam sclerotherapy. Int Angiol. 2013 Aug;32(4):394-403. PMID: 23822942.23822942
70 Lattimer CR, Azzam M, Kalodiki E, . Cost and effectiveness of laser with phlebectomies compared with foam sclerotherapy in superficial venous insufficiency. Early results of a randomised controlled trial. Eur J Vasc Endovasc Surg. 2012 May;43(5):594-600. doi: 10.1016/j.ejvs.2012.01.032. PMID: 22386383.22386383
71 Liu P, Ren S, Yang Y, . Intravenous catheter-guided laser ablation: a novel alternative for branch varicose veins. Int Surg. 2011 Oct-Dec;96(4):331-6. PMID: 22808616.22808616
72 Liu X, Jia X, Guo W, . Ultrasoundguided foam sclerotherapy of the great saphenous vein with sapheno-femoral ligation compared to standard stripping: a prospective clinical study. Int Angiol. 2011 Aug;30(4):321-6. PMID: 21747350.21747350
73 Lurie F, Creton D, Eklof B, . Prospective randomized study of endovenous radiofrequency obliteration (closure procedure) versus ligation and stripping in a selected patient population (EVOLVeS Study). J Vasc Surg. 2003 Aug;38(2):207-14. PMID: 12891099.12891099
74 Lurie F, Creton D, Eklof B, . Reprinted article "Prospective randomised study of endovenous radiofrequency obliteration (closure) versus ligation and vein stripping (EVOLVeS): two-year follow-up". Eur J Vasc Endovasc Surg. 2011 Sep;42 Suppl 1:S107-13. doi: 10.1016/j.ejvs.2011.06.019. PMID: 21855011.21855011
75 Lurie F, Creton D, Eklof B, . Prospective randomised study of endovenous radiofrequency obliteration (closure) versus ligation and vein stripping (EVOLVeS): two-year follow-up. Eur J Vasc Endovasc Surg. 2005 Jan;29(1):67-73. doi: 10.1016/j.ejvs.2004.09.019. PMID: 15570274.15570274
76 Menyhei G, Gyevnar Z, Arato E, . Conventional stripping versus cryostripping: a prospective randomised trial to compare improvement in quality of life and complications. Eur J Vasc Endovasc Surg. 2008 Feb;35(2):218-23. doi: 10.1016/j.ejvs.2007.08.017. PMID: 17964821.17964821
77 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 2]. Health Technol Assess. 2006;10(13):1-196, iii-iv. PMID: 16707070.16707070
78 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 3]. Health Technol Assess. 2006;10(13):1-196, iii-iv.
79 Michaels JA, Brazier JE, Campbell WB, . Randomized clinical trial comparing surgery with conservative treatment for uncomplicated varicose veins. Br J Surg. 2006 Feb;93(2):175-81. doi: 10.1002/bjs.5264. PMID: 16432825.16432825
80 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 1]. Health Technol Assess. 2006 Apr;10(13):1-196, iii-iv. PMID: 16707070.16707070
81 Moreno-Moraga J, Smarandache A, Pascu ML, . 1064 nm Nd:YAG long pulse laser after polidocanol microfoam injection dramatically improves the result of leg vein treatment: a randomized controlled trial on 517 legs with a three-year follow-up. Phlebology. 2014 Dec;29(10):658-66. doi: 10.1177/0268355513502786. PMID: 23989971.23989971
82 Morrison N, Gibson K, McEnroe S, . Randomized trial comparing cyanoacrylate embolization and radiofrequency ablation for incompetent great saphenous veins (VeClose). J Vasc Surg. 2015 Apr;61(4):985-94. doi: 10.1016/j.jvs.2014.11.071. PMID: 25650040.25650040
83 Mozafar M, Atqiaee K, Haghighatkhah H, . Endovenous laser ablation of the great saphenous vein versus high ligation: long- term results. Lasers Med Sci. 2014 Mar;29(2):765-71. doi: 10.1007/s10103013-1389-z. PMID: 23942818.23942818
84 Nelson EA, Prescott RJ, Harper DR, . A factorial, randomized trial of pentoxifylline or placebo, four-layer or single-layer compression, and knitted viscose or hydrocolloid dressings for venous ulcers. J Vasc Surg. 2007 Jan;45(1):134-41. doi: 10.1016/j.jvs.2006.09.043. PMID: 17210398.17210398
85 Nikolovska S, Pavlova L, Petrova N, . Pentoxifylline--efficient in the treatment of venous ulcers in the absence of compression? Acta Dermatovenerol Croat. 2002 Mar;10(1):9-13. PMID: 12137725.12137725
86 Noppeney T, Storck M, Nüllen H, . Perioperative quality assessment of varicose vein surgery: Commission for quality assessment of the German Society for Vascular Surgery. Langenbeck’s Archives of Surgery. 2016;401(3):375-80.
87 Nordon IM, Hinchliffe RJ, Brar R, . A prospective double-blind randomized controlled trial of radiofrequency versus laser treatment of the great saphenous vein in patients with varicose veins. Ann Surg. 2011 Dec;254(6):876-81. doi: 10.1097/SLA.0b013e318230af5a. PMID: 21934487.21934487
88 Obi AT, Reames BN, Rook TJ, . Outcomes associated with ablation compared to combined ablation and transilluminated powered phlebectomy in the treatment of venous varicosities. Phlebology. 2015 Sep 15doi: 10.1177/0268355515604257. PMID: 26376824.26376824
89 O’Hare JL, Earnshaw JJ. Randomised clinical trial of foam sclerotherapy for patients with a venous leg ulcer. Eur J Vasc Endovasc Surg. 2010 Apr;39(4):495-9. doi: 10.1016/j.ejvs.2009.11.025. PMID: 20006528.20006528
90 Pares JO, Juan J, Tellez R, . Varicose vein surgery: stripping versus the CHIVA method: a randomized controlled trial. Ann Surg. 2010 Apr;251(4):624-31. doi: 10.1097/SLA.0b013e3181d0d0a3. PMID: 20224376.20224376
91 Pronk P, Gauw SA, Mooij MC, . Randomised controlled trial comparing sapheno-femoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anaesthesia: one year results. Eur J Vasc Endovasc Surg. 2010 Nov;40(5):649-56. doi: 10.1016/j.ejvs.2010.08.007. PMID: 20888274.20888274
92 Gauw SA, Lawson JA, van Vlijmen-van Keulen CJ, . Five-year follow-up of a randomized, controlled trial comparing saphenofemoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anesthesia. J Vasc Surg. 2016 Oct 22;63(2):420-8. doi: 10.1016/j.jvs.2015.08.084. PMID: 26602795.26602795
93 Rabe E, Schliephake D, Otto J, . Sclerotherapy of telangiectases and reticular veins: a double-blind, randomized, comparative clinical trial of polidocanol, sodium tetradecyl sulphate and isotonic saline (EASI study). Phlebology. 2010 Jun;25(3):124-31. doi: 10.1258/phleb.2009.009043. PMID: 20483861.20483861
94 Rasmussen LH, Bjoern L, Lawaetz M, . Randomized trial comparing endovenous laser ablation of the great saphenous vein with high ligation and stripping in patients with varicose veins: short-term results. J Vasc Surg. 2007 Aug;46(2):308-15. doi: 10.1016/j.jvs.2007.03.053. PMID: 17600655.17600655
95 Rasmussen LH, Bjoern L, Lawaetz M, . Randomised clinical trial comparing endovenous laser ablation with stripping of the great saphenous vein: clinical outcome and recurrence after 2 years. Eur J Vasc Endovasc Surg. 2010 May;39(5):630-5. doi: 10.1016/j.ejvs.2009.11.040. PMID: 20064730.20064730
96 Rasmussen L, Lawaetz M, Bjoern L, . Randomized clinical trial comparing endovenous laser ablation and stripping of the great saphenous vein with clinical and duplex outcome after 5 years. J Vasc Surg. 2013 Aug;58(2):421-6. doi: 10.1016/j.jvs.2012.12.048. PMID: 23768792.23768792
97 Rasmussen LH, Lawaetz M, Bjoern L, . Randomized clinical trial comparing endovenous laser ablation, radiofrequency ablation, foam sclerotherapy and surgical stripping for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1079-87. doi: 10.1002/bjs.7555. PMID: 21725957.21725957
98 Rasmussen L, Lawaetz M, Serup J, . Randomized clinical trial comparing endovenous laser ablation, radiofrequency ablation, foam sclerotherapy, and surgical stripping for great saphenous varicose veins with 3-year follow-up. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(4):349-56.26992754
99 Rass K, Frings N, Glowacki P, . Comparable effectiveness of endovenous laser ablation and high ligation with stripping of the great saphenous vein: twoyear results of a randomized clinical trial (RELACS study). Arch Dermatol. 2012 Jan;148(1):49-58. doi: 10.1001/archdermatol.2011.272. PMID: 21931012.21931012
100 Rass K, Frings N, Glowacki P, . Same Site Recurrence is More Frequent After Endovenous Laser Ablation Compared with High Ligation and Stripping of the Great Saphenous Vein: 5 year Results of a Randomized Clinical Trial (RELACS Study). Eur J Vasc Endovasc Surg. 2015 Nov;50(5):648-56. doi: 10.1016/j.ejvs.2015.07.020. PMID: 26319476.26319476
101 Rautio T, Ohinmaa A, Perala J, . Endovenous obliteration versus conventional stripping operation in the treatment of primary varicose veins: a randomized controlled trial with comparison of the costs. J Vasc Surg. 2002 May;35(5):958-65. PMID: 12021712.12021712
102 Perala J, Rautio T, Biancari F, . Radiofrequency endovenous obliteration versus stripping of the long saphenous vein in the management of primary varicose veins: 3-year outcome of a randomized study. Ann Vasc Surg. 2005 Sep;19(5):669-72. doi: 10.1007/s10016-005-6613-2. PMID: 16052388.16052388
103 Roopram AD, Lind MY, Van Brussel JP, . Endovenous laser ablation versus conventional surgery in the treatment of small saphenous vein incompetence. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(4):357-63.26992756
104 Samuel N, Carradice D, Wallace T, . Randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. Ann Surg. 2013 Mar;257(3):419-26. doi: 10.1097/SLA.0b013e318275f4e4. PMID: 23160149.23160149
105 Nandhra S, El-sheikha J, Carradice D, . A randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. J Vasc Surg. 2015 Mar;61(3):741-6. doi: 10.1016/j.jvs.2014.09.037. PMID: 25720930.25720930
106 Schouten R, Mollen RM, Kuijpers HC. A comparison between cryosurgery and conventional stripping in varicose vein surgery: perioperative features and complications. Ann Vasc Surg. 2006 May;20(3):306-11. doi: 10.1007/s10016006-9051-x. PMID: 16779510.16779510
107 Sell H, Vikatmaa P, Alback A, . Compression therapy versus surgery in the treatment of patients with varicose veins: A RCT. Eur J Vasc Endovasc Surg. 2014 Jun;47(6):670-7. doi: 10.1016/j.ejvs.2014.02.015. PMID: 24675145.24675145
108 Serra R, Buffone G, Molinari V, . Low molecular weight heparin improves healing of chronic venous ulcers especially in the elderly. Int Wound J. 2015 Apr;12(2):150-3. doi: 10.1111/iwj.12071. PMID: 23517508.23517508
109 Shadid N, Ceulen R, Nelemans P, . Randomized clinical trial of ultrasoundguided foam sclerotherapy versus surgery for the incompetent great saphenous vein. Br J Surg. 2012 Aug;99(8):1062-70. doi: 10.1002/bjs.8781. PMID: 22627969.22627969
110 Shepherd AC, Gohel MS, Brown LC, . Randomized clinical trial of VNUS ClosureFAST radiofrequency ablation versus laser for varicose veins. Br J Surg. 2010 Jun;97(6):810-8. doi: 10.1002/bjs.7091. PMID: 20473992.20473992
111 Shepherd AC, Ortega-Ortega M, Gohel MS, . COST-EFFECTIVENESS OF RADIOFREQUENCY ABLATION VERSUS LASER FOR VARICOSE VEINS. Int J Technol Assess Health Care. 2015 Jan;31(5):289-96. doi: 10.1017/s0266462315000537. PMID: 26715372.26715372
112 Stötter L, Schaaf I, Bockelbrink A. Comparative outcomes of radiofrequency endoluminal ablation, invagination stripping, and cryostripping in the treatment of great saphenous vein insufficiency. Phlebology. 2006;21(2):60-4.
113 Subramonia S, Lees T. Randomized clinical trial of radiofrequency ablation or conventional high ligation and stripping for great saphenous varicose veins. Br J Surg. 2010 Mar;97(3):328-36. doi: 10.1002/bjs.6867. PMID: 20035541.20035541
114 Theivacumar NS, Dellagrammaticas D, Mavor AI, . Endovenous laser ablation: does standard above-knee great saphenous vein ablation provide optimum results in patients with both above- and below-knee reflux? A randomized controlled trial. J Vasc Surg. 2008 Jul;48(1):173-8. doi: 10.1016/j.jvs.2008.01.062. PMID: 18440756.18440756
115 Todd KL, 3rd, Wright DI. The VANISH-2 study: a randomized, blinded, multicenter study to evaluate the efficacy and safety of polidocanol endovenous microfoam 0.5% and 1.0% compared with placebo for the treatment of saphenofemoral junction incompetence. Phlebology. 2014 Oct;29(9):608-18. doi: 10.1177/0268355513497709. PMID: 23864535.23864535
116 van den Bos RR, Malskat WS, De Maeseneer MG, . Randomized clinical trial of endovenous laser ablation versus steam ablation (LAST trial) for great saphenous varicose veins. Br J Surg. 2014 Aug;101(9):1077-83. doi: 10.1002/bjs.9580. PMID: 24981585.24981585
117 van Gent WB, Hop WC, van Praag MC, . Conservative versus surgical treatment of venous leg ulcers: a prospective, randomized, multicenter trial. J Vasc Surg. 2006 Sep;44(3):563-71. doi: 10.1016/j.jvs.2006.04.053. PMID: 16950434.16950434
118 van Gent WB, Catarinella FS, Lam YL, . Conservative versus surgical treatment of venous leg ulcers: 10-year follow up of a randomized, multicenter trial. Phlebology. 2015 Mar;30(1 Suppl):35-41. doi: 10.1177/0268355514568848. PMID: 25729066.25729066
119 Vandongen YK, Stacey MC. Graduated compression elastic stockings reduce lipodermatosclerosis and ulcer recurrence. Phlebology. 2000;15(1):33-7.
120 Vanscheidt W, Rabe E, Naser-Hijazi B, . The efficacy and safety of a coumarin/troxerutin-combination (SB-LOT) in patients with chronic venous insufficiency: a double blind placebo-controlled randomised study. Vasa. 2002 Aug;31(3):185-90. doi: 10.1024/0301-1526.31.3.185. PMID: 12236023.12236023
121 Vasquez M, Gasparis AP. A multicenter, randomized, placebo-controlled trial of endovenous thermal ablation with or without polidocanol endovenous microfoam treatment in patients with great saphenous vein incompetence and visible varicosities. Phlebology. 2016 Mar 7doi: 10.1177/0268355516637300. PMID: 26957489.26957489
122 Viarengo LM, Poterio-Filho J, Poterio GM, . Endovenous laser treatment for varicose veins in patients with active ulcers: measurement of intravenous and perivenous temperatures during the procedure. Dermatol Surg. 2007 Oct;33(10):1234-42; discussion 41-2. doi: 10.1111/j.15244725.2007.33259.x. PMID: 17903157.17903157
123 Wang H, Chen Q, Fei Z, . Hemodynamic classification and CHIVA treatment of varicose veins in lower extremities (VVLE). Int J Clin Exp Med. 2016;9(2):2465-71.
124 Wong IK, Andriessen A, Charles HE, . Randomized controlled trial comparing treatment outcome of two compression bandaging systems and standard care without compression in patients with venous leg ulcers. J Eur Acad Dermatol Venereol. 2012 Jan;26(1):102-10. doi: 10.1111/j.14683083.2011.04327.x. PMID: 22077933.22077933
125 Wozniak W, Mlosek RK, Ciostek P. Assessment of the efficacy and safety of steam vein sclerosis as compared to classic surgery in lower extremity varicose vein management. Wideochir Inne Tech Maloinwazyjne. 2015 Apr;10(1):15-24. doi: 10.5114/wiitm.2015.48573. PMID: 25960788.25960788
126 Wright D, Gobin JP, Bradbury AW, . Varisolve® polidocanol microfoam compared with surgery or sclerotherapy in the management of varicose veins in the presence of trunk vein incompetence: European randomized controlled trial. Phlebology. 2006;21(4):180-90.
127 Yang L, Wang XP, Su WJ, . Randomized clinical trial of endovenous microwave ablation combined with high ligation versus conventional surgery for varicose veins. Eur J Vasc Endovasc Surg. 2013 Oct;46(4):473-9. doi: 10.1016/j.ejvs.2013.07.004. PMID: 23911734.23911734
128 Zamboni P, Cisno C, Marchetti F, . Minimally invasive surgical management of primary venous ulcers vs. compression treatment: a randomized clinical trial. Eur J Vasc Endovasc Surg. 2003 Apr;25(4):313-8. doi: 10.1053/ejvs.2002.1871. PMID: 12651168.12651168
129 Zamboni P, Cisno C, Marchetti F, . Haemodynamic CHIVA correction surgery versus compression for primary venous ulcers: First year results. Phlebology. 2004;19(1):28-34.
130 Garg N, Gloviczki P, Karimi KM, . Factors affecting outcome of open and hybrid reconstructions for nonmalignant obstruction of iliofemoral veins and inferior vena cava. J Vasc Surg. 2011 Feb;53(2):383-93. doi: 10.1016/j.jvs.2010.08.086. PMID: 21146346.21146346
131 Ginsberg JS, Hirsh J, Julian J, . Prevention and treatment of postphlebitic syndrome: results of a 3-part study. Arch Intern Med. 2001 Sep 24;161(17):2105-9. PMID: 11570939.11570939
132 Holmes CE, Bambace NM, Lewis P, . Efficacy of a short course of complex lymphedema therapy or graduated compression stocking therapy in the treatment of post-thrombotic syndrome. Vasc Med. 2014 Feb;19(1):42-8. doi: 10.1177/1358863x14521883. PMID: 24558028.24558028
133 Kahn SR, Shrier I, Shapiro S, . Sixmonth exercise training program to treat post-thrombotic syndrome: a randomized controlled two-centre trial. CMAJ. 2011 Jan 11;183(1):37-44. doi: 10.1503/cmaj.100248. PMID: 21098066.21098066
134 O’Sullivan GJ, Semba CP, Bittner CA, . Endovascular management of iliac vein compression (May-Thurner) syndrome. J Vasc Interv Radiol. 2000 JulAug;11(7):823-36. PMID: 10928517.10928517
135 Raju S, Kirk OK, Jones TL. Endovenous management of venous leg ulcers. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(2):165-72.26992338
136 Yin M, Shi H, Ye K, . Clinical Assessment of Endovascular Stenting Compared with Compression Therapy Alone in Post-thrombotic Patients with Iliofemoral Obstruction. Eur J Vasc Endovasc Surg. 2015 Jul;50(1):101-7. doi: 10.1016/j.ejvs.2015.02.007. PMID: 25920630.25920630
137 Yin M, Huang X, Cui C, . The effect of stent placement for May-Thurner syndrome combined with symptomatic superficial venous reflux disease. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2015;3(2):168-72.26993835