# Appendix E Key to Included Primary and Companion Articles

Study Designation | Primary Abstracted Article | Companion Articles
CLASS (The Comparison of LAser, Surgery and foam Sclerotherapy) | Brittenden, 2014^1^ | Brittenden, 2015^2^
EASI Study (The Efficacy and Safety of Aethoxysklerol®, Sotradecol® and Isotonic Saline for the Sclerotherapy of Telanglectasias and Reticular Varicose Veins) | Rabe, 2010^3^ | None
ESCHAR Trial (The Effect of Surgery and Compression on Healing And Recurrence) | Barwell, 2004^4^ | Gohel, 2007^5^ Gohel, 2005^6^ Gohel, 2005^7^
Evlt Versus Vnus Endovenous Randomised Trial study | Nordon, 2011^8^ | None
EVoLVeS (EndoVenous radiofrequency obliteration versus Ligation and Vein Stripping) | Lurie, 2003^9^ | Lurie, 2011^10^ Lurie, 2005^11^
HELP-1 (The Hull Endovenous Laser Project 1) | Carradice, 2011^12^ | Carradice, 2011^13^
HELP-2 (The Hull Endovenous Laser Project 2) | Samuel, 2013^14^ | Nandhra, 2015^15^
LARA (The Laser And Radiofrequency Ablation study) | Goode, 2010^16^ | None
LAST Trial (Laser Ablation versus STeam ablation) | van den Bos, 2014^17^ | None
MAGNA Trial | Biemans, 2013^18^ | van der Velden, 2015^19^
REACTIV (The Randomised and | Michaels, 2006^20^ | None
REACTIV (The Randomised and | Michaels, 2006^21^ | None
Economic Assessment of Conservative and Therapeutic Interventions for Varicose Veins) | Michaels, 2006^22^ | Michaels, 2006^23^
RECOVERY study | Almeida, 2009^24^ | None
RELACS (The Randomized study comparing Endovenous Laser Ablation with Crossectomy and Stripping of the great saphenous vein | Rass, 2012^25^ | Rass, 2015^26^
SUAVIS (The SUIodexide Arterial Venous Italian Study) | Coccheri, 2002^27^ | None
VALVV Study (VNUS ClosureFAST radiofrequency Ablation versus 980nm Laser for Varicose Veins) | Shepherd, 2010^28^ | Shepherd, 2015^29^
VANISH-1 | King, 2015^30^ | None
VANISH-2 | Todd, 2014^31^ | None
Varithena 013 | Gibson, 2016^32^ | None
Varithena 017 | Vasquez, 2016^33^ | None
VeCLoSE Trial | Morrison, 2015^34^ | None
VEDICO (VEnous Disease Control Trial) | Belcaro, 2003^35^ | Belcaro, 2003^36^
None | Bountouroglou, 2006^37^ | Kalodiki, 2012^38^
None | Disselhoff, 2008^39^ | Disselhoff, 2009^40^ Disselhoff, 2011^41^
None | Flessenkamper, 2013^42^ | Flessenkamper, 2016^43^
None | Kalteis, 2008^44^ | Kalteis, 2015^43^
None | Lane, 2016^46^ | Bootun, 2016^47^
None | Lattimer, 2013^48^ | Lattimer, 2012^49^
None | Pronk, 2010^50^ | Gauw, 2016^51^
None | Rasmussen, 2011^52^ | Rasmussen, 2013^53^
None | Rasmussen, 2007^54^ | Rasmussen, 2010^55^ Rasmussen, 2013^56^
None | Rautio, 2002^57^ | Perala, 2005^58^
None | van Gent, 2006^59^ | van Gent, 2015^60^
None | Zamboni, 2003^61^ | Zamboni, 2004^62^
None | Abela, 2008^63^ | None
None | Aguilar-Ferrandiz, 2014^64^ | None
None | Aguilar-Ferrandiz, 2014^65^ | None
None | Aguilar-Ferrandiz, 2013^66^ | None
None | Al Shammeri, 2014^67^ | None
None | Antoch, 2002^68^ | None
None | Basela, 2011^69^ | None
None | Belcaro, 2000^70^ | None
None | Belcaro, 2015^71^ | None
None | Benarroch-Gampel, 2013^72^ | None
None | Campos, 2015^73^ | None
None | Carpentier, 2014^74^ | None
None | Carradice, 2009^75^ | None
None | Carruthers, 2014^76^ | None
None | Christenson, 2010^77^ | None
None | Clarke-Moloney, 2005^78^ | None
None | Darwood, 2008^79^ | None
None | De Franciscis, 2013^80^ | None
None | de Roos, 2003^81^ | None
None | del Rio Sola, 2012^82^ | None
None | Depalma, 2000^83^ | None
None | Elderman, 2014^84^ | None
None | Figueiredo, 2009^85^ | None
None | Franek, 2006^86^ | None
None | Gale, 2010^87^ | None
None | Garg, 2011^88^ | None
None | Ginsberg, 2001^89^ | None
None | Guest, 2003^90^ | None
None | Hamel-Desnos, 2010^91^ | None
None | Helmy ElKaffas, 2011^92^ | None
None | Holmes, 2014^93^ | None
None | Houtermans-Auckel, 2009^94^ | None
None | Jull, 2009^95^ | None
None | Kahle, 2004^96^ | None
None | Kahn, 2011^97^ | None
None | Kayilioglu, 2016^98^ | None
None | Klem, 2009^99^ | None
None | Kumar, 2002^100^ | None
None | Kurstjens, 2016^101^ | None
None | Lee, 2008^102^ | None
None | Liu, 2011^103^ | None
None | Liu, 2011^104^ | None
None | Mantoni, 2002^105^ | None
None | Massenburg, 2015^106^ | None
None | Menyhei, 2008^107^ | None
None | Meyer, 2000^108^ | None
None | Moreno-Moraga, 2014^109^ | None
None | Mousa, 2016^110^ | None
None | Mozafar, 2014^111^ | None
None | Nelson, 2007^112^ | None
None | Nikolovska, 2002^113^ | None
None | Noppeney, 2016^114^ | None
None | obi, 2015^115^ | None
None | o’Hare, 2010^116^ | None
None | o’Sullivan, 2000^117^ | None
None | Pares, 2010^118^ | None
None | Rabahie, 2011^119^ | None
None | Raju, 2013^120^ | None
None | Roopram, 2013^121^ | None
None | Schouten, 2006^122^ | None
None | Sell, 2014^123^ | None
None | Serra, 2015^124^ | None
None | Shadid, 2012^125^ | None
None | Stotter, 2006^126^ | None
None | Subramonia, 2001^127^ | None
None | Theivacumar, 2008^128^ | None
None | Vandongen, 2000^129^ | None
None | Vanscheidt, 2002^130^ | None
None | Viarengo, 2007^131^ | None
None | Wang, 2016^132^ | None
None | Wong, 2012^133^ | None
None | Wozniak, 2015^134^ | None
None | Wright, 2006^135^ | None
None | Yang, 2013^136^ | None
None | Yin, 2015^137^ | None
None | Yin, 2015^138^ | None

## References to Appendix E:

1 Brittenden J, Cotton SC, Elders A, . A randomized trial comparing treatments for varicose veins. N Engl J Med. 2014 Sep 25;371(13):1218-27. doi: 10.1056/NEJMoa1400781. PMID: 25251616.25251616
2 Brittenden J, Cotton SC, Elders A, . Clinical effectiveness and cost-effectiveness of foam sclerotherapy, endovenous laser ablation and surgery for varicose veins: results from the Comparison of LAser, Surgery and foam Sclerotherapy (CLASS) randomised controlled trial. Health Technol Assess. 2015 Apr;19(27):1-342. doi: 10.3310/hta19270. PMID: 25858333.25858333
3 Rabe E, Schliephake D, otto J, . Sclerotherapy of telangiectases and reticular veins: a double-blind, randomized, comparative clinical trial of polidocanol, sodium tetradecyl sulphate and isotonic saline (EASI study). Phlebology. 2010 Jun;25(3):124-31. doi: 10.1258/phleb.2009.009043. PMID: 20483861.20483861
4 Barwell JR, Davies CE, Deacon J, . Comparison of surgery and compression with compression alone in chronic venous ulceration (ESCHAR study): randomised controlled trial. Lancet. 2004 Jun 5;363(9424):1854-9. doi: 10.1016/s01406736(04)16353-8. PMID: 15183623.15183623
5 Gohel MS, Barwell JR, Taylor M, . Long term results of compression therapy alone versus compression plus surgery in chronic venous ulceration (ESCHAR): randomised controlled trial. BMJ. 2007 Jul 14;335(7610):83. doi: 10.1136/bmj.39216.542442.BE. PMID: 17545185.17545185
6 Gohel MS, Barwell JR, Earnshaw JJ, . Randomized clinical trial of compression plus surgery versus compression alone in chronic venous ulceration (ESCHAR study)-haemodynamic and anatomical changes. Br J Surg. 2005 Mar;92(3):291-7. doi: 10.1002/bjs.4837. PMID: 15584055.15584055
7 Gohel MS, Barwell JR, Wakely C, . The influence of superficial venous surgery and compression on incompetent calf perforators in chronic venous leg ulceration. Eur J Vasc Endovasc Surg. 2005 Jan;29(1):78-82. doi: 10.1016/j.ejvs.2004.09.016. PMID: 15570276.15570276
8 Nordon IM, Hinchliffe RJ, Brar R, . A prospective double-blind randomized controlled trial of radiofrequency versus laser treatment of the great saphenous vein in patients with varicose veins. Ann Surg. 2011 Dec;254(6):876-81. doi: 10.1097/SLA.0b013e318230af5a. PMID: 21934487.21934487
9 Lurie F, Creton D, Eklof B, . Prospective randomized study of endovenous radiofrequency obliteration (closure procedure) versus ligation and stripping in a selected patient population (EVoLVeS Study). J Vasc Surg. 2003 Aug;38(2):207-14. PMID: 12891099.12891099
10 Lurie F, Creton D, Eklof B, . Reprinted article "Prospective randomised study of endovenous radiofrequency obliteration (closure) versus ligation and vein stripping (EVoLVeS): two-year follow-up". Eur J Vasc Endovasc Surg. 2011 Sep;42 Suppl 1:S107-13. doi: 10.1016/j.ejvs.2011.06.019. PMID: 21855011.21855011
11 Lurie F, Creton D, Eklof B, . Prospective randomised study of endovenous radiofrequency obliteration (closure) versus ligation and vein stripping (EVoLVeS): two-year follow-up. Eur J Vasc Endovasc Surg. 2005 Jan;29(1):67-73. doi: 10.1016/j.ejvs.2004.09.019. PMID: 15570274.15570274
12 Carradice D, Mekako AI, Mazari FA, . Randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg. 2011 Apr;98(4):501-10. doi: 10.1002/bjs.7394. PMID: 21283981.21283981
13 Carradice D, Mekako AI, Mazari FA, . Clinical and technical outcomes from a randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1117-23. doi: 10.1002/bjs.7615. PMID: 21638277.21638277
14 Samuel N, Carradice D, Wallace T, . Randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. Ann Surg. 2013 Mar;257(3):419-26. doi: 10.1097/SLA.0b013e318275f4e4. PMID: 23160149.23160149
15 Nandhra S, El-sheikha J, Carradice D, . A randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. J Vasc Surg. 2015 Mar;61(3):741-6. doi: 10.1016/j.jvs.2014.09.037. PMID: 25720930.25720930
16 Goode SD, Chowdhury A, Crockett M, . Laser and radiofrequency ablation study (LARA study): a randomised study comparing radiofrequency ablation and endovenous laser ablation (810 nm). Eur J Vasc Endovasc Surg. 2010 Aug;40(2):246-53. doi: 10.1016/j.ejvs.2010.02.026. PMID: 20537570.20537570
17 van den Bos RR, Malskat WS, De Maeseneer MG, . Randomized clinical trial of endovenous laser ablation versus steam ablation (LAST trial) for great saphenous varicose veins. Br J Surg. 2014 Aug;101(9):1077-83. doi: 10.1002/bjs.9580. PMID: 24981585.24981585
18 Biemans AA, Kockaert M, Akkersdijk GP, . Comparing endovenous laser ablation, foam sclerotherapy, and conventional surgery for great saphenous varicose veins. J Vasc Surg. 2013 Sep;58(3):727-34.e1. doi: 10.1016/j.jvs.2012.12.074. PMID: 23769603.23769603
19 van der Velden SK, Biemans AA, De Maeseneer MG, . Five-year results of a randomized clinical trial of conventional surgery, endovenous laser ablation and ultrasound-guided foam sclerotherapy in patients with great saphenous varicose veins. Br J Surg. 2015 Sep;102(10):1184-94. doi: 10.1002/bjs.9867. PMID: 26132315.26132315
20 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 1]. Health Technol Assess. 2006 Apr;10(13):1-196, iii-iv. PMID: 16707070.16707070
21 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 2]. Health Technol Assess. 2006;10(13):1-196, iii-iv. PMID: 16707070.16707070
22 Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial) [Study 3]. Health Technol Assess. 2006;10(13):1-196, iii-iv.
23 Michaels JA, Brazier JE, Campbell WB, . Randomized clinical trial comparing surgery with conservative treatment for uncomplicated varicose veins. Br J Surg. 2006 Feb;93(2):175-81. doi: 10.1002/bjs.5264. PMID: 16432825.16432825
24 Almeida JI, Kaufman J, Gockeritz o, . Radiofrequency endovenous ClosureFAST versus laser ablation for the treatment of great saphenous reflux: a multicenter, single-blinded, randomized study (RECOVERY study). J Vasc Interv Radiol. 2009 Jun;20(6):752-9. doi: 10.1016/j.jvir.2009.03.008. PMID: 19395275.19395275
25 Rass K, Frings N, Glowacki P, . Comparable effectiveness of endovenous laser ablation and high ligation with stripping of the great saphenous vein: two- year results of a randomized clinical trial (RELACS study). Arch Dermatol. 2012 Jan;148(1):49-58. doi: 10.1001/archdermatol.2011.272. PMID: 21931012.21931012
26 Rass K, Frings N, Glowacki P, . Same Site Recurrence is More Frequent After Endovenous Laser Ablation Compared with High Ligation and Stripping of the Great Saphenous Vein: 5 year Results of a Randomized Clinical Trial (RELACS Study). Eur J Vasc Endovasc Surg. 2015 Nov;50(5):648-56. doi: 10.1016/j.ejvs.2015.07.020. PMID: 26319476.26319476
27 Coccheri S, Scondotto G, Agnelli G, . Randomised, double blind, multicentre, placebo controlled study of sulodexide in the treatment of venous leg ulcers. Thromb Haemost. 2002 Jun;87(6):947-52. PMID: 12083500.12083500
28 Shepherd AC, Gohel MS, Brown LC, . Randomized clinical trial of VNUS ClosureFAST radiofrequency ablation versus laser for varicose veins. Br J Surg. 2010 Jun;97(6):810-8. doi: 10.1002/bjs.7091. PMID: 20473992.20473992
29 Shepherd AC, ortega-ortega M, Gohel MS, . CoST-EFFECTIVENESS oF RADIoFREQUENCY ABLATIoN VERSUS LASER FoR VARICoSE VEINS. Int J Technol Assess Health Care. 2015 Jan;31(5):289-96. doi: 10.1017/s0266462315000537. PMID: 26715372.26715372
30 King JT, o’Byrne M, Vasquez M, . Treatment of Truncal Incompetence and Varicose Veins with a Single Administration of a New Polidocanol Endovenous Microfoam Preparation Improves Symptoms and Appearance. Eur J Vasc Endovasc Surg. 2015 Dec;50(6):784-93. doi: 10.1016/j.ejvs.2015.06.111. PMID: 26384639.26384639
31 Todd KL, 3rd, Wright DI. The VANISH-2 study: a randomized, blinded, multicenter study to evaluate the efficacy and safety of polidocanol endovenous microfoam 0.5% and 1.0% compared with placebo for the treatment of saphenofemoral junction incompetence. Phlebology. 2014 oct;29(9):608-18. doi: 10.1177/0268355513497709. PMID: 23864535.23864535
32 Gibson K, Kabnick L. A multicenter, randomized, placebo-controlled study to evaluate the efficacy and safety of Varithena(R) (polidocanol endovenous microfoam 1%) for symptomatic, visible varicose veins with saphenofemoral junction incompetence. Phlebology. 2016 Mar 24doi: 10.1177/0268355516635386. PMID: 27013511.27013511
33 Vasquez M, Gasparis AP. A multicenter, randomized, placebo-controlled trial of endovenous thermal ablation with or without polidocanol endovenous microfoam treatment in patients with great saphenous vein incompetence and visible varicosities. Phlebology. 2016 Mar 7doi: 10.1177/0268355516637300. PMID: 26957489.26957489
34 Morrison N, Gibson K, McEnroe S, . Randomized trial comparing cyanoacrylate embolization and radiofrequency ablation for incompetent great saphenous veins (VeClose). J Vasc Surg. 2015 Apr;61(4):985-94. doi: 10.1016/j.jvs.2014.11.071. PMID: 25650040.25650040
35 Belcaro G, Cesarone MR, Di Renzo A, . Foam-sclerotherapy, surgery, sclerotherapy, and combined treatment for varicose veins: a 10-year, prospective, randomized, controlled, trial (VEDICO trial). Angiology. 2003 May-Jun;54(3):307-15. PMID: 12785023.12785023
36 Belcaro G, Cesarone M, Di Renzo A, . Treatments for varicose veins: Surgery, sclerotherapy, foamsclerotherapy and combined (surgery+sclerotherapy) options. A 10-year, prospective, randomised, controlled, follow-up study. The VEDICO* trial and EST (European Sclerotherapy Trial). Angeiologie. 2003;55(1):29-36.
37 Bountouroglou DG, Azzam M, Kakkos SK, . Ultrasound-guided foam sclerotherapy combined with sapheno-femoral ligation compared to surgical treatment of varicose veins: early results of a randomised controlled trial. Eur J Vasc Endovasc Surg. 2006 Jan;31(1):93-100. doi: 10.1016/j.ejvs.2005.08.024. PMID: 16233981.16233981
38 Kalodiki E, Lattimer CR, Azzam M, . Long-term results of a randomized controlled trial on ultrasound-guided foam sclerotherapy combined with saphenofemoral ligation vs standard surgery for varicose veins. J Vasc Surg. 2012 Feb;55(2):451-7. doi: 10.1016/j.jvs.2011.08.040. PMID: 22104345.22104345
39 Disselhoff BC, der Kinderen DJ, Kelder JC, . Randomized clinical trial comparing endovenous laser with cryostripping for great saphenous varicose veins. Br J Surg. 2008 oct;95(10):1232-8. doi: 10.1002/bjs.6351. PMID: 18763255.18763255
40 Disselhoff BC, Buskens E, Kelder JC, . Randomised comparison of costs and costeffectiveness of cryostripping and endovenous laser ablation for varicose veins: 2-year results. Eur J Vasc Endovasc Surg. 2009 Mar;37(3):357-63. doi: 10.1016/j.ejvs.2008.11.013. PMID: 19111485.19111485
41 Disselhoff BC, der Kinderen DJ, Kelder JC, . Five-year results of a randomized clinical trial comparing endovenous laser ablation with cryostripping for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1107-11. doi: 10.1002/bjs.7542. PMID: 21633948.21633948
42 Flessenkamper I, Hartmann M, Stenger D, . Endovenous laser ablation with and without high ligation compared with high ligation and stripping in the treatment of great saphenous varicose veins: initial results of a multicentre randomized controlled trial. Phlebology. 2013 Feb;28(1):16-23. doi: 10.1258/phleb.2011.011147. PMID: 22451455.22451455
43 Flessenkamper I, Hartmann M, Hartmann K, . Endovenous laser ablation with and without high ligation compared to high ligation and stripping for treatment of great saphenous varicose veins: Results of a multicentre randomised controlled trial with up to 6 years follow-up. Phlebology. 2016 oct 22;31(1):23-33. doi: 10.1177/0268355514555547. PMID: 25342648.25342648
44 Kalteis M, Berger I, Messie-Werndl S, . High ligation combined with stripping and endovenous laser ablation of the great saphenous vein: early results of a randomized controlled study. J Vasc Surg. 2008 Apr;47(4):822-9; discussion 9. doi: 10.1016/j.jvs.2007.10.060. PMID: 18295441.18295441
45 Kalteis M, Adelsgruber P, Messie-Werndl S, . Five-year results of a randomized controlled trial comparing high ligation combined with endovenous laser ablation and stripping of the great saphenous vein. Dermatol Surg. 2015 May;41(5):579-86. doi: 10.1097/dss.0000000000000369. PMID: 25899888.25899888
46 Lane T, Bootun R, Dharmarajah B, . A multi-centre randomised controlled trial comparing radiofrequency and mechanical occlusion chemically assisted ablation of varicose veins - Final results of the Venefit versus Clarivein for varicose veins trial. Phlebology. 2016 May 24doi: 10.1177/0268355516651026. PMID: 27221810.27221810
47 Bootun R, Lane T, Dharmarajah B, . Intra-procedural pain score in a randomised controlled trial comparing mechanochemical ablation to radiofrequency ablation: The Multicentre Venefit versus ClariVein(R) for varicose veins trial. Phlebology. 2016;31(1):61-5. doi: 10.1177/0268355514551085. PMID: 25193822.25193822
48 Lattimer CR, Kalodiki E, Azzam M, . Interim results on abolishing reflux alongside a randomized clinical trial on laser ablation with phlebectomies versus foam sclerotherapy. Int Angiol. 2013 Aug;32(4):394-403. PMID: 23822942.23822942
49 Lattimer CR, Azzam M, Kalodiki E, . Cost and effectiveness of laser with phlebectomies compared with foam sclerotherapy in superficial venous insufficiency. Early results of a randomised controlled trial. Eur J Vasc Endovasc Surg. 2012 May;43(5):594-600. doi: 10.1016/j.ejvs.2012.01.032. PMID: 22386383.22386383
50 Pronk P, Gauw SA, Mooij MC, . Randomised controlled trial comparing sapheno-femoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anaesthesia: one year results. Eur J Vasc Endovasc Surg. 2010 Nov;40(5):649-56. doi: 10.1016/j.ejvs.2010.08.007. PMID: 20888274.20888274
51 Gauw SA, Lawson JA, van Vlijmen-van Keulen CJ, . Five-year follow-up of a randomized, controlled trial comparing saphenofemoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anesthesia. J Vasc Surg. 2016 oct 22;63(2):420-8. doi: 10.1016/j.jvs.2015.08.084. PMID: 26602795.26602795
52 Rasmussen LH, Lawaetz M, Bjoern L, . Randomized clinical trial comparing endovenous laser ablation, radiofrequency ablation, foam sclerotherapy and surgical stripping for great saphenous varicose veins. Br J Surg. 2011 Aug;98(8):1079-87. doi: 10.1002/bjs.7555. PMID: 21725957.21725957
53 Rasmussen L, Lawaetz M, Serup J, . Randomized clinical trial comparing endovenous laser ablation, radiofrequency ablation, foam sclerotherapy, and surgical stripping for great saphenous varicose veins with 3-year follow-up. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(4):349-56.26992754
54 Rasmussen LH, Bjoern L, Lawaetz M, . Randomized trial comparing endovenous laser ablation of the great saphenous vein with high ligation and stripping in patients with varicose veins: short-term results. J Vasc Surg. 2007 Aug;46(2):308-15. doi: 10.1016/j.jvs.2007.03.053. PMID: 17600655.17600655
55 Rasmussen LH, Bjoern L, Lawaetz M, . Randomised clinical trial comparing endovenous laser ablation with stripping of the great saphenous vein: clinical outcome and recurrence after 2 years. Eur J Vasc Endovasc Surg. 2010 May;39(5):630-5. doi: 10.1016/j.ejvs.2009.11.040. PMID: 20064730.20064730
56 Rasmussen L, Lawaetz M, Bjoern L, . Randomized clinical trial comparing endovenous laser ablation and stripping of the great saphenous vein with clinical and duplex outcome after 5 years. J Vasc Surg. 2013 Aug;58(2):421-6. doi: 10.1016/j.jvs.2012.12.048. PMID: 23768792.23768792
57 Rautio T, ohinmaa A, Perala J, . Endovenous obliteration versus conventional stripping operation in the treatment of primary varicose veins: a randomized controlled trial with comparison of the costs. J Vasc Surg. 2002 May;35(5):958-65. PMID: 12021712.12021712
58 Perala J, Rautio T, Biancari F, . Radiofrequency endovenous obliteration versus stripping of the long saphenous vein in the management of primary varicose veins: 3-year outcome of a randomized study. Ann Vasc Surg. 2005 Sep;19(5):669-72. doi: 10.1007/s10016-005-6613-2. PMID: 16052388.16052388
59 van Gent WB, Hop WC, van Praag MC, . Conservative versus surgical treatment of venous leg ulcers: a prospective, randomized, multicenter trial. J Vasc Surg. 2006 Sep;44(3):563-71. doi: 10.1016/j.jvs.2006.04.053. PMID: 16950434.16950434
60 van Gent WB, Catarinella FS, Lam YL, . Conservative versus surgical treatment of venous leg ulcers: 10-year follow up of a randomized, multicenter trial. Phlebology. 2015 Mar;30(1 Suppl):35-41. doi: 10.1177/0268355514568848. PMID: 25729066.25729066
61 Zamboni P, Cisno C, Marchetti F, . Minimally invasive surgical management of primary venous ulcers vs. compression treatment: a randomized clinical trial. Eur J Vasc Endovasc Surg. 2003 Apr;25(4):313-8. doi: 10.1053/ejvs.2002.1871. PMID: 12651168.12651168
62 Zamboni P, Cisno C, Marchetti F, . Haemodynamic CHIVA correction surgery versus compression for primary venous ulcers: First year results. Phlebology. 2004;19(1):28-34.
63 Abela R, Liamis A, Prionidis I, . Reverse foam sclerotherapy of the great saphenous vein with sapheno-femoral ligation compared to standard and invagination stripping: a prospective clinical series. Eur J Vasc Endovasc Surg. 2008 oct;36(4):485-90. doi: 10.1016/j.ejvs.2008.06.029. PMID: 18718769.18718769
64 Aguilar-Ferrandiz ME, Moreno-Lorenzo C, Mataran-Penarrocha GA, . Effect of a mixed kinesio taping-compression technique on quality of life and clinical and gait parameters in postmenopausal women with chronic venous insufficiency: doubleblinded, randomized controlled trial. Arch Phys Med Rehabil. 2014 Jul;95(7):1229-39. doi: 10.1016/j.apmr.2014.03.024. PMID: 24732169.24732169
65 Aguilar-Ferrandiz ME, Castro-Sanchez AM, Mataran-Penarrocha GA, . A randomized controlled trial of a mixed Kinesio taping-compression technique on venous symptoms, pain, peripheral venous flow, clinical severity and overall health status in postmenopausal women with chronic venous insufficiency. Clin Rehabil. 2014 Jan;28(1):69-81. doi: 10.1177/0269215512469120. PMID: 23426563.23426563
66 Aguilar-Ferrandiz ME, Castro-Sanchez AM, Mataran-Penarrocha GA, . Effects of kinesio taping on venous symptoms, bioelectrical activity of the gastrocnemius muscle, range of ankle motion, and quality of life in postmenopausal women with chronic venous insufficiency: a randomized controlled trial. Arch Phys Med Rehabil. 2013 Dec;94(12):2315-28. doi: 10.1016/j.apmr.2013.05.016. PMID: 23769763.23769763
67 Al Shammeri o, AlHamdan N, Al-Hothaly B, . Chronic Venous Insufficiency: prevalence and effect of compression stockings. Int J Health Sci (Qassim). 2014 Jul;8(3):231-6. PMID: 25505858.25505858
68 Antoch G, Pourhassan S, Hansen o, . Comparison of colour Doppler ultrasonography, ascending phlebography and clinical examination in the diagnosis of incompetent calf perforating veins. Br J Surg. 2002 Feb;89(2):192-3. doi: 10.1046/j.0007-1323.2001.02003.x. PMID: 11856132.11856132
69 Basela H, Aydina C, Aya Y, . Endovenous laser ablation (EVLA) versus high ligation and striping (HL/S): Two-years follow up. Eastern Journal of Medicine. 2011;17(2):83-7.
70 Belcaro G, Nicolaides AN, Ricci A, . Endovascular sclerotherapy, surgery, and surgery plus sclerotherapy in superficial venous incompetence: a randomized, 10year follow-up trial--final results. Angiology. 2000 Jul;51(7):529-34. PMID: 10917577.10917577
71 Belcaro G, Dugall M, Corsi M. Superficial venous incompetence: Low-cost outpatient mini-surgery, sclerotherapy and combined procedure as a management plan. Costs and efficacy. A 20-year, follow-up registry. Minerva Chir. 2015 Jun 5 PMID: 26046959.26046959
72 Benarroch-Gampel J, Sheffield KM, Boyd CA, . Analysis of venous thromboembolic events after saphenous ablation. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(1):26-32.26993890
73 Campos W, Jr., Torres Io, da Silva ES, . A prospective randomized study comparing polidocanol foam sclerotherapy with surgical treatment of patients with primary chronic venous insufficiency and ulcer. Ann Vasc Surg. 2015 Aug;29(6):1128-35. doi: 10.1016/j.avsg.2015.01.031. PMID: 26004968.26004968
74 Carpentier PH, Blaise S, Satger B, . A multicenter randomized controlled trial evaluating balneotherapy in patients with advanced chronic venous insufficiency. J Vasc Surg. 2014 Feb;59(2):447-54.e1. doi: 10.1016/j.jvs.2013.08.002. PMID: 24135621.24135621
75 Carradice D, Mekako AI, Hatfield J, . Randomized clinical trial of concomitant or sequential phlebectomy after endovenous laser therapy for varicose veins. Br J Surg. 2009 Apr;96(4):369-75. doi: 10.1002/bjs.6556. PMID: 19283745.19283745
76 Carruthers TN, Farber A, Rybin D, . Interventions on the superficial venous system for chronic venous insufficiency by surgeons in the modern era: an analysis of ACS-NSQIP. Vasc Endovascular Surg. 2014 oct-Nov;48(7-8):482-90. doi: 10.1177/1538574414561226. PMID: 25487248.25487248
77 Christenson JT, Gueddi S, Gemayel G, . Prospective randomized trial comparing endovenous laser ablation and surgery for treatment of primary great saphenous varicose veins with a 2-year follow-up. J Vasc Surg. 2010 Nov;52(5):1234-41. doi: 10.1016/j.jvs.2010.06.104. PMID: 20801608.20801608
78 Clarke-Moloney M, o’Brien JF, Grace PA, . Health-related quality of life during four-layer compression bandaging for venous ulcer disease: a randomised controlled trial. Ir J Med Sci. 2005 Apr Jun;174(2):21-5. PMID: 16094908.16094908
79 Darwood RJ, Theivacumar N, Dellagrammaticas D, . Randomized clinical trial comparing endovenous laser ablation with surgery for the treatment of primary great saphenous varicose veins. Br J Surg. 2008 Mar;95(3):294-301. doi: 10.1002/bjs.6101. PMID: 18278775.18278775
80 De Franciscis S, Gasbarro V, Amato B, . Hemodynamic surgery versus conventional surgery in chronic venous disease: A multicenter retrospective study. Acta Phlebologica. 2013;14(3):109-14.
81 de Roos KP, Nieman FH, Neumann HA. Ambulatory phlebectomy versus compression sclerotherapy: results of a randomized controlled trial. Dermatol Surg. 2003 Mar;29(3):221-6. PMID: 12614412.12614412
82 del Rio Sola ML, Antonio J, Fajardo G, . Influence of aspirin therapy in the ulcer associated with chronic venous insufficiency. Ann Vasc Surg. 2012 Jul;26(5):620-9. doi: 10.1016/j.avsg.2011.02.051. PMID: 22437068.22437068
83 Depalma RG, Kowallek DL, Barcia TC, . Target selection for surgical intervention in severe chronic venous insufficiency: comparison of duplex scanning and phlebography. J Vasc Surg. 2000 Nov;32(5):913-20. doi: 10.1067/mva.2000.110347. PMID: 11054223.11054223
84 Elderman JH, Krasznai AG, Voogd AC, . Role of compression stockings after endovenous laser therapy for primary varicosis. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2014;2(3):289-96.26993388
85 Figueiredo M, Araujo S, Barros N, Jr., . Results of surgical treatment compared with ultrasound-guided foam sclerotherapy in patients with varicose veins: a prospective randomised study. Eur J Vasc Endovasc Surg. 2009 Dec;38(6):758-63. doi: 10.1016/j.ejvs.2009.07.015. PMID: 19744867.19744867
86 Franek A, Taradaj J, Polak A, . Efficacy of high voltage stimulation for healing of venous leg ulcers in surgically and conservatively treated patients. Phlebologie. 2006;35(3):127-33.
87 Gale SS, Lee JN, Walsh ME, . A randomized, controlled trial of endovenous thermal ablation using the 810-nm wavelength laser and the ClosurePLUS radiofrequency ablation methods for superficial venous insufficiency of the great saphenous vein. J Vasc Surg. 2010 Sep;52(3):645-50. doi: 10.1016/j.jvs.2010.04.030. PMID: 20638231.20638231
88 Garg N, Gloviczki P, Karimi KM, . Factors affecting outcome of open and hybrid reconstructions for nonmalignant obstruction of iliofemoral veins and inferior vena cava. J Vasc Surg. 2011 Feb;53(2):383-93. doi: 10.1016/j.jvs.2010.08.086. PMID: 21146346.21146346
89 Ginsberg JS, Hirsh J, Julian J, . Prevention and treatment of postphlebitic syndrome: results of a 3-part study. Arch Intern Med. 2001 Sep 24;161(17):2105-9. PMID: 11570939.11570939
90 Guest M, Smith JJ, Tripuraneni G, . Randomized clinical trial of varicose vein surgery with compression versus compression alone for the treatment of venous ulceration. Phlebology. 2003;18(3):130-6.
91 Hamel-Desnos CM, Guias BJ, Desnos PR, . Foam sclerotherapy of the saphenous veins: randomised controlled trial with or without compression. Eur J Vasc Endovasc Surg. 2010 Apr;39(4):500-7. doi: 10.1016/j.ejvs.2009.11.027. PMID: 20097585.20097585
92 Helmy ElKaffas K, ElKashef o, ElBaz W. Great saphenous vein radiofrequency ablation versus standard stripping in the management of primary varicose veins-a randomized clinical trial. Angiology. 2011 Jan;62(1):49-54. doi: 10.1177/0003319710380680. PMID: 20724299.20724299
93 Holmes CE, Bambace NM, Lewis P, . Efficacy of a short course of complex lymphedema therapy or graduated compression stocking therapy in the treatment of post-thrombotic syndrome. Vasc Med. 2014 Feb;19(1):42-8. doi: 10.1177/1358863x14521883. PMID: 24558028.24558028
94 Houtermans-Auckel JP, van Rossum E, Teijink JA, . To wear or not to wear compression stockings after varicose vein stripping: a randomised controlled trial. Eur J Vasc Endovasc Surg. 2009 Sep;38(3):387-91. doi: 10.1016/j.ejvs.2009.05.025. PMID: 19608438.19608438
95 Jull A, Parag V, Walker N, . The prepare pilot RCT of home-based progressive resistance exercises for venous leg ulcers. J Wound Care. 2009 Dec;18(12):497-503. doi: 10.12968/jowc.2009.18.12.45606. PMID: 20081574.20081574
96 Kahle B, Leng K. Efficacy of sclerotherapy in varicose veins-- prospective, blinded, placebo-controlled study. Dermatol Surg. 2004 May;30(5):723-8; discussion 8. doi: 10.1111/j.1524-4725.2004.30207.x. PMID: 15099314.15099314
97 Kahn SR, Shrier I, Shapiro S, . Sixmonth exercise training program to treat post-thrombotic syndrome: a randomized controlled two-centre trial. CMAJ. 2011 Jan 11;183(1):37-44. doi: 10.1503/cmaj.100248. PMID: 21098066.21098066
98 Kayilioglu SI, Koksoy C, Alacayir I. Diagnostic value of the femoral vein flow pattern for the detection of an iliocaval venous obstruction. J Vasc Surg Venous Lymphat Disord. 2016 Jan;4(1):2-8. doi: 10.1016/j.jvsv.2015.08.002. PMID: 26946889.26946889
99 Klem TM, Schnater JM, Schutte PR, . A randomized trial of cryo stripping versus conventional stripping of the great saphenous vein. J Vasc Surg. 2009 Feb;49(2):403-9. doi: 10.1016/j.jvs.2008.09.016. PMID: 19028042.19028042
100 Kumar S, Samraj K, Nirujogi V, . Intermittent pneumatic compression as an adjuvant therapy in venous ulcer disease. J Tissue Viability. 2002 Apr;12(2):42-4, 6, 8 passim. PMID: 12001325.12001325
101 Kurstjens RL, de Wolf MA, Alsadah SA, . The value of hemodynamic measurements by air plethysmography in diagnosing venous obstruction of the lower limb. J Vasc Surg Venous Lymphat Disord. 2016 Jul;4(3):313-9. doi: 10.1016/j.jvsv.2016.01.005. PMID: 27318051.27318051
102 Lee W, Chung JW, Yin YH, . Threedimensional CT venography of varicose veins of the lower extremity: image quality and comparison with doppler sonography. AJR Am J Roentgenol. 2008 oct;191(4):1186-91. doi: 10.2214/ajr.07.3471. PMID: 18806163.18806163
103 Liu P, Ren S, Yang Y, . Intravenous catheter-guided laser ablation: a novel alternative for branch varicose veins. Int Surg. 2011 oct-Dec;96(4):331-6. PMID: 22808616.22808616
104 Liu X, Jia X, Guo W, . Ultrasoundguided foam sclerotherapy of the great saphenous vein with sapheno-femoral ligation compared to standard stripping: a prospective clinical study. Int Angiol. 2011 Aug;30(4):321-6. PMID: 21747350.21747350
105 Mantoni M, Larsen L, Lund Jo, . Evaluation of chronic venous disease in the lower limbs: comparison of five diagnostic methods. Br J Radiol. 2002 Jul;75(895):578-83. doi: 10.1259/bjr.75.895.750578. PMID: 12145130.12145130
106 Massenburg BB, Himel HN, Blue RC, . Magnetic resonance imaging in proximal venous outflow obstruction. Ann Vasc Surg. 2015 Nov;29(8):1619-24. doi: 10.1016/j.avsg.2015.06.083. PMID: 26315799.26315799
107 Menyhei G, Gyevnar Z, Arato E, . Conventional stripping versus cryostripping: a prospective randomised trial to compare improvement in quality of life and complications. Eur J Vasc Endovasc Surg. 2008 Feb;35(2):218-23. doi: 10.1016/j.ejvs.2007.08.017. PMID: 17964821.17964821
108 Meyer T, Cavallaro A, Lang W. Duplex ultrasonography in the diagnosis of incompetent Cockett veins. Eur J Ultrasound. 2000 Jun;11(3):175-80. PMID: 10874192.10874192
109 Moreno-Moraga J, Smarandache A, Pascu ML, . 1064 nm Nd:YAG long pulse laser after polidocanol microfoam injection dramatically improves the result of leg vein treatment: a randomized controlled trial on 517 legs with a three-year follow-up. Phlebology. 2014 Dec;29(10):658-66. doi: 10.1177/0268355513502786. PMID: 23989971.23989971
110 Mousa AY, Broce M, Yacoub M, . Validation of venous duplex ultrasound imaging in determining iliac vein stenosis after standard treatment of active chronic venous ulcers. J Vasc Surg Venous Lymphat Disord. 2016 Jul;4(3):307-12. doi: 10.1016/j.jvsv.2016.02.002. PMID: 27318050.27318050
111 Mozafar M, Atqiaee K, Haghighatkhah H, . Endovenous laser ablation of the great saphenous vein versus high ligation: longterm results. Lasers Med Sci. 2014 Mar;29(2):765-71. doi: 10.1007/s10103013-1389-z. PMID: 23942818.23942818
112 Nelson EA, Prescott RJ, Harper DR, . A factorial, randomized trial of pentoxifylline or placebo, four-layer or single-layer compression, and knitted viscose or hydrocolloid dressings for venous ulcers. J Vasc Surg. 2007 Jan;45(1):134-41. doi: 10.1016/j.jvs.2006.09.043. PMID: 17210398.17210398
113 Nikolovska S, Pavlova L, Petrova N, . Pentoxifylline--efficient in the treatment of venous ulcers in the absence of compression? Acta Dermatovenerol Croat. 2002 Mar;10(1):9-13. PMID: 12137725.12137725
114 Noppeney T, Storck M, Nüllen H, . Perioperative quality assessment of varicose vein surgery: Commission for quality assessment of the German Society for Vascular Surgery. Langenbeck’s Archives of Surgery. 2016;401(3):375-80.
115 obi AT, Reames BN, Rook TJ, . outcomes associated with ablation compared to combined ablation and transilluminated powered phlebectomy in the treatment of venous varicosities. Phlebology. 2015 Sep 15doi: 10.1177/0268355515604257. PMID: 26376824.26376824
116 o’Hare JL, Earnshaw JJ. Randomised clinical trial of foam sclerotherapy for patients with a venous leg ulcer. Eur J Vasc Endovasc Surg. 2010 Apr;39(4):495-9. doi: 10.1016/j.ejvs.2009.11.025. PMID: 20006528.20006528
117 o’Sullivan GJ, Semba CP, Bittner CA, . Endovascular management of iliac vein compression (May-Thurner) syndrome. J Vasc Interv Radiol. 2000 JulAug;11(7):823-36. PMID: 10928517.10928517
118 Pares Jo, Juan J, Tellez R, . Varicose vein surgery: stripping versus the CHIVA method: a randomized controlled trial. Ann Surg. 2010 Apr;251(4):624-31. doi: 10.1097/SLA.0b013e3181d0d0a3. PMID: 20224376.20224376
119 Rabahie GN, Waisberg DR, Martins LC, . Comparative study among the physical examination, echo-color Doppler mapping and operative approaching in the recurrent lower extremity varicose veins from the saphenofemoral junction. Jornal Vascular Brasileiro. 2011;10(3):198-204.
120 Raju S, Kirk oK, Jones TL. Endovenous management of venous leg ulcers. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(2):165-72.26992338
121 Roopram AD, Lind MY, Van Brussel JP, . Endovenous laser ablation versus conventional surgery in the treatment of small saphenous vein incompetence. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2013;1(4):357-63.26992756
122 Schouten R, Mollen RM, Kuijpers HC. A comparison between cryosurgery and conventional stripping in varicose vein surgery: perioperative features and complications. Ann Vasc Surg. 2006 May;20(3):306-11. doi: 10.1007/s10016006-9051-x. PMID: 16779510.16779510
123 Sell H, Vikatmaa P, Alback A, . Compression therapy versus surgery in the treatment of patients with varicose veins: A RCT. Eur J Vasc Endovasc Surg. 2014 Jun;47(6):670-7. doi: 10.1016/j.ejvs.2014.02.015. PMID: 24675145.24675145
124 Serra R, Buffone G, Molinari V, . Low molecular weight heparin improves healing of chronic venous ulcers especially in the elderly. Int Wound J. 2015 Apr;12(2):150-3. doi: 10.1111/iwj.12071. PMID: 23517508.23517508
125 Shadid N, Ceulen R, Nelemans P, . Randomized clinical trial of ultrasoundguided foam sclerotherapy versus surgery for the incompetent great saphenous vein. Br J Surg. 2012 Aug;99(8):1062-70. doi: 10.1002/bjs.8781. PMID: 22627969.22627969
126 Stötter L, Schaaf I, Bockelbrink A. Comparative outcomes of radiofrequency endoluminal ablation, invagination stripping, and cryostripping in the treatment of great saphenous vein insufficiency. Phlebology. 2006;21(2):60-4.
127 Subramonia S, Lees T. Randomized clinical trial of radiofrequency ablation or conventional high ligation and stripping for great saphenous varicose veins. Br J Surg. 2010 Mar;97(3):328-36. doi: 10.1002/bjs.6867. PMID: 20035541.20035541
128 Theivacumar NS, Dellagrammaticas D, Mavor AI, . Endovenous laser ablation: does standard above-knee great saphenous vein ablation provide optimum results in patients with both above- and below-knee reflux? A randomized controlled trial. J Vasc Surg. 2008 Jul;48(1):173-8. doi: 10.1016/j.jvs.2008.01.062. PMID: 18440756.18440756
129 Vandongen YK, Stacey MC. Graduated compression elastic stockings reduce lipodermatosclerosis and ulcer recurrence. Phlebology. 2000;15(1):33-7.
130 Vanscheidt W, Rabe E, Naser-Hijazi B, . The efficacy and safety of a coumarin/troxerutin-combination (SB-LoT) in patients with chronic venous insufficiency: a double blind placebo-controlled randomised study. Vasa. 2002 Aug;31(3):185-90. doi: 10.1024/0301-1526.31.3.185. PMID: 12236023.12236023
131 Viarengo LM, Poterio-Filho J, Poterio GM, . Endovenous laser treatment for varicose veins in patients with active ulcers: measurement of intravenous and perivenous temperatures during the procedure. Dermatol Surg. 2007 oct;33(10):1234-42; discussion 41-2. doi: 10.1111/j.15244725.2007.33259.x. PMID: 17903157.17903157
132 Wang H, Chen Q, Fei Z, . Hemodynamic classification and CHIVA treatment of varicose veins in lower extremities (VVLE). Int J Clin Exp Med. 2016;9(2):2465-71.
133 Wong IK, Andriessen A, Charles HE, . Randomized controlled trial comparing treatment outcome of two compression bandaging systems and standard care without compression in patients with venous leg ulcers. J Eur Acad Dermatol Venereol. 2012 Jan;26(1):102-10. doi: 10.1111/j.14683083.2011.04327.x. PMID: 22077933.22077933
134 Wozniak W, Mlosek RK, Ciostek P. Assessment of the efficacy and safety of steam vein sclerosis as compared to classic surgery in lower extremity varicose vein management. Wideochir Inne Tech Maloinwazyjne. 2015 Apr;10(1):15-24. doi: 10.5114/wiitm.2015.48573. PMID: 25960788.25960788
135 Wright D, Gobin JP, Bradbury AW, . Varisolve® polidocanol microfoam compared with surgery or sclerotherapy in the management of varicose veins in the presence of trunk vein incompetence: European randomized controlled trial. Phlebology. 2006;21(4):180-90.
136 Yang L, Wang XP, Su WJ, . Randomized clinical trial of endovenous microwave ablation combined with high ligation versus conventional surgery for varicose veins. Eur J Vasc Endovasc Surg. 2013 oct;46(4):473-9. doi: 10.1016/j.ejvs.2013.07.004. PMID: 23911734.23911734
137 Yin M, Huang X, Cui C, . The effect of stent placement for May-Thurner syndrome combined with symptomatic superficial venous reflux disease. Journal of Vascular Surgery: Venous and Lymphatic Disorders. 2015;3(2):168-72.26993835
138 Yin M, Shi H, Ye K, . Clinical Assessment of Endovascular Stenting Compared with Compression Therapy Alone in Post-thrombotic Patients with Iliofemoral obstruction. Eur J Vasc Endovasc Surg. 2015 Jul;50(1):101-7. doi: 10.1016/j.ejvs.2015.02.007. PMID: 25920630.25920630