# Appendix D List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reasons cited. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## Not a full publication, article retracted/withdrawn, or full publication not available

Barucchello V, Pontello P, Carrer F, . Endovenous laser in the treatment of varicose veins of the lower limbs geriatric patient: Results of activity for 6 years. BMC Geriatrics 2009;9(SUPPL. 1).19317898
Elastic compression stockings reduce the incidence of post-thrombotic syndrome in people with proximal deep vein thrombosis. Evidence-Based Healthcare and Public Health 2005;9(1):81-2.
Iborra E, Vila R, Barjau E, . Surgical treatment of varicose veins: comparative study between two different techniques. Phlebology 2006;21(3):152.
Ippolito E, Belcaro G, Dugall M, . Venoruton(R): post thrombotic syndrome. Clinical improvement in venous insufficiency (signs and symptoms) with Venoruton(R). A five-year, open-registry, efficacy study. Panminerva Med 2011;53(3 Suppl 1):13-9. PMID: 22108472.22108472
Paravastu Sharath Chandra V and Dodd PDF. Endovenous ablation therapy (LASER or radiofrequency) or foam sclerotherapy versus conventional surgical repair for short saphenous varicose veins. Cochrane Database of Systematic Reviews 2013;12. No. CD010878.
Pare´s o, J Juan, C Moreno, . Randomized clinical trial on surgical techniques for the treatment of varicose veins in legs: non-conservative treatment compared with a conservative one. Five years follow-up.. Phlebology 2008;23(5):243.
Perrin M. Reconstructive surgery for deep venous reflux: A report on 144 cases. Phlebology 2000;15(3-4):143.

## Not available in English

De Medeiros CAF. Comparison of endovenous laser therapy vs. conventional stripping of the great saphenous vein: Midterm results. Jornal Vascular Brasileiro 2006;5(4):277-87.
Flessenkämper I, Stenger D, Hartmann M, . Endovenous laser therapy vs. high ligation/stripping for varicosity of the great saphenous vein: Clinical and sonographic findings. Phlebologie 2013;42(1):7-11.
Gaspar RJ. Effects of endolaser on the greater saphenous vein in the treatment of chronic venous insufficiency. Jornal Vascular Brasileiro 2011;10(1):81-82.
Iborra-ortega E., E. Barjau-Urrea, R. Vila-Coll, . Comparative study of two surgical techniques in the treatment of varicose veins in the lower extremities: results from a five-year follow-up [Estudio comparativo de dos técnicas quirúrgicas en el tratamiento de las varices de las extremidades inferiores: resultados tras cinco años de seguimiento]. Angiologia 2006;58(6):459-468.
Seidel AC, Rossetti LP, Juliano Y, . Evaluation of the greater saphenous vein with classification C2 e C3 (CEAP) by air plethysmography and color Doppler ultrasonography. Jornal Vascular Brasileiro 2012;11(3):187-193.
Zhang L, Zhang BG and Zhang JW. Postoperative quality of life in patients with chronic venous insufficiency in lower limbs. Journal of Clinical Rehabilitative Tissue Engineering Research 2007;11(36):7299-7301.

## Not original data or publication date prior to Jan 1, 2000

Arko FR, Arko MZ and Murphy EH. Endovascular intervention for lower-extremity deep venous thrombosis. Vascular Disease Management 2011;8(3):71-79.
Bertanha M, Sobreira ML, Pinheiro Lucio Filho CE, . Polidocanol versus hypertonic glucose for sclerotherapy treatment of reticular veins of the lower limbs: study protocol for a randomized controlled trial. Trials 2014;15:497. PMID: 25527165.25527165
Boersma D, van Eekeren RR, Kelder HJ, . Mechanochemical endovenous ablation versus radiofrequency ablation in the treatment of primary small saphenous vein insufficiency (MESSI trial): study protocol for a randomized controlled trial. Trials 2014;15:421. PMID: 25354769.25354769
De Maeseneer M, Pichot o, Cavezzi A, . Duplex ultrasound investigation of the veins of the lower limbs after treatment for varicose veins - UIP consensus document. Eur J Vasc Endovasc Surg 2011;42(1):89-102. PMID: 21530331.21530331
Dermody M, Schul MW and o’Donnell TF. Thromboembolic complications of endovenous thermal ablation and foam sclerotherapy in the treatment of great saphenous vein insufficiency. Phlebology 2015;30(5):357-64. PMID: 24699720.24699720
Hull R and Butcher P. Value of patient self-assessment in the diagnosis and monitoring of postthrombotic syndrome: the Patient-Tracked Symptoms questionnaire. Clin Appl Thromb Hemost 2012;18(4):345-50. PMID: 22496091.22496091
Marinello J and Videla S. Chronic venous insufficiency of the lower limbs: suitability of transcutaneous blood gas monitoring as an endpoint to evaluate the outcome of pharmacological treatment with calcium dobesilate. Methods Find Exp Clin Pharmacol 2004;26(10):775-80. PMID: 15672120.15672120
Michiels JJ, Michiels JM, Moossdorff W, . Diagnosis of deep vein thrombosis, and prevention of deep vein thrombosis recurrence and the post-thrombotic syndrome in the primary care medicine setting anno 2014. World J Crit Care Med 2015;4(1):29-39. PMID: 25685720.25685720
Michiels JJ, Moosdorff W, Maasland H, . Duplex ultrasound, clinical score, thrombotic risk, and D-dimer testing for evidence based diagnosis and management of deep vein thrombosis and alternative diagnoses in the primary care setting and outpatient ward. Int Angiol 2014;33(1):1-19. PMID: 24452081.24452081
Morrison N. Saphenous ablation: what are the choices, laser or RF energy. Semin Vasc Surg 2005;18(1):15-8. PMID: 15791548.15791548
o’Brien JA, Finlayson KJ, Kerr G, . Testing the effectiveness of a self-efficacy based exercise intervention for adults with venous leg ulcers: protocol of a randomised controlled trial. BMC Dermatol 2014;14:16. PMID: 25277416.25277416
oguzkurt L. Ultrasonographic anatomy of the lower extremity superficial veins. Diagn Interv Radiol 2012;18(4):423-30. PMID: 22427019.22427019
Perrin M. Endoluminal treatment of lower limb varicose veins by endovenous laser and radiofrequency techniques. Phlebology 2004;19(4):170-178.
Roddy SP. A randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. J Vasc Surg 2015;61(3):834. PMID: 25720937.25720937
Tew GA, Michaels J, Crank H, . Supervised exercise training as an adjunctive therapy for venous leg ulcers: study protocol for a randomised controlled trial. Trials 2015;16:443. PMID: 26445318.26445318
van den Bos RR, Kockaert MA, Neumann HA, . Technical review of endovenous laser therapy for varicose veins. Eur J Vasc Endovasc Surg 2008;35(1):88-95. PMID: 17920307.17920307
van Eekeren RR, Boersma D, Holewijn S, . Mechanochemical endovenous Ablation versus RADiofrequeNcy Ablation in the treatment of primary great saphenous vein incompetence (MARADoNA): study protocol for a randomized controlled trial. Trials 2014;15:121. PMID: 24726004.24726004
Vazquez SR and Kahn SR. Advances in the diagnosis and management of postthrombotic syndrome. Best Pract Res Clin Haematol 2012;25(3):391-402. PMID: 22959554.22959554

## Does not meet study design or sample size requirements

Abreu AM and oliveira BG. A study of the Unna Boot compared with the elastic bandage in venous ulcers: a randomized clinical trial. Rev Lat Am Enfermagem 2015;23(4):571-7. PMID: 26444157.26444157
Aherne T, McHugh SM, Tashkandi W, . Radiofrequency ablation: an assessment of clinical and cost efficacy. Ir J Med Sci 2014. PMID: 25413474.25413474
Arcelus JI, Caprini JA, Sehgal LR, . Home use of impulse compression of the foot and compression stockings in the treatment of chronic venous insufficiency. J Vasc Surg 2001;34(5):805-11. PMID: 11700479.11700479
Aschauer M, Deutschmann HA, Stollberger R, . Value of a blood pool contrast agent in MR venography of the lower extremities and pelvis: preliminary results in 12 patients. Magn Reson Med 2003;50(5):993-1002. PMID: 14587010.14587010
Balint IB, Vizsy L, Vargovics E, . Cryosclerosis. A forgotten endovenous procedure for treating the incompetence of the great saphenous vein. Short term results. Int Angiol 2014;33(6):547-52. PMID: 24675151.24675151
Barwell JR, Taylor M, Deacon J, . Surgical correction of isolated superficial venous reflux reduces long-term recurrence rate in chronic venous leg ulcers. Eur J Vasc Endovasc Surg 2000;20(4):363-68. PMID: 11035968.11035968
Bozkaya H, Cinar C, Ertugay S, . Endovascular Treatment of Iliac Vein Compression (MayThurner) Syndrome: Angioplasty and Stenting with or without Manual Aspiration Thrombectomy and Catheter-Directed Thrombolysis. Ann Vasc Dis 2015;8(1):21-8. PMID: 25848427.25848427
Bozkurt AK and Yilmaz MF. A prospective comparison of a new cyanoacrylate glue and laser ablation for the treatment of venous insufficiency. Phlebology 2016;31(1 Suppl):106-13. PMID: 26916777.26916777
Bozoglan o, Mese B, Eroglu E, . Comparison of Endovenous Laser and Radiofrequency Ablation in Treating Varicose Veins in the Same Patient. Vascular and Endovascular Surgery 2016;50(1):47-51.26767802
Brethauer SA, Murray JD, Hatter DG, . Treatment of varicose veins: proximal saphenofemoral ligation comparing adjunctive varicose phlebectomy with sclerotherapy at a military medical center. Vasc Surg 2001;35(1):51-8. PMID: 11668369.11668369
Carradice D, Samuel N, Wallace T, . Comparing the treatment response of great saphenous and small saphenous vein incompetence following surgery and endovenous laser ablation: a retrospective cohort study. Phlebology 2012;27(3):128-34. PMID: 21813578.21813578
Chaby G, Senet P, Ganry o, . Prognostic factors associated with healing of venous leg ulcers: a multicentre, prospective, cohort study. Br J Dermatol 2013;169(5):1106-13. PMID: 23909381.23909381
Chan CY, Chen TC, Hsieh YK, . Retrospective comparison of clinical outcomes between endovenous laser and saphenous vein-sparing surgery for treatment of varicose veins. World J Surg 2011;35(7):1679-86. PMID: 21509638.21509638
Chang JB and Stein TA. Management of varicose veins from chronic venous insufficiency. International Journal of Angiology 2002;11(4):234-237.
Coles CM, Werner RS and Zelickson BD. Comparative pilot study evaluating the treatment of leg veins with a long pulse ND:YAG laser and sclerotherapy. Lasers Surg Med 2002;30(2):154-9. PMID: 11870796.11870796
Darvall KA, Bate GR, Adam DJ, . Recovery after ultrasound-guided foam sclerotherapy compared with conventional surgery for varicose veins. Br J Surg 2009;96(11):1262-7. PMID: 19847864.19847864
Delis KT, Bjarnason H, Wennberg PW, . Successful iliac vein and inferior vena cava stenting ameliorates venous claudication and improves venous outflow, calf muscle pump function, and clinical status in post-thrombotic syndrome. Ann Surg 2007;245(1):130-9. PMID: 17197976.17197976
DeMuth RP, Caylor K, Walton T, . Clinical significance of standing versus reversed trendelenburg position for the diagnosis of lower-extremity venous reflux in the great saphenous vein. Journal for Vascular Ultrasound 2012;36(1):19-22.
Der Sahakian G, Claessens YE, Allo JC, . Accuracy of D-dimers to rule out venous thromboembolism events across age categories. Emergency Medicine International 2010;2010.
Disselhoff BC, der Kinderen DJ and Moll FL. Is there a risk for lymphatic complications after endovenous laser treatment versus cryostripping of the great saphenous vein? A prospective study. Phlebology 2008;23(1):10-4. PMID: 18361264.18361264
Forauer AR, Gemmete JJ, Dasika NL, . Intravascular ultrasound in the diagnosis and treatment of iliac vein compression (May-Thurner) syndrome. J Vasc Interv Radiol 2002;13(5):523-7. PMID: 11997362.11997362
Forlee M, Rossington A and Searle R. A prospective, open, multicentre study to evaluate a new gelling fibre dressing containing silver in the management of venous leg ulcers. Int Wound J 2014;11(4):438-45. PMID: 24602074.24602074
Gonzalez-Zeh R, Armisen R and Barahona S. Endovenous laser and echo-guided foam ablation in great saphenous vein reflux: one-year follow-up results. J Vasc Surg 2008;48(4):940-6. PMID: 18639418.18639418
Hager ES, Washington C, Steinmetz A, . Factors that influence perforator vein closure rates using radiofrequency ablation, laser ablation, or foam sclerotherapy. J Vasc Surg Venous Lymphat Disord 2016;4(1):51-6. PMID: 26946896.26946896
Haut ER, Lau BD, Kraus PS, . Preventability of Hospital-Acquired Venous Thromboembolism. JAMA Surg 2015;150(9):912-5. PMID: 26222738.26222738
Hinchliffe RJ, Ubhi J, Beech A, . A prospective randomised controlled trial of VNUS closure versus surgery for the treatment of recurrent long saphenous varicose veins. Eur J Vasc Endovasc Surg 2006;31(2):212-8. PMID: 16137898.16137898
Hjerppe A, Saarinen JP, Venermo MA, . Prolonged healing of venous leg ulcers: the role of venous reflux, ulcer characteristics and mobility. J Wound Care 2010;19(11):474, 476, 478 passim. PMID: 21135795.21135795
Islamoglu F. An alternative treatment for varicose veins: ligation plus foam sclerotherapy. Dermatol Surg 2011;37(4):470-9. PMID: 21481066.21481066
Kahn SR, Shbaklo H, Shapiro S, . Effectiveness of compression stockings to prevent the post-thrombotic syndrome (the SoX Trial and Bio-SoX biomarker substudy): a randomized controlled trial. BMC Cardiovasc Disord 2007;7:21. PMID: 17711595.17711595
Kakkos SK, Lin JC, Sparks J, . Prospective comparison of the pneumatic cuff and manual compression methods in diagnosing lower extremity venous reflux. Vasc Endovascular Surg 2009;43(5):480-4. PMID: 19729384.19729384
Kan YM and Delis KT. Hemodynamic effects of supervised calf muscle exercise in patients with venous leg ulceration: a prospective controlled study. Arch Surg 2001;136(12):1364-9. PMID: 11735861.11735861
Kim HK, Kim HJ, Shim JH, . Endovenous lasering versus ambulatory phlebectomy of varicose tributaries in conjunction with endovenous laser treatment of the great or small saphenous vein. Ann Vasc Surg 2009;23(2):207-11. PMID: 18684588.18684588
Krnic A and Sucic Z. Bipolar radiofrequency induced thermotherapy and 1064 nm Nd:Yag laser in endovenous occlusion of insufficient veins: short term follow up results. Vasa 2011;40(3):235-40. PMID: 21638252.21638252
Lagan KM, McKenna T, Witherow A, . Low-intensity laser therapy/combined phototherapy in the management of chronic venous ulceration: a placebo-controlled study. J Clin Laser Med Surg 2002;20(3):109-16. PMID: 12165122.12165122
Lakhwani MN, Dadlani NI and Wong YC. 980-nm laser therapy versus varicose vein surgery in racially diverse Penang, Malaysia. ANZ J Surg 2009;79(5):352-7. PMID: 19566516.19566516
Landau Z, Migdal M, Lipovsky A, . Visible light-induced healing of diabetic or venous foot ulcers: a placebo-controlled double-blind study. Photomed Laser Surg 2011;29(6):399-404. PMID: 21214497.21214497
Lane RJ, Cuzzilla ML, Coroneos JC, . Recurrence rates following external valvular stenting of the saphenofemoral junction: a comparison with simultaneous contralateral stripping of the great saphenous vein. Eur J Vasc Endovasc Surg 2007;34(5):595-603; discussion 604. PMID: 17881252.17881252
Lattimer CR, Kalodiki E, Azzam M, . The Aberdeen varicose vein questionnaire may be the preferred method of rationing patients for varicose vein surgery. Angiology 2014;65(3):205-9. PMID: 2337819423378194
Lee KH, Chung JH, Kim KT, . Comparative Study of Cryostripping and Endovenous Laser Therapy for Varicose Veins: Mid-Term Results. Korean J Thorac Cardiovasc Surg 2015;48(5):345-50. PMID: 26509128.26509128
Liu CH, Wu CJ, Yu CY, . Evaluation of Lower Limb Varicose Vein by Ultrasonic Venous Duplex Examination. Journal of Medical Ultrasound 2013;21(2):76-80.
Lurie F and Kistner RL. Trends in patient reported outcomes of conservative and surgical treatment of primary chronic venous disease contradict current practices. Ann Surg 2011;254(2):363-7. PMID: 21532467.21532467
Maeso J, Juan J, Escribano J, . Comparison of clinical outcome of stripping and CHIVA for treatment of varicose veins in the lower extremities. Ann Vasc Surg 2001;15(6):661-5. PMID: 11769147.11769147
Mao J, Zhang C, Wang Z, . A retrospective study comparing endovenous laser ablation and microwave ablation for great saphenous varicose veins. Eur Rev Med Pharmacol Sci 2012;16(7):873-7. PMID: 22953634.22953634
Marsden G, Perry M, Bradbury A, . A Cost-effectiveness Analysis of Surgery, Endothermal Ablation, Ultrasound-guided Foam Sclerotherapy and Compression Stockings for Symptomatic Varicose Veins. Eur J Vasc Endovasc Surg 2015;50(6):794-801. PMID: 26433594.26433594
Marston WA, owens LV, Davies S, . Endovenous saphenous ablation corrects the hemodynamic abnormality in patients with CEAP clinical class 3-6 CVI due to superficial reflux. Vasc Endovascular Surg 2006;40(2):125-30. PMID: 16598360.16598360
McDaniel HB, Marston WA, Farber MA, . Recurrence of chronic venous ulcers on the basis of clinical, etiologic, anatomic, and pathophysiologic criteria and air plethysmography. J Vasc Surg 2002;35(4):723-8. PMID: 11932670.11932670
Mekako AI, Hatfield J, Bryce J, . A nonrandomised controlled trial of endovenous laser therapy and surgery in the treatment of varicose veins. Ann Vasc Surg 2006;20(4):451-7. PMID: 16802211.16802211
Merchant RF, DePalma RG and Kabnick LS. Endovascular obliteration of saphenous reflux: a multicenter study. J Vasc Surg 2002;35(6):1190-6. PMID: 12042730.12042730
Miyazaki K, Nishibe T, Sata F, . Long-term results of treatments for varicose veins due to greater saphenous vein insufficiency. Int Angiol 2005;24(3):282-6. PMID: 16158040.16158040
Miyazaki K, Nishibe T, Sata F, . Stripping operation with sclerotherapy for primary varicose veins due to greater saphenous vein reflux: three-year results. World J Surg 2003;27(5):551-3. PMID: 12715221.12715221
o’Brien J, Edwards H, Stewart I, . A home-based progressive resistance exercise programme for patients with venous leg ulcers: a feasibility study. Int Wound J 2013;10(4):389-96. PMID: 22697811.22697811
Park HS, Kwon Y, Eom BW, . Prospective nonrandomized comparison of quality of life and recurrence between high ligation and stripping and radiofrequency ablation for varicose veins. J Korean Surg Soc 2013;84(1):48-56. PMID: 23323236.23323236
Pascarella L, Bergan JJ and Mekenas LV. Severe chronic venous insufficiency treated by foamed sclerosant. Ann Vasc Surg 2006;20(1):83-91. PMID: 16378144.16378144
Puggioni A, Kalra M, Carmo M, . Endovenous laser therapy and radiofrequency ablation of the great saphenous vein: analysis of early efficacy and complications. J Vasc Surg 2005;42(3):488-93. PMID: 16171593.16171593
Rossi FH, Gama CAR, Fonseca IYI, . Computed tomograpy venography diagnosis of iliocaval venous obstruction in advanced chronic venous insufficiency. Jornal Vascular Brasileiro 2014;13(4):306-311.
Rueda CA, Bittenbinder EN, Buckley CJ, . The management of chronic venous insufficiency with ulceration: the role of minimally invasive perforator interruption. Ann Vasc Surg 2013;27(1):89-95. PMID: 23257074.23257074
Rustempasic N, Cvorak A and Agincic A. outcome of endovenous laser ablation of varicose veins. Acta Inform Med 2014;22(5):329-32. PMID: 25568583.25568583
Scanlon E, Karlsmark T, Leaper DJ, . Cost-effective faster wound healing with a sustained silver-releasing foam dressing in delayed healing leg ulcers--a health-economic analysis. Int Wound J 2005;2(2):150-60. PMID: 16722864.16722864
Shaidakov EV, Grigoryan AG, Ilyukhin EA, . Radiofrequency ablation or stripping of largediameter incompetent great saphenous varicose veins with C2 or C3 disease. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2015.
Shepherd AC, Gohel MS, Lim CS, . Pain following 980-nm endovenous laser ablation and segmental radiofrequency ablation for varicose veins: a prospective observational study. Vasc Endovascular Surg 2010;44(3):212-6. PMID: 20150227.20150227
Shi H, Liu X, Lu M, . The effect of endovenous laser ablation of incompetent perforating veins and the great saphenous vein in patients with primary venous disease. Eur J Vasc Endovasc Surg 2015;49(5):574-80. PMID: 25754773.25754773
Siribumrungwong B, Noorit P, Wilasrusmee C, . Cost-utility analysis of great saphenous vein ablation with radiofrequency, foam and surgery in the emerging health-care setting of Thailand. Phlebology 2015. PMID: 26341394.26341394
Solís JV, Ribé L, Portero JL, . Stripping saphenectomy, CHIVA and laser ablation for the treatment of the saphenous vein insufficiency. Ambulatory Surgery 2009;15(1).
Sullivan V, Denk PM, Sonnad SS, . Ligation versus anticoagulation: treatment of aboveknee superficial thrombophlebitis not involving the deep venous system. J Am Coll Surg 2001;193(5):556-62. PMID: 11708514.11708514
Tesmann JP, Thierbach H, Dietrich A, . Radiofrequency induced thermotherapy (RFITT) of varicose veins compared to endovenous laser treatment (EVLT): a non-randomized prospective study concentrating on occlusion rates, side-effects and clinical outcome. Eur J Dermatol 2011;21(6):945-51. PMID: 21914582.21914582
Theivacumar NS, Darwood R and Gough MJ. Neovascularisation and recurrence 2 years after varicose vein treatment for sapheno-femoral and great saphenous vein reflux: a comparison of surgery and endovenous laser ablation. Eur J Vasc Endovasc Surg 2009;38(2):203-7. PMID: 19524460.19524460
Thompson R, Lewis A and Weir C. Patient-reported quality-of-life after radiofrequency ablation of varicose veins compared to conventional surgery. Ir J Med Sci 2013;182(4):639-42. PMID: 23543415.23543415
Tonev Ao, Genadiev SG, Dimitrov SG, . A retrospective study of 100 patients with varicose veins treated with radiofrequency ablation and stripping. Phlebolymphology 2013;20(3):150-154.
Toregeani JF, Rocha AST, Kimura CJ, . Radiofrequency thermal ablation versus conventional saphenectomy. Jornal Vascular Brasileiro 2015;14(1):4-9.
van Eekeren RR, Boersma D, Konijn V, . Postoperative pain and early quality of life after radiofrequency ablation and mechanochemical endovenous ablation of incompetent great saphenous veins. J Vasc Surg 2013;57(2):445-50. PMID: 23141679.23141679
van Groenendael L, Flinkenflogel L, van der Vliet JA, . Conventional surgery and endovenous laser ablation of recurrent varicose veins of the small saphenous vein: a retrospective clinical comparison and assessment of patient satisfaction. Phlebology 2010;25(3):151-7. PMID: 20483865.20483865
van Groenendael L, van der Vliet JA, Flinkenflogel L, . Treatment of recurrent varicose veins of the great saphenous vein by conventional surgery and endovenous laser ablation. J Vasc Surg 2009;50(5):1106-13. PMID: 19878788.19878788
Vranic H, Hadzimehmedagic A, Kacila M M, . Combined compressive-surgical treatment of chronic venous ulcer of the leg. HealthMED 2010;4(4):890-895.
Vuylsteke M, Van Den Bussche D, Audenaert EA, . Endovenous laser obliteration for the treatment of primary varicose veins. Phlebology 2006;21(2):80-87.
Wang MH, Jin X, Zhang SY, . Lateral subfascial endoscopic perforating vein surgery as treatment for lateral perforating vein incompetence and venous ulceration. World J Surg 2009;33(5):1093-8. PMID: 19189173.19189173
Wendelboe AM, Campbell J, McCumber M, . The design and implementation of a new surveillance system for venous thromboembolism using combined active and passive methods. Am Heart J 2015;170(3):447-54.e18. PMID: 26385027.26385027
Weyer S, Weishaupt F, Kleeberg C, . RheoStim: Development of an Adaptive Multi-Sensor to Prevent Venous Stasis. Sensors (Basel) 2016;16(4). PMID: 27023544.27023544
Yamaki T, Nozaki M and Iwasaka S. Comparative study of duplex-guided foam sclerotherapy and duplex-guided liquid sclerotherapy for the treatment of superficial venous insufficiency. Dermatol Surg 2004;30(5):718-22; discussion 722. PMID: 15099313.15099313
Zhao ZY, Zhang XJ, Li JH, . Comparison of high ligation and stripping of the great saphenous vein combined with foam sclerotherapy versus conventional surgery for the treatment of superficial venous varicosities of the lower extremity. Int J Clin Exp Med 2015;8(5):7843-8. PMID: 26221338.26221338
Zitek T, Baydoun J, Yepez S, . Mistakes and pitfalls associated with Two-Point compression ultrasound for deep vein thrombosis. Western Journal of Emergency Medicine 2016;17(2):201-208.26973753

## Does not report data for a study population of interest

Abdalwahab M, Mansour Y and El-Dib A. A study on the role of rivaroxaban in management of venous thromboembolism. Egyptian Journal of Chest Diseases and Tuberculosis 2015;64(4):893-896.
Akhtar SS, Nabi Z, Salim KP, . Magnetic resonance venography and venous ultrasonography for diagnosing deep venous thrombosis. Saudi Med J 2010;31(1):88-90. PMID: 20062908.20062908
Alkhouli M, Zack CJ, Zhao H, . Comparative outcomes of catheter-directed thrombolysis plus anticoagulation versus anticoagulation alone in the treatment of inferior vena caval thrombosis. Circ Cardiovasc Interv 2015;8(2):e001882. PMID: 25663321.25663321
Apollonio A, Antignani PL, Di Salvo M, . A large Italian observational multicentre study on vascular ulcers of the lower limbs (Studio Ulcere Vascolari). International Wound Journal 2014.
Armstrong DG, Marston WA, Reyzelman AM, . Comparative effectiveness of mechanically and electrically powered negative pressure wound therapy devices: a multicenter randomized controlled trial. Wound Repair Regen 2012;20(3):332-41. PMID: 22564228.22564228
Aschwanden M, Jeanneret C, Koller MT, . Effect of prolonged treatment with compression stockings to prevent post-thrombotic sequelae: a randomized controlled trial. J Vasc Surg 2008;47(5):1015-21. PMID: 18372153.18372153
Ashby RL, Gabe R, Ali S, . Clinical and cost-effectiveness of compression hosiery versus compression bandages in treatment of venous leg ulcers (Venous leg Ulcer Study IV, VenUS IV): a randomised controlled trial. Lancet 2014;383(9920):871-9. PMID: 24315520.24315520
Bakker NA, Schieven LW, Bruins RM, . Compression stockings after endovenous laser ablation of the great saphenous vein: a prospective randomized controlled trial. Eur J Vasc Endovasc Surg 2013;46(5):588-92. PMID: 24012465.24012465
Bauer JD, Isenring E and Waterhouse M. The effectiveness of a specialised oral nutrition supplement on outcomes in patients with chronic wounds: a pragmatic randomised study. J Hum Nutr Diet 2013;26(5):452-8. PMID: 23627791.23627791
Beltramino R, Penenory A and Buceta AM. An open-label, randomized multicenter study comparing the efficacy and safety of Cyclo 3 Fort versus hydroxyethyl rutoside in chronic venous lymphatic insufficiency. Angiology 2000;51(7):535-44. PMID: 10917578.10917578
Bollen L, Peetermans M, Peeters M, . Active PAI-1 as marker for venous thromboembolism: case-control study using a comprehensive panel of PAI-1 and TAFI assays. Thromb Res 2014;134(5):1097-102. PMID: 25193405.25193405
Bucek RA, Quehenberger P, Feliks I, . Results of a new rapid d-dimer assay (cardiac ddimer) in the diagnosis of deep vein thrombosis. Thromb Res 2001;103(1):17-23. PMID: 11434942.11434942
Cassou Birckholz MF, Engelhorn CA, Salles-Cunha SX, . Assessment of venous thrombus time of progression by gray-scale median analysis. Int Angiol 2011;30(1):79-87. PMID: 21248677.21248677
Cham MD, Yankelevitz DF, Shaham D, . Deep venous thrombosis: detection by using indirect CT venography. The Pulmonary Angiography-Indirect CT Venography Cooperative Group. Radiology 2000;216(3):744-51. PMID: 10966705.10966705
Comerota AJ. The ATTRACT trial: rationale for early intervention for iliofemoral DVT. Perspect Vasc Surg Endovasc Ther 2009;21(4):221-4; quiz 224-5. PMID: 20047905.20047905
Comerota AJ, Throm RC, Mathias SD, . Catheter-directed thrombolysis for iliofemoral deep venous thrombosis improves health-related quality of life. J Vasc Surg 2000;32(1):130-7. PMID: 10876214.10876214
Couturaud F, Sanchez o, Pernod G, . Six Months vs Extended oral Anticoagulation After a First Episode of Pulmonary Embolism: The PADIS-PE Randomized Clinical Trial. Jama 2015;314(1):31-40. PMID: 26151264.26151264
de Graaff JC, Ubbink DT, Buller HR, . The diagnosis of deep venous thrombosis using laser Doppler skin perfusion measurements. Microvasc Res 2001;61(1):49-55. PMID: 11162195.11162195
De Sanctis MT, Cesarone MR, Incandela L, . Treatment of superficial vein thrombosis with standardized application of Essaven gel--a placebo-controlled, randomized study. Angiology 2001;52 Suppl 3:S57-62. PMID: 11775651.11775651
Deal EN, Hollands JM, Riney JN, . Evaluation of therapeutic anticoagulation with enoxaparin and associated anti-Xa monitoring in patients with morbid obesity: a case series. J Thromb Thrombolysis 2011;32(2):188-94. PMID: 21465129.21465129
Elsharawy M and Elzayat E. Early results of thrombolysis vs anticoagulation in iliofemoral venous thrombosis. A randomised clinical trial. Eur J Vasc Endovasc Surg 2002;24(3):209-14. PMID: 12217281.12217281
Enden T, Klow NE, Sandvik L, . Catheter-directed thrombolysis vs. anticoagulant therapy alone in deep vein thrombosis: results of an open randomized, controlled trial reporting on shortterm patency. J Thromb Haemost 2009;7(8):1268-75. PMID: 19422443.19422443
Fraser DG, Moody AR, Davidson IR, . Deep venous thrombosis: diagnosis by using venous enhanced subtracted peak arterial MR venography versus conventional venography. Radiology 2003;226(3):812-20. PMID: 12601180.12601180
Funfsinn N, Caliezi C, Biasiutti FD, . Rapid D-dimer testing and pre-test clinical probability in the exclusion of deep venous thrombosis in symptomatic outpatients. Blood Coagul Fibrinolysis 2001;12(3):165-70. PMID: 11414629.11414629
Gabriel V, Jimenez JC, Alktaifi A, . Success of endovenous saphenous and perforator ablation in patients with symptomatic venous insufficiency receiving long-term warfarin therapy. Ann Vasc Surg 2012;26(5):607-11. PMID: 22516240.22516240
Ganesh SK, Sharma Y, Dayhoff J, . Detection of venous thromboembolism by proteomic serum biomarkers. PLoS one 2007;2(6):e544. PMID: 17579716.17579716
Garg K, Kemp JL, Wojcik D, . Thromboembolic disease: comparison of combined CT pulmonary angiography and venography with bilateral leg sonography in 70 patients. AJR Am J Roentgenol 2000;175(4):997-1001. PMID: 11000152.11000152
Gosselin RC, owings JT, Utter GH, . A new method for measuring D-dimer using immunoturbidometry: a study of 255 patients with suspected pulmonary embolism and deep vein thrombosis. Blood Coagul Fibrinolysis 2000;11(8):715-21. PMID: 11132649.11132649
Guest JF, Gerrish A, Ayoub N, . Clinical outcomes and cost-effectiveness of three alternative compression systems used in the management of venous leg ulcers. J Wound Care 2015;24(7):300, 302-5, 307-8, passim. PMID: 26198552.26198552
Hager E, Yuo T, Avgerinos E, . Anatomic and functional outcomes of pharmacomechanical and catheter-directed thrombolysis of iliofemoral deep venous thrombosis. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2014;2(3):246-252.26993382
Hager ES, Yuo T, Tahara R, . outcomes of endovascular intervention for May-Thurner syndrome. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2013;1(3):270-275.26992586
Haig Y, Enden T, Grotta o, . Post-thrombotic syndrome after catheter-directed thrombolysis for deep vein thrombosis (CaVenT): 5-year follow-up results of an open-label, randomised controlled trial. Lancet Haematol 2016;3(2):e64-71. PMID: 26853645.26853645
Harper P, Marson C, Grimmer A, . The rapid whole blood agglutination d-dimer assay has poor sensitivity for use as an exclusion test in suspected deep vein thrombosis. N Z Med J 2001;114(1126):61-4. PMID: 11280427.11280427
Heit JA, Lahr BD, Ashrani AA, . Predictors of venous thromboembolism recurrence, adjusted for treatments and interim exposures: a population-based case-cohort study. Thromb Res 2015;136(2):298-307. PMID: 26143712.26143712
Incandela L, De Sanctis MT, Cesarone MR, . Treatment of superficial vein thrombosis: clinical evaluation of Essaven gel--a placebo-controlled, 8-week, randomized study. Angiology 2001;52 Suppl 3:S69-72. PMID: 11775653.11775653
Jensen AD, Borris LC, Christiansen TM, . Accuracy of magnetic resonance imaging in the diagnosis of deep vein thrombosis in asymptomatic patients with injuries of the lower extremity. A pilot study. Thromb Res 2001;101(6):423-6. PMID: 11322998.11322998
Jiang Y, Li J, Liu Y, . Diagnostic accuracy of deep vein thrombosis is increased by analysis using combined optimal cut-off values of postoperative plasma D-dimer levels. Experimental and Therapeutic Medicine 2016;11(5):1716-1720.27168793
Kahn SR, Shapiro S, Wells PS, . Compression stockings to prevent post-thrombotic syndrome: a randomised placebo-controlled trial. Lancet 2014;383(9920):880-8. PMID: 24315521.24315521
Katzenschlager R, Ugurlouglu A, Sipos G, . Efficacy and tolerability of liposomal heparin spraygel as an add-on treatment in the management of superficial venous thrombosis. Angiology 2007;58 Suppl 1:27s-35s. PMID: 17478880.17478880
Lane RJ, Cuzzilla ML and Coroneos JC. The treatment of varicose veins with external stenting to the saphenofemoral junction. Vasc Endovascular Surg 2002;36(3):179-92. PMID: 12075383.12075383
Lee YM, Ting AC and Cheng SW. Diagnosing deep vein thrombosis in the lower extremity: correlation of clinical and duplex scan findings. Hong Kong Med J 2002;8(1):9-11. PMID: 11861986.11861986
Lopez-Beret P, orgaz A, Fontcuberta J, . Low molecular weight heparin versus oral anticoagulants in the long-term treatment of deep venous thrombosis. J Vasc Surg 2001;33(1):77-90. PMID: 11137927.11137927
Louzada ML, Carrier M, Lazo-Langner A, . Development of a clinical prediction rule for risk stratification of recurrent venous thromboembolism in patients with cancer-associated venous thromboembolism. Circulation 2012;126(4):448-54. PMID: 22679142.22679142
Luzzi R, Belcaro G, Dugall M, . The efficacy of sulodexide in the prevention of postthrombotic syndrome. Blood 2014;20(6):594-9. PMID: 24781035.24781035
Mahé I, Sterpu R, Bertoletti L, . Long-term anticoagulant therapy of patients with venous thromboembolism. What are the practices?. PLoS oNE 2015;10(6).
Mariani F, Marone EM, Gasbarro V, . Multicenter randomized trial comparing compression with elastic stocking versus bandage after surgery for varicose veins. J Vasc Surg 2011;53(1):115-22. PMID: 21050700.21050700
Martinez Trabal JL, Comerota AJ, LaPorte FB, . The quantitative benefit of isolated, segmental, pharmacomechanical thrombolysis (ISPMT) for iliofemoral venous thrombosis. J Vasc Surg 2008;48(6):1532-7. PMID: 18804941.18804941
Meagher H, Ryan D, Clarke-Moloney M, . An experimental study of prescribed walking in the management of venous leg ulcers. J Wound Care 2012;21(9):421-2, 424-6, 428 passim. PMID: 22990394.22990394
Milone M, Salvatore G, Maietta P, . Recurrent varicose veins of the lower limbs after surgery. Role of surgical technique (stripping vs. CHIVA) and surgeon’s experience. G Chir 2011;32(11-12):460-3. PMID: 22217371.22217371
o’Halloran PD, Winter PK, otter JA, . Aqueous oxygen peroxide treatment of VLUs in a primary care-based randomised, double-blind, placebo-controlled trial. J Wound Care 2014;23(4):176, 178, 180-1 passim. PMID: 24762381.24762381
ono A, Murase K, Taniguchi T, . Deep venous thrombosis: diagnostic value of non-contrastenhanced MR venography using electrocardiography-triggered three-dimensional half-Fourier FSE. Magn Reson Med 2010;64(1):88-97. PMID: 20572137.20572137
ozyer U, Harman A, Yildirim E, . Long-term results of angioplasty and stent placement for treatment of central venous obstruction in 126 hemodialysis patients: a 10-year single-center experience. AJR Am J Roentgenol 2009;193(6):1672-9. PMID: 19933663.19933663
Prandoni P, Lensing AW, Prins MH, . Below-knee elastic compression stockings to prevent the post-thrombotic syndrome: a randomized, controlled trial. Ann Intern Med 2004;141(4):249-56. PMID: 15313740.15313740
Quere I, Leizorovicz A, Galanaud JP, . Superficial venous thrombosis and compression ultrasound imaging. J Vasc Surg 2012;56(4):1032-1038.e1. PMID: 22832262.22832262
Reeder S, de Roos KP, de Maeseneer M, . Ulcer recurrence after in-hospital treatment for recalcitrant venous leg ulceration. Br J Dermatol 2013;168(5):999-1002. PMID: 23253015.23253015
Salome GM and Ferreira LM. Impact of skin grafting of venous leg ulcers on functional status and pain. World J Surg 2013;37(6):1438-45. PMID: 23463396.23463396
Salome GM, Blanes L and Ferreira LM. The impact of skin grafting on the quality of life and self-esteem of patients with venous leg ulcers. World J Surg 2014;38(1):233-40. PMID: 24065417.24065417
San Norberto Garcia EM, Merino B, Taylor JH, . Low-molecular-weight heparin for prevention of venous thromboembolism after varicose vein surgery in moderate-risk patients: a randomized, controlled trial. Ann Vasc Surg 2013;27(7):940-6. PMID: 23993109.23993109
Schulman S, Lindmarker P, Holmstrom M, . Post-thrombotic syndrome, recurrence, and death 10 years after the first episode of venous thromboembolism treated with warfarin for 6 weeks or 6 months. J Thromb Haemost 2006;4(4):734-42. PMID: 16634738.16634738
Schwarz T, Schmidt B, Schmidt B, . Interobserver agreement of complete compression ultrasound for clinically suspected deep vein thrombosis. Clin Appl Thromb Hemost 2002;8(1):45-9. PMID: 11991239.11991239
Sharifi M, Mehdipour M, Bay C, . Endovenous therapy for deep venous thrombosis: the ToRPEDo trial. Catheter Cardiovasc Interv 2010;76(3):316-25. PMID: 20578224.20578224
Sharif-Kashani B, Behzadnia N, Shahabi P, . Screening for deep vein thrombosis in asymptomatic high-risk patients: a comparison between digital photoplethysmography and venous ultrasonography. Angiology 2009;60(3):301-7. PMID: 18854340.18854340
Shi WY, Wang LW, Wang SJ, . Combined direct and indirect CT venography (Combined CTV) in detecting lower extremity deep vein thrombosis. Medicine (United States) 2016;95(11).
So WK, Wong IK, Lee DT, . Effect of compression bandaging on wound healing and psychosocial outcomes in older people with venous ulcers: a randomised controlled trial. Hong Kong Med J 2014;20 Suppl 7:40-1. PMID: 25647826.25647826
Spirk D, Aujesky D, Husmann M, . Cardiac troponin testing and the simplified Pulmonary Embolism Severity Index. The SWIss Venous ThromboEmbolism Registry (SWIVTER). Thromb Haemost 2011;106(5):978-84. PMID: 21833454.21833454
Tawfick WA and Sultan S. Technical and clinical outcome of topical wound oxygen in comparison to conventional compression dressings in the management of refractory nonhealing venous ulcers. Vasc Endovascular Surg 2013;47(1):30-7. PMID: 23223182.23223182
Veiga F, Escriba A, Maluenda MP, . Low molecular weight heparin (enoxaparin) versus oral anticoagulant therapy (acenocoumarol) in the long-term treatment of deep venous thrombosis in the elderly: a randomized trial. Thromb Haemost 2000;84(4):559-64. PMID: 11057850.11057850
Wang L, Kang W, Zu M, . Application of 128-slice spiral CT combination scanning in the diagnosis of embolisms in pulmonary arteries and lower extremity veins. Experimental and Therapeutic Medicine 2014;7(2):401-404.24396414
Yao M, Fabbi M, Hayashi H, . A retrospective cohort study evaluating efficacy in high-risk patients with chronic lower extremity ulcers treated with negative pressure wound therapy. Int Wound J 2014;11(5):483-8. PMID: 23163962.23163962

## Does not include an intervention of interest

Andreozzi GM, Bignamini AA, Daví G, . Sulodexide for the prevention of recurrent venous thromboembolism: The Sulodexide in Secondary Prevention of Recurrent Deep Vein Thrombosis (SURVET) study: A multicenter, randomized, double-blind, placebo-controlled trial. Circulation 2015;132(20):1891-1897.26408273
Arcangeli P. Pycnogenol in chronic venous insufficiency. Fitoterapia 2000;71(3):236-44. PMID: 10844161.10844161
Arosio E, Ferrari G, Santoro L, . A placebo-controlled, double-blind study of mesoglycan in the treatment of chronic venous ulcers. Eur J Vasc Endovasc Surg 2001;22(4):365-72. PMID: 11563899.11563899
Assadian A, Wickenhauser G, Hubl W, . Traditional versus endoscopic saphenous vein stripping: a prospective randomized pilot trial. Eur J Vasc Endovasc Surg 2008;36(5):611-5. PMID: 18718770.18718770
Belcaro G, Cesarone MR, Nicolaides AN, . Treatment of venous ulcers with pentoxifylline: a 6-month randomized, double-blind, placebo controlled trial. Angiology 2002;53 Suppl 1:S45-7. PMID: 11865836.11865836
Belcaro G, Rulo A, Cesarone MR, . Capillary filtration in venous hypertension: evaluation with the vacuum suction chamber device and strain-gauge plethysmography. Angiology 2001;52 Suppl 2:S39-43. PMID: 11666122.11666122
Belczak SQ, Sincos IR, Campos W, . Veno-active drugs for chronic venous disease: A randomized, double-blind, placebo-controlled parallel-design trial. Phlebology 2014;29(7):454-60. PMID: 23761871.23761871
Berard A and Zuccarelli F. Test-retest reliability study of a new improved Leg-o-meter, the Lego-meter II, in patients suffering from venous insufficiency of the lower limbs. Angiology 2000;51(9):711-7. PMID: 10999611.10999611
Blomgren L, Johansson G, Emanuelsson L, . Late follow-up of a randomized trial of routine duplex imaging before varicose vein surgery. Br J Surg 2011;98(8):1112-6. PMID: 21618499.21618499
Bouman AC, Cheung YW, Spronk HM, . Biomarkers for post thrombotic syndrome: a casecontrol study. Thromb Res 2014;134(2):369-75. PMID: 24975586.24975586
Brizzio E, Amsler F, Lun B, . Comparison of low-strength compression stockings with bandages for the treatment of recalcitrant venous ulcers. J Vasc Surg 2010;51(2):410-6. PMID: 19879713.19879713
Bryan LJ, Callas PW, Criqui MH, . Higher soluble P-selectin is associated with chronic venous insufficiency: the San Diego Population Study. Thromb Res 2012;130(5):716-9. PMID: 22892384.22892384
Campbell WB, Decaluwe H, Boecxstaens V, . The symptoms of varicose veins: difficult to determine and difficult to study. Eur J Vasc Endovasc Surg 2007;34(6):741-4. PMID: 17870617.17870617
Carpentier PH and Satger B. Randomized trial of balneotherapy associated with patient education in patients with advanced chronic venous insufficiency. J Vasc Surg 2009;49(1):163-70. PMID: 18829219.18829219
Cesarone MR, Belcaro G, De Sanctis MT, . Effects of the total triterpenic fraction of Centella asiatica in venous hypertensive microangiopathy: a prospective, placebo-controlled, randomized trial. Angiology 2001;52 Suppl 2:S15-18. PMID: 11666117.11666117
Cesarone MR, Belcaro G, Pellegrini L, . Venoruton vs Daflon: evaluation of effects on quality of life in chronic venous insufficiency. Angiology 2006;57(2):131-8. PMID: 16518519.16518519
Cesarone MR, Belcaro G, Rohdewald P, . Rapid relief of signs/symptoms in chronic venous microangiopathy with pycnogenol: a prospective, controlled study. Angiology 2006;57(5):569-76. PMID: 17067979.17067979
Cesarone MR, Belcaro G, Rohdewald P, . Comparison of Pycnogenol and Daflon in treating chronic venous insufficiency: a prospective, controlled study. Clin Appl Thromb Hemost 2006;12(2):205-12. PMID: 16708123.16708123
Cesarone MR, Belcaro G, Rulo A, . Microcirculatory effects of total triterpenic fraction of Centella asiatica in chronic venous hypertension: measurement by laser Doppler, TcPo2-Co2, and leg volumetry. Angiology 2001;52 Suppl 2:S45-8. PMID: 11666123.11666123
Daher A, Jones V and da Silva AF. The role of popliteal vein incompetence in the diagnosis of saphenous-popliteal reflux using continuous wave doppler. Eur J Vasc Endovasc Surg 2001;21(4):350-2. PMID: 11359337.11359337
Danielsson G, Jungbeck C, Peterson K, . A randomised controlled trial of micronised purified flavonoid fraction vs placebo in patients with chronic venous disease. Eur J Vasc Endovasc Surg 2002;23(1):73-6. PMID: 11748952.11748952
De Sanctis MT, Belcaro G, Cesarone MR, . Treatment of venous ulcers with pentoxifylline: a 12-month, double-blind, placebo controlled trial. Microcirculation and healing. Angiology 2002;53 Suppl 1:S49-51. PMID: 11865837.11865837
De Sanctis MT, Belcaro G, Incandela L, . Treatment of edema and increased capillary filtration in venous hypertension with total triterpenic fraction of Centella asiatica: a clinical, prospective, placebo-controlled, randomized, dose-ranging trial. Angiology 2001;52 Suppl 2:S55-9. PMID: 11666125.11666125
De Sanctis MT, Incandela L, Belcaro G, . Topical treatment of venous microangiopathy in patients with venous ulceration with Essaven gel--a placebo-controlled, randomized study. Angiology 2001;52 Suppl 3:S29-34. PMID: 11775646.11775646
Dini V, Romanelli M, Andriessen A, . Improvement of periulcer skin condition in venous leg ulcer patients: prospective, randomized, controlled, single-blinded clinical trial comparing a biosynthetic cellulose dressing with a foam dressing. Adv Skin Wound Care 2013;26(8):352-9. PMID: 23860220.23860220
Disselhoff BC, der Kinderen DJ, Kelder JC, . Randomized clinical trial comparing endovenous laser ablation of the great Saphenous vein with and without ligation of the saphenofemoral junction: 2-year results. Eur J Vasc Endovasc Surg 2008;36(6):713-8. PMID: 18848791.18848791
dos Santos Crisostomo RS, Costa DS, de Luz Belo Martins C, . Influence of manual lymphatic drainage on health-related quality of life and symptoms of chronic venous insufficiency: a randomized controlled trial. Arch Phys Med Rehabil 2015;96(2):283-91. PMID: 25308883.25308883
Edwards H, Courtney M, Finlayson K, . A randomised controlled trial of a community nursing intervention: improved quality of life and healing for clients with chronic leg ulcers. J Clin Nurs 2009;18(11):1541-9. PMID: 19490293.19490293
El-Sheikha J, Nandhra S, Carradice D, . Clinical outcomes and quality of life 5 years after a randomized trial of concomitant or sequential phlebectomy following endovenous laser ablation for varicose veins. Br J Surg 2014;101(9):1093-7. PMID: 24916467.24916467
Ferrara F, Meli F, Raimondi F, . The treatment of venous leg ulcers: a new therapeutic use of iloprost. Ann Surg 2007;246(5):860-5. PMID: 17968180.17968180
Flore R, Ponziani FR, Gerardino L, . Biomarkers of low-grade inflammation in primary varicose veins of the lower limbs. Eur Rev Med Pharmacol Sci 2015;19(4):557-62. PMID: 25753870.25753870
Forestier RJ, Briancon G, Francon A, . Balneohydrotherapy in the treatment of chronic venous insufficiency. Vasa 2014;43(5):365-71. PMID: 25147013.25147013
Galanaud JP, Sevestre MA, Genty C, . Incidence and predictors of venous thromboembolism recurrence after a first isolated distal deep vein thrombosis. J Thromb Haemost 2014;12(4):436-43. PMID: 24450376.24450376
Galeandro AI, Quistelli G, Scicchitano P, . Doppler ultrasound venous mapping of the lower limbs. Vasc Health Risk Manag 2012;8:59-64. PMID: 22371652.22371652
Gatti MAN, Vieira LM, Barraviera B, . Treatment of venous ulcers with fibrin sealant derived from snake venom. Journal of Venomous Animals and Toxins Including Tropical Diseases 2011;17(2):226-229.
Gaweesh AS, Kayed MH, Gaweesh TY, . Underlying deep venous abnormalities in patients with unilateral chronic venous disease. Phlebology 2013;28(8):426-31. PMID: 22952112.22952112
Gohel MS, Barwell JR, Heather BP, . The predictive value of haemodynamic assessment in chronic venous leg ulceration. Eur J Vasc Endovasc Surg 2007;33(6):742-6. PMID: 17275361.17275361
Goldman MP. Treatment of varicose and telangiectatic leg veins: double-blind prospective comparative trial between aethoxyskerol and sotradecol. Dermatol Surg 2002;28(1):52-5. PMID: 11991271.11991271
Gurgel Gdo A, Castro AA, Araujo M, . Evaluation of the venous reflux of the great saphenous vein by duplex scan after surgical treatment of the saphenofemoral junction insufficiency. Rev Col Bras Cir 2013;40(5):380-5. PMID: 24573586.24573586
Heinen M, Borm G, van der Vleuten C, . The Lively Legs self-management programme increased physical activity and reduced wound days in leg ulcer patients: Results from a randomized controlled trial. Int J Nurs Stud 2012;49(2):151-61. PMID: 21959100.21959100
Incandela L, Belcaro G, Cesarone MR, . Microangiopathy and venous ulceration: topical treatment with Essaven gel--a placebo-controlled, randomized study. Angiology 2001;52 Suppl 3:S17-21. PMID: 11775644.11775644
Incandela L, Belcaro G, Renton S, . HR (Paroven, Venoruton; 0-(beta-hydroxyethyl)rutosides) in venous hypertensive microangiopathy: a prospective, placebo-controlled, randomized trial. J Cardiovasc Pharmacol Ther 2002;7 Suppl 1:S7-s10. PMID: 12011966.12011966
Jones TM, Cassada DC, Heidel RE, . Maximal venous outflow velocity: an index for iliac vein obstruction. Ann Vasc Surg 2012;26(8):1106-13. PMID: 22835564.22835564
Jorgensen B, Price P, Andersen KE, . The silver-releasing foam dressing, Contreet Foam, promotes faster healing of critically colonised venous leg ulcers: a randomised, controlled trial. Int Wound J 2005;2(1):64-73. PMID: 16722854.16722854
Kahn SR, Azoulay L, Hirsch A, . Effect of graduated elastic compression stockings on leg symptoms and signs during exercise in patients with deep venous thrombosis: a randomized cross-over trial. J Thromb Haemost 2003;1(3):494-9. PMID: 12871456.12871456
Kiesewetter H, Koscielny J, Kalus U, . Efficacy of orally administered extract of red vine leaf AS 195 (folia vitis viniferae) in chronic venous insufficiency (stages I-II). A randomized, double-blind, placebo-controlled trial. Arzneimittelforschung 2000;50(2):109-17. PMID: 10719612.10719612
Kirsner RS, Marston WA, Snyder RJ, . Spray-applied cell therapy with human allogeneic fibroblasts and keratinocytes for the treatment of chronic venous leg ulcers: a phase 2, multicentre, double-blind, randomised, placebo-controlled trial. Lancet 2012;380(9846):977-85. PMID: 22863328.22863328
Klem TM, Sybrandy JE and Wittens CH. Measurement of health-related quality of life with the Dutch translated Aberdeen Varicose Vein Questionnaire before and after treatment. Eur J Vasc Endovasc Surg 2009;37(4):470-6. PMID: 19117775.19117775
Klonizakis M, Manning G and Donnelly R. Assessment of lower limb microcirculation: exploring the reproducibility and clinical application of laser Doppler techniques. Skin Pharmacol Physiol 2011;24(3):136-43. PMID: 21212723.21212723
Koch R. Comparative study of Venostasin and Pycnogenol in chronic venous insufficiency. Phytother Res 2002;16 Suppl 1:S1-5. PMID: 11933130.11933130
Kopera D, Kokol R, Berger C, . Does the use of low-level laser influence wound healing in chronic venous leg ulcers?. J Wound Care 2005;14(8):391-4. PMID: 16178295.16178295
Labs KH, Degischer S, Gamba G, . Effectiveness and safety of calcium dobesilate in treating chronic venous insufficiency: Randomized, double-blind, placebo-controlled trial. Phlebology 2004;19(3):123-130.
Lammoglia-ordiales L, Vega-Memije ME, Herrera-Arellano A, . A randomised comparative trial on the use of a hydrogel with tepescohuite extract (Mimosa tenuiflora cortex extract-2G) in the treatment of venous leg ulcers. Int Wound J 2012;9(4):412-8. PMID: 22128789.22128789
Lazareth I, ourabah Z, Senet P, . Evaluation of a new silver foam dressing in patients with critically colonised venous leg ulcers. J Wound Care 2007;16(3):129-32. PMID: 17385590.17385590
Leach MJ, Pincombe J and Foster G. Using horsechestnut seed extract in the treatment of venous leg ulcers: a cost-benefit analysis. ostomy Wound Manage 2006;52(4):68-70, 72-4, 76-8. PMID: 16636364.16636364
Leach MJ, Pincombe J and Foster G. Clinical efficacy of horsechestnut seed extract in the treatment of venous ulceration. J Wound Care 2006;15(4):159-67. PMID: 16620045.16620045
Leclere FM, Puechguiral IR, Rotteleur G, . A prospective randomized study of 980 nm diode laser-assisted venous ulcer healing on 34 patients. Wound Repair Regen 2010;18(6):580-5. PMID: 20958856.20958856
Makris SA, Karkos CD, Awad S, . An “all-comers” venous duplex scan policy for patients with lower limb varicose veins attending a one-stop vascular clinic: is it justified?. Eur J Vasc Endovasc Surg 2006;32(6):718-24. PMID: 16798025.16798025
Mekako AI, Chetter IC, Coughlin PA, . Randomized clinical trial of co-amoxiclav versus no antibiotic prophylaxis in varicose vein surgery. Br J Surg 2010;97(1):29-36. PMID: 20013927.20013927
Milic DJ, Zivic SS, Bogdanovic DC, . The influence of different sub-bandage pressure values on venous leg ulcers healing when treated with compression therapy. J Vasc Surg 2010;51(3):655-61. PMID: 20045611.20045611
Miyake RK, Zeman HD, Duarte FH, . Vein imaging: a new method of near infrared imaging, where a processed image is projected onto the skin for the enhancement of vein treatment. Dermatol Surg 2006;32(8):1031-8. PMID: 16918565.16918565
Moffatt CJ, Stanton J, Murray S, . A randomised trial to compare the performance of oxyzyme® and Iodozyme® with standard care in the treatment of patients with venous and mixed venous/arterial ulceration. Wound Medicine 2014;6:1-10.
o’Donnell MJ, McRae S, Kahn SR, . Evaluation of a venous-return assist device to treat severe post-thrombotic syndrome (VENoPTS). A randomized controlled trial. Thromb Haemost 2008;99(3):623-9. PMID: 18327413.18327413
ortega-Zilic N, Hunziker T, Lauchli S, . EpiDex(R) Swiss field trial 2004-2008. Dermatology 2010;221(4):365-72. PMID: 21071921.21071921
ottillinger B and Greeske K. Rational therapy of chronic venous insufficiency--chances and limits of the therapeutic use of horse-chestnut seeds extract. BMC Cardiovasc Disord 2001;1:5. PMID: 11747472.11747472
Petrassi C, Mastromarino A and Spartera C. PYCNoGENoL in chronic venous insufficiency. Phytomedicine 2000;7(5):383-8. PMID: 11081989.11081989
Petruzzellis V, Troccoli T, Candiani C, . oxerutins (Venoruton): efficacy in chronic venous insufficiency--a double-blind, randomized, controlled study. Angiology 2002;53(3):257-63. PMID: 12025912.12025912
Prandoni P, Lensing AW, Prins MH, . The impact of residual thrombosis on the long-term outcome of patients with deep venous thrombosis treated with conventional anticoagulation. Semin Thromb Hemost 2015;41(2):133-40. PMID: 25682083.25682083
Rabe E, Stucker M, Esperester A, . Efficacy and tolerability of a red-vine-leaf extract in patients suffering from chronic venous insufficiency--results of a double-blind placebocontrolled study. Eur J Vasc Endovasc Surg 2011;41(4):540-7. PMID: 21239190.21239190
Ragg JC. Film compression bandage: New modality for continuous and sports-suitable compression therapy of varicose veins following foam sclerotherapy. Phlebologie 2015;44(5):249-255.
Renner R, Gebhardt C, Simon JC, . Changes in quality of life for patients with chronic venous insufficiency, present or healed leg ulcers. J Dtsch Dermatol Ges 2009;7(11):953-61. PMID: 19386020.19386020
Rosfors S and Blomgren L. Venous occlusion plethysmography in patients with post-thrombotic venous claudication. J Vasc Surg 2013;58(3):722-6. PMID: 23548174.23548174
Rosfors S, Persson LM and Blomgren L. Computerized venous strain-gauge plethysmography is a reliable method for measuring venous function. Eur J Vasc Endovasc Surg 2014;47(1):81-6. PMID: 24262322.24262322
Sanchez-Vazquez R, Briseno-Rodriguez G, Cardona-Munoz EG, . Isosorbide dinitrate spray as therapeutic strategy for treatment of chronic venous ulcers. Angiology 2008;59(1):64-71. PMID: 18319224.18319224
Saveljev VS, Pokrovsky AV, Kirienko AI, . Stripping of the great saphenous vein under micronized purified flavonoid fraction (MPFF) protection (results of the Russian multicenter controlled trial DEFANCE). Phlebolymphology 2008;15(2):45-51.
Schul MW, Eaton T and Erdman B. Compression versus sclerotherapy for patients with isolated refluxing reticular veins and telangiectasia: a randomized trial comparing quality-of-life outcomes. Phlebology 2011;26(4):148-56. PMID: 2142219321422193
Serra R, Buffone G, de Franciscis A, . Skin grafting followed by low-molecular-weight heparin long-term therapy in chronic venous leg ulcers. Ann Vasc Surg 2012;26(2):190-7. PMID: 22018697.22018697
Shepherd AC, Gohel MS, Lim CS, . A study to compare disease-specific quality of life with clinical anatomical and hemodynamic assessments in patients with varicose veins. J Vasc Surg 2011;53(2):374-82. PMID: 21129895.21129895
Stacey MC, Mata SD, Trengove NJ, . Randomised double-blind placebo controlled trial of topical autologous platelet lysate in venous ulcer healing. Eur J Vasc Endovasc Surg 2000;20(3):296-301. PMID: 10986030.10986030
Szewczyk MT, Jawien A, Cierzniakowska K, . Comparison of the effectiveness of compression stockings and layer compression systems in venous ulceration treatment. Arch Med Sci 2010;6(5):793-9. PMID: 22419941.22419941
Taradaj J, Franek A, Brzezinska-Wcislo L, . The use of therapeutic ultrasound in venous leg ulcers: a randomized, controlled clinical trial. Phlebology 2008;23(4):178-83. PMID: 18663117.18663117
Tawfick W and Sultan S. Does topical wound oxygen (TWo2) offer an improved outcome over conventional compression dressings (CCD) in the management of refractory venous ulcers (RVU)? A parallel observational comparative study. Eur J Vasc Endovasc Surg 2009;38(1):125-32. PMID: 19464933.19464933
Tumino G, Masuelli L, Bei R, . Topical treatment of chronic venous ulcers with sucralfate: a placebo controlled randomized study. Int J Mol Med 2008;22(1):17-23. PMID: 18575771.18575771
Vanscheidt W, Ukat A, Horak V, . Treatment of recalcitrant venous leg ulcers with autologous keratinocytes in fibrin sealant: a multinational randomized controlled clinical trial. Wound Repair Regen 2007;15(3):308-15. PMID: 17537117.17537117
Vowden P, Romanelli M and Price P. Effect of amelogenin extracellular matrix protein and compression on hard-to-heal venous leg ulcers. J Wound Care 2007;16(5):189-95. PMID: 17552400.17552400
Vowden P, Romanelli M, Peter R, . The effect of amelogenins (Xelma) on hard-to-heal venous leg ulcers. Wound Repair Regen 2006;14(3):240-6. PMID: 16808801.16808801
Wang SM, Hu ZJ, Li SQ, . Effect of external valvuloplasty of the deep vein in the treatment of chronic venous insufficiency of the lower extremity. J Vasc Surg 2006;44(6):1296-300. PMID: 17145434.17145434

## Does not include a comparator of interest

Agus GB, Mancini S and Magi G. The first 1000 cases of Italian Endovenous-laser Working Group (IEWG). Rationale, and long-term outcomes for the 1999-2003 period. Int Angiol 2006;25(2):209-15. PMID: 16763541.16763541
Aiono S, Simmons MJ, Galland RB, . Is a palpable short saphenous vein a useful clinical sign in varicose vein assessment?. Ann R Coll Surg Engl 2001;83(2):105-7. PMID: 11320916.11320916
Alos J, Carreno P, Lopez JA, . Efficacy and safety of sclerotherapy using polidocanol foam: a controlled clinical trial. Eur J Vasc Endovasc Surg 2006;31(1):101-7. PMID: 16226901.16226901
Amer NM and Walker M. A comparative study between crepe bandage, tensopress, and panelast following varicose vein operations. International Journal of Angiology 2005;14(4):233-236.
Asbeutah AM, Riha AZ, Cameron JD, . Quantitative assessment of chronic venous insufficiency using duplex ultrasound and air plethysmography. Journal for Vascular Ultrasound 2006;30(1):23-30.
Ashby RL, Gabe R, Ali S, . VenUS IV (Venous leg Ulcer Study IV) - compression hosiery compared with compression bandaging in the treatment of venous leg ulcers: a randomised controlled trial, mixed-treatment comparison and decision-analytic model. Health Technol Assess 2014;18(57):1-293, v-vi. PMID: 25242076.25242076
Belcaro G, Nicolaides AN, Cesarone MR, . Flush ligation of the sapheno-femoral junction vs simple, distal ligation. A randomised, 10-year, follow-up. The safe study. Angeiologie 2002;54(1):19-23.
Blaise S, Bosson JL and Diamand JM. Ultrasound-guided sclerotherapy of the great saphenous vein with 1% vs. 3% polidocanol foam: a multicentre double-blind randomised trial with 3-year follow-up. Eur J Vasc Endovasc Surg 2010;39(6):779-86. PMID: 20206556.20206556
Błaszczak E, Franek A, Taradaj J, . Evaluation of healing process dynamics of the leg venous ulcers treated by means of selected physical methods. Fizjoterapia 2007;15(1):3-16.
Boon R, Akkersdijk GJ and Nio D. Percutaneus treatment of varicose veins with bipolar radiofrequency ablation. Eur J Radiol 2010;75(1):43-7. PMID: 20554143.20554143
Brizzio Eo, Blättler W, Rossi G, . Healing venous ulcers with different modalities of leg compression. Unexpected findings of a pilot study. Phlebologie 2006;35(5):249-255.
Broholm R, Kreiner S, Baekgaard N, . observer agreement of lower limb venous reflux assessed by duplex ultrasound scanning using manual and pneumatic cuff compression in patients with chronic venous disease and controls. Eur J Vasc Endovasc Surg 2011;41(5):704-10. PMID: 21333558.21333558
Butler CM, Scurr JH and Coleridge Smith PD. Prospective randomised trial comparing conventional (babcock) stripping with inverting (pin) stripping of the long saphenous vein. Phlebology 2002;17(2):59-63.
Cambal M and Labas P. Venous leg ulcers--a surgical treatment. Bratisl Lek Listy 2008;109(9):391-5. PMID: 19040144.19040144
Campbell WB, Niblett PG, Peters AS, . The clinical effectiveness of hand held Doppler examination for diagnosis of reflux in patients with varicose veins. Eur J Vasc Endovasc Surg 2005;30(6):664-9. PMID: 16385703.16385703
Canonico S, Luminello F, Mainelli R, . Long-term recurrence and nerve injury after total and partial stripping of the great saphenous vein by external phleboextractor. Vascular Surgery 2000;34(2):163-166.
Cappelli M, Molino Lova R, Ermini S, . Hemodynamics of the sapheno-femoral complex: an operational diagnosis of proximal femoral valve function. Int Angiol 2006;25(4):356-60. PMID: 17164741.17164741
Carradice D, Wallace T, Gohil R, . A comparison of the effectiveness of treating those with and without the complications of superficial venous insufficiency. Ann Surg 2014;260(2):396-401. PMID: 24424141.24424141
Catarinella F, Nieman F, de Wolf M, . Short-term follow-up of Quality-of-Life in interventionally treated patients with post-thrombotic syndrome after deep venous occlusion. Phlebology 2014;29(1 suppl):104-111. PMID: 24843095.24843095
Cavezzi A, Frullini A, Ricci S, . Treatment of varicose veins by foam sclerotherapy: Two clinical series. Phlebology 2002;17(1):13-18.
Cesarone MR, De Sanctis MT, Incandela L, . Microvascular changes in venous hypertension due to varicose veins after standardized application of Essaven gel--a placebo-controlled, randomized study. Angiology 2001;52 Suppl 3:S11-6. PMID: 11775643.11775643
Chandler JG, Pichot o, Sessa C, . Defining the role of extended saphenofemoral junction ligation: a prospective comparative study. J Vasc Surg 2000;32(5):941-53. PMID: 11054226.11054226
Chandler JG, Pichot o, Sessa C, . Treatment of primary venous insufficiency by endovenous saphenous vein obliteration. Vascular Surgery 2000;34(3):201-214.
Charles H, Callicot C, Mathurin D, . Randomised, comparative study of three primary dressings for the treatment of venous ulcers. Br J Community Nurs 2002;7(6 Suppl):48-54. PMID: 12066081.12066081
Chetter IC, Mylankal KJ, Hughes H, . Randomized clinical trial comparing multiple stab incision phlebectomy and transilluminated powered phlebectomy for varicose veins. Br J Surg 2006;93(2):169-74. PMID: 16432820.16432820
Couzan S, Leizorovicz A, Laporte S, . A randomized double-blind trial of upward progressive versus degressive compressive stockings in patients with moderate to severe chronic venous insufficiency. J Vasc Surg 2012;56(5):1344-1350.e1. PMID: 22592040.22592040
De Maeseneer MG, Vandenbroeck CP, Hendriks JM, . Accuracy of duplex evaluation one year after varicose vein surgery to predict recurrence at the sapheno-femoral junction after five years. Eur J Vasc Endovasc Surg 2005;29(3):308-12. PMID: 15694807.15694807
Delgado-Beltran A. Crossectomy and foam sclerotherapy of the great saphenous vein versus stripping of great saphenous vein and varicectomy in the treatment of the legs ulcers. Ulcers 2013.
Devereux N, Recke AL, Westermann L, . Catheter-directed Foam Sclerotherapy of Great Saphenous Veins in Combination with Pre-treatment Reduction of the Diameter Employing the Principals of Perivenous Tumescent Local Anesthesia. European Journal of Vascular and Endovascular Surgery 2013.
Doganci S and Demirkilic U. Comparison of 980 nm laser and bare-tip fibre with 1470 nm laser and radial fibre in the treatment of great saphenous vein varicosities: a prospective randomised clinical trial. Eur J Vasc Endovasc Surg 2010;40(2):254-9. PMID: 20547079.20547079
Dolibog P, Franek A, Taradaj J, . A comparative clinical study on five types of compression therapy in patients with venous leg ulcers. Int J Med Sci 2014;11(1):34-43. PMID: 24396284.24396284
Dumas BE, Spronk S, Boelhouwer RU, . Subfascial ligation at three different levels versus partial exeresis of the incompetent short saphenous vein: a randomized clinical trial. J Vasc Nurs 2007;25(1):12-8. PMID: 17324764.17324764
Durkin MT, Turton EP, Wijesinghe LD, . Long saphenous vein stripping and quality of lifea randomised trial. Eur J Vasc Endovasc Surg 2001;21(6):545-9. PMID: 11397030.11397030
Dzieciuchowicz L, Krasinski Z, Gabriel M, . A prospective comparison of four methods of endovenous thermal ablation. Pol Przegl Chir 2011;83(11):597-605. PMID: 22246092.22246092
Eissawy MG, Abd-Elgawad EA and El-Shereif MAE. Endovenous laser ablation of varicose veins. Egyptian Journal of Radiology and Nuclear Medicine 2016;47(1):179-183
Galego GN, Lima GBB, Franklin RN, . outcome of 1470nm laser diode ablation for superficial venous insufficiency. Jornal Vascular Brasileiro 2015;14(2):115-122.
Geier B, Mumme A, Hummel T, . Validity of duplex-ultrasound in identifying the cause of groin recurrence after varicose vein surgery. J Vasc Surg 2009;49(4):968-72. PMID: 19249187.19249187
Gifford SM, Kalra M, Gloviczki P, . Reflux in the below-knee great saphenous vein can be safely treated with endovenous ablation. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2014;2(4):397-402.26993545
Golbasi I, Turkay C, Erbasan o, . Endovenous laser with miniphlebectomy for treatment of varicose veins and effect of different levels of laser energy on recanalization. A single center experience. Lasers Med Sci 2015;30(1):103-8. PMID: 24993399.24993399
Häfner HM and Jünger M. The haemodynamic efficacy of six different compression stockings from compression class 2 in patients suffering from chronic venous insufficiency. Phlebology 2000;15(3-4):126-130.
Harlander-Locke M, Jimenez JC, Lawrence PF, . Endovenous ablation with concomitant phlebectomy is a safe and effective method of treatment for symptomatic patients with axial reflux and large incompetent tributaries. J Vasc Surg 2013;58(1):166-72. PMID: 23571079.23571079
Harlander-Locke M, Lawrence P, Jimenez JC, . Combined treatment with compression therapy and ablation of incompetent superficial and perforating veins reduces ulcer recurrence in patients with CEAP 5 venous disease. J Vasc Surg 2012;55(2):446-50. PMID: 22104338.22104338
Hsieh MC, Chang PY, Hsu WH, . Role of three-dimensional rotational venography in evaluation of the left iliac vein in patients with chronic lower limb edema. Int J Cardiovasc Imaging 2011;27(7):923-9. PMID: 21072686.21072686
Incandela L, Belcaro G, Cesarone MR, . Changes in microcirculation in venous ulcers with Essaven gel--a pilot, cross-over, placebo-controlled, randomized study. Angiology 2001;52 Suppl 3:S23-7. PMID: 11775645.11775645
Incandela L, Belcaro G, Nicolaides AN, . Superficial vein valve repair with a new external valve support (EVS). The IMES (International Multicenter EVS Study). Angiology 2000;51(8 Pt 2):S39-52. PMID: 10959510.10959510
Jones L, Braithwaite BD, Selwyn D, . Reprinted Article “neovascularisation is the principal cause of varicose vein recurrence: Results of a randomised trial of stripping the long saphenous vein”. European Journal of Vascular and Endovascular Surgery 2011;42(Suppl. 1):S57-S60.21855024
Kahn SR, Azoulay L, Hirsch A, . Acute effects of exercise in patients with previous deep venous thrombosis: impact of the postthrombotic syndrome. Chest 2003;123(2):399-405. PMID: 12576357.12576357
Kala Singh K, Surjyalal Sharma A, Sunil Singh L, . Prevalence and surgical outcomes of varicose veins at Regional Institute of Medical Sciences, Imphal. Journal, Indian Academy of Clinical Medicine 2013;14(3-4):209-213.
Kalodiki E, Calahoras LS, Delis KT, . Air plethysmography: the answer in detecting past deep venous thrombosis. J Vasc Surg 2001;33(4):715-20. PMID: 11296322.11296322
Kianifard B, Holdstock J, Allen C, . Randomized clinical trial of the effect of adding subfascial endoscopic perforator surgery to standard great saphenous vein stripping. Br J Surg 2007;94(9):1075-80. PMID: 17701962.17701962
Kim J, Richards S and Kent PJ. Clinical examination of varicose veins--a validation study. Ann R Coll Surg Engl 2000;82(3):171-5. PMID: 10858678.10858678
Kim JY, Choi D, Guk Ko Y, . Percutaneous treatment of deep vein thrombosis in MayThurner syndrome. Cardiovasc Intervent Radiol 2006;29(4):571-5. PMID: 16502185.16502185
Knipp BS, Blackburn SA, Bloom JR, . Endovenous laser ablation: venous outcomes and thrombotic complications are independent of the presence of deep venous insufficiency. J Vasc Surg 2008;48(6):1538-45. PMID: 18829223.18829223
Koroglu M, Eris HN, Aktas AR, . Endovenous laser ablation and foam sclerotherapy for varicose veins: does the presence of perforating vein insufficiency affect the treatment outcome?. Acta Radiol 2011;52(3):278-84. PMID: 21498363.21498363
Kucharzewski M, Wilemska-Kucharzewska K, Kózka M, . Leg venous ulcer healing process after application of membranous dressing with silver ions. Phlebologie 2013;42(6):340-346.
Kwak HS, Han YM, Lee YS, . Stents in common iliac vein obstruction with acute ipsilateral deep venous thrombosis: early and late results. J Vasc Interv Radiol 2005;16(6):815-22. PMID: 15947045.15947045
Labas P and Cambal M. Profuse bleeding in patients with chronic venous insufficiency. Int Angiol 2007;26(1):64-6. PMID: 17353890.17353890
Lam YL, Toonder IM and Wittens CH. Clarivein(R) mechano-chemical ablation an interim analysis of a randomized controlled trial dose-finding study. Phlebology 2015. PMID: 26249150.26249150
Lane RJ, Graiche JA, Coroneos JC, . Long-term comparison of external valvular stenting and stripping of varicose veins. ANZ J Surg 2003;73(8):605-9. PMID: 12887530.12887530
Lattimer CR, Kalodiki E, Azzam M, . Validation of a new duplex derived haemodynamic effectiveness score, the saphenous treatment score, in quantifying varicose vein treatments. Eur J Vasc Endovasc Surg 2012;43(3):348-54. PMID: 22240336.22240336
Lattimer CR, Kalodiki E, Azzam M, . Validation of the Villalta scale in assessing postthrombotic syndrome using clinical, duplex, and hemodynamic comparators. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2014;2(1):8-14.26992962
Leung TK, Lin JM, Chu CL, . Efficacy of gradual pressure-decline compressing stockings in Asian patients with lower leg varicose veins: analysis by general measurements and magnetic resonance image. Int Angiol 2012;31(6):534-43. PMID: 23222931.23222931
Lin PH, Matos JM, Chen A, . Treatment outcomes and Lessons Learned From Transilluminated Powered Phlebectomy for Varicose Veins in 1034 Patients. Vasc Endovascular Surg 2016;50(4):277-82. PMID: 27114445.27114445
Lorenz D, Gabel W, Redtenbacher M, . Randomized clinical trial comparing bipolar coagulating and standard great saphenous stripping for symptomatic varicose veins. Br J Surg 2007;94(4):434-40. PMID: 17385181.17385181
Lurie F, Comerota A, Eklof B, . Multicenter assessment of venous reflux by duplex ultrasound. J Vasc Surg 2012;55(2):437-45. PMID: 22178437.22178437
Luz BS, Araujo CS, Atzingen DA, . Evaluating the effectiveness of the customized Unna boot when treating patients with venous ulcers. An Bras Dermatol 2013;88(1):41-9. PMID: 23539002.23539002
Ma T, Fu W and Ma J. Popliteal vein external banding at the valve-free segment to treat severe chronic venous insufficiency. J Vasc Surg 2016. PMID: 27131925.27131925
Makarova NP, Lurie F and Hmelniker SM. Does surgical correction of the superficial femoral vein valve change the course of varicose disease?. J Vasc Surg 2001;33(2):361-8. PMID: 11174790.11174790
Mariani F, Mattaliano V, Mosti G, . The treatment of venous leg ulcers with a specifically designed compression stocking kit: Comparison with bandaging. Phlebologie 2008;37(4):191-197.
Maurins U, Rabe E and Pannier F. Does laser power influence the results of endovenous laser ablation (EVLA) of incompetent saphenous veins with the 1 470-nm diode laser? A prospective randomized study comparing 15 and 25 W. Int Angiol 2009;28(1):32-7. PMID: 19190553.19190553
McDonagh B, Huntley DE, Rosenfeld R, . Efficacy of the comprehensive objective mapping, precise image guided injection, anti-reflux positioning and sequential sclerotherapy (CoMPASS) technique in the management of greater saphenous varicosities with saphenofemoral incompetence. Phlebology 2002;17(1):19-28.
Meng QY, Li XQ, Qian AM, . Endovascular treatment of iliac vein compression syndrome. Chin Med J (Engl) 2011;124(20):3281-4. PMID: 22088521.22088521
Milic DJ, Zivic SS, Bogdanovic DC, . A randomized trial of the Tubulcus multilayer bandaging system in the treatment of extensive venous ulcers. J Vasc Surg 2007;46(4):750-5. PMID: 17764879.17764879
Miyazaki K, Nishibe T, Kudo F, . Hemodynamic changes in stripping operation or saphenofemoral ligation of the greater saphenous vein for primary varicose veins. Ann Vasc Surg 2004;18(4):465-9. PMID: 15164263.15164263
Moehrle M, Kemmler J, Rauschenbach M, . Acute and long term effect of compression stockings in athletes with venous insufficiency. Phlebologie 2007;36(6):313-319.
Mol GC, van de Ree MA, Klok FA, . one versus two years of elastic compression stockings for prevention of post-thrombotic syndrome (oCTAVIA study): randomised controlled trial. Bmj 2016;353:i2691. PMID: 27245485.27245485
Mosti G and Partsch H. Compression stockings with a negative pressure gradient have a more pronounced effect on venous pumping function than graduated elastic compression stockings. Eur J Vasc Endovasc Surg 2011;42(2):261-6. PMID: 21612949.21612949
Nayak L, Hildebolt CF and Vedantham S. Postthrombotic syndrome: feasibility of a strategy of imaging-guided endovascular intervention. J Vasc Interv Radiol 2012;23(9):1165-73. PMID: 22841898.22841898
Neglen P and Raju S. Intravascular ultrasound scan evaluation of the obstructed vein. J Vasc Surg 2002;35(4):694-700. PMID: 11932665.11932665
Nelson EA, Harper DR, Prescott RJ, . Prevention of recurrence of venous ulceration: randomized controlled trial of class 2 and class 3 elastic compression. J Vasc Surg 2006;44(4):803-8. PMID: 17012004.17012004
Nelzen o and Fransson I. Early results from a randomized trial of saphenous surgery with or without subfascial endoscopic perforator surgery in patients with a venous ulcer. Br J Surg 2011;98(4):495-500. PMID: 21656715.21656715
ouvry P, Allaert FA, Desnos P, . Efficacy of polidocanol foam versus liquid in sclerotherapy of the great saphenous vein: a multicentre randomised controlled trial with a 2-year follow-up. Eur J Vasc Endovasc Surg 2008;36(3):366-70. PMID: 18524643.18524643
özen Y, Çekmecelioglu D, Sarikaya S, . Mechano-Chemical Endovenous Ablation of Great Saphenous Vein Insufficiency: Two-Year Results. Damar Cer Derg 2014;23(3):176-179.
Park SW, Hwang JJ, Yun IJ, . Randomized clinical trial comparing two methods for endovenous laser ablation of incompetent perforator veins in thigh and great saphenous vein without evidence of saphenofemoral reflux. Dermatol Surg 2012;38(4):640-6. PMID: 22211402.22211402
Park SW, Yun IJ, Hwang JJ, . Fluoroscopy-guided endovenous sclerotherapy using a microcatheter prior to endovenous laser ablation: comparison between liquid and foam sclerotherapy for varicose tributaries. Korean J Radiol 2014;15(4):481-7. PMID: 25053908.25053908
Perrin M. Reconstructive surgery for deep venous reflux: a report on 144 cases. Cardiovasc Surg 2000;8(4):246-55. PMID: 10840201.10840201
Ragg JC. Eccentric compression of large varicose veins after foam sclerotherapy using a novel silicone gel pad. Phlebologie 2014;43(5):250-256.
Raju S, Darcey R and Neglen P. Unexpected major role for venous stenting in deep reflux disease. J Vasc Surg 2010;51(2):401-8; discussion 408. PMID: 20006920.20006920
Rao J, Wildemore JK and Goldman MP. Double-blind prospective comparative trial between foamed and liquid polidocanol and sodium tetradecyl sulfate in the treatment of varicose and telangiectatic leg veins. Dermatol Surg 2005;31(6):631-5; discussion 635. PMID: 15996411.15996411
Rautio T, Perala J, Biancari F, . Accuracy of hand-held Doppler in planning the operation for primary varicose veins. Eur J Vasc Endovasc Surg 2002;24(5):450-5. PMID: 12435347.12435347
Roztocil K, Stvrtinova V and Strejcek J. Efficacy of a 6-month treatment with Daflon 500 mg in patients with venous leg ulcers associated with chronic venous insufficiency. Int Angiol 2003;22(1):24-31. PMID: 12771852.12771852
Saha S, Tiwari A, Hunns C, . Efficacy of topical local anaesthesia to reduce perioperative pain for endovenous laser ablation of varicose veins: a double-blind randomized controlled trial. Ther Adv Cardiovasc Dis 2016. PMID: 2709924227099242
Sang H, Li X, Qian A, . outcome of endovascular treatment in postthrombotic syndrome. Ann Vasc Surg 2014;28(6):1493-500. PMID: 24727397.24727397
Sarac A, Jahollari A, Talay S, . Long-term results of external valvuloplasty in adult patients with isolated great saphenous vein insufficiency. Clin Interv Aging 2014;9:575-9. PMID: 24741299.24741299
Satokawa H, Yokoyama H, Wakamatsu H, . Comparison of Endovenous Laser Treatment for Varicose Veins with High Ligation Using Pulse Mode and without High Ligation Using Continuous Mode and Lower Energy. Ann Vasc Dis 2010;3(1):46-51. PMID: 23555387.23555387
Scheltinga MR, Wijburg ER, Keulers BJ, . Conventional versus invaginated stripping of the great saphenous vein: a randomized, double-blind, controlled clinical trial. World J Surg 2007;31(11):2236-42. PMID: 17763897.17763897
Schwahn-Schreiber C, Marshall M, Murena-Schmidt R, . Long-term observational study on outpatient treatment of venous diseases with medical compression stockings in Germany The mediven® observational study. Phlebologie 2016;45(1):15-24.
Sharifi M, Mehdipour M, Bay C, . Effect of anticoagulation on endothermal ablation of the great saphenous vein. J Vasc Surg 2011;53(1):147-9. PMID: 20864301.20864301
Singer E, Thalhammer C, Degischer S, . Clinical value of interwoven silver fibres in class II compression stockings: Results from a crossover trial. Phlebology 2006;21(3):115-120.
Sutton PA, El-Dhuwaib Y, Dyer J, . The incidence of post operative venous thromboembolism in patients undergoing varicose vein surgery recorded in Hospital Episode Statistics. Ann R Coll Surg Engl 2012;94(7):481-3. PMID: 23031765.23031765
Sybrandy JE, van Gent WB, Pierik EG, . Endoscopic versus open subfascial division of incompetent perforating veins in the treatment of venous leg ulceration: long-term follow-up. J Vasc Surg 2001;33(5):1028-32. PMID: 11331845.11331845
Taradaj J, Rosinczuk J, Dymarek R, . Comparison of efficacy of the intermittent pneumatic compression with a high- and low-pressure application in reducing the lower limbs phlebolymphedema. Ther Clin Risk Manag 2015;11:1545-54. PMID: 26504396.26504396
Ukritmanoroat T. Comparison of efficacy and safety between foam sclerotherapy and conventional sclerotherapy: a controlled clinical trial. J Med Assoc Thai 2011;94 Suppl 2:S35-40. PMID: 21717876.21717876
Uncu H. Sclerotherapy: a study comparing polidocanol in foam and liquid form. Phlebology 2010;25(1):44-9. PMID: 20118346.20118346
Us M, Basaran M, Sanioglu S, . The use of external banding increases the durability of transcommissural external deep venous valve repair. Eur J Vasc Endovasc Surg 2007;33(4):494-501. PMID: 17239634.17239634
van Rij AM, Jones GT, Hill BG, . Mechanical inhibition of angiogenesis at the saphenofemoral junction in the surgical treatment of varicose veins: early results of a blinded randomized controlled trial. Circulation 2008;118(1):66-74. PMID: 18559704.18559704
Vashist MG, Malik V and Singhal N. Role of Subfascial Endoscopic Perforator Surgery (SEPS) in Management of Perforator Incompetence in Varicose Veins: A Prospective Randomised Study. Indian J Surg 2014;76(2):117-23. PMID: 24891775.24891775
Wang H, Sun Z, Jiang W, . Postoperative prophylaxis of venous thromboembolism (VTE) in patients undergoing high ligation and stripping of the great saphenous vein (GSV). Vasc Med 2015;20(2):117-21. PMID: 25601917.25601917
Winterborn RJ and Earnshaw JJ. Randomised trial of polytetrafluoroethylene patch insertion for recurrent great saphenous varicose veins. Eur J Vasc Endovasc Surg 2007;34(3):367-73. PMID: 17512226.17512226
Winterborn RJ, Foy C and Earnshaw JJ. Causes of varicose vein recurrence: late results of a randomized controlled trial of stripping the long saphenous vein. J Vasc Surg 2004;40(4):634-9. PMID: 15472588.15472588
Winterborn RJ, Foy C, Heather BP, . Randomised trial of flush saphenofemoral ligation for primary great saphenous varicose veins. Eur J Vasc Endovasc Surg 2008;36(4):477-84. PMID: 18718771.18718771
Wolpert LM, Rahmani o, Stein B, . Magnetic resonance venography in the diagnosis and management of May-Thurner syndrome. Vasc Endovascular Surg 2002;36(1):51-7. PMID: 12704525.12704525
Yamaki T, Hamahata A, Soejima K, . Prospective randomised comparative study of visual foam sclerotherapy alone or in combination with ultrasound-guided foam sclerotherapy for treatment of superficial venous insufficiency: preliminary report. Eur J Vasc Endovasc Surg 2012;43(3):343-7. PMID: 22230599.22230599
Yamaki T, Nozaki M and Sasaki K. Alternative greater saphenous vein-sparing surgery: valvuloplasty combined with axial transposition of a competent tributary vein for the treatment of primary valvular incompetence---18-month follow-up. Dermatol Surg 2002;28(2):162-7. PMID: 11860429.11860429
Yamaki T, Nozaki M and Sasaki K. Preliminary report of a new approach to sparing the greater saphenous vein for grafting: valvuloplasty combined with axial transposition of a competent tributary vein. J Endovasc Ther 2001;8(2):188-96. PMID: 11357981.11357981
Yilmaz S, Ceken K, Alparslan A, . Endovenous laser ablation and concomitant foam sclerotherapy: experience in 504 patients. Cardiovasc Intervent Radiol 2012;35(6):1403-7. PMID: 22167308.22167308

## Does not include outcomes of interest

Barnikol WK and Potzschke H. A novel, non-invasive diagnostic clinical procedure for the determination of an oxygenation status of chronic lower leg ulcers using peri-ulceral transcutaneous oxygen partial pressure measurements: results of its application in chronic venous insufficiency (CVI). Ger Med Sci 2012;10:Doc11. PMID: 22737104.22737104
Carandina S, Mari C, De Palma M, . Varicose vein stripping vs haemodynamic correction (CHIVA): a long term randomised trial. Eur J Vasc Endovasc Surg 2008;35(2):230-7. PMID: 17964822.17964822
Çeviker K, Şahinalp Ş, ÇiÇek E, . Quality of life in patients with chronic venous disease in Turkey: influence of different treatment modalities at 6-month follow-up. Quality of Life Research 2016;25(6):1527-1536.26567017
Cho ES, Kim JH, Kim S, . Computed tomographic venography for varicose veins of the lower extremities: prospective comparison of 80-kVp and conventional 120-kVp protocols. J Comput Assist Tomogr 2012;36(5):583-90. PMID: 22992610.22992610
Chudek J, Mikosiński J, Kobielski A, . Patients’ satisfaction with therapy methods of advanced chronic venous disease. International Angiology 2016;35(1):98-107.26406967
Cotton SC, MacLennan G, Brittenden J, . Behavioural recovery after treatment for varicose veins. Br J Surg 2016;103(4):374-81. PMID: 26805720.26805720
de Medeiros CA and Luccas GC. Comparison of endovenous treatment with an 810 nm laser versus conventional stripping of the great saphenous vein in patients with primary varicose veins. Dermatol Surg 2005;31(12):1685-94; discussion 1694. PMID: 16336888.16336888
Harding K, Cutting K and Price P. The cost-effectiveness of wound management protocols of care. Br J Nurs 2000;9(19 Suppl):S6, S8, S10 passim. PMID: 12271239.12271239
Hnatek L, Duben J, Gatek J, . Endovascular reflux-elimination of perforating veins by RFITT and foam sclerotherapy. Phlebologie 2015;44(1):13-17.
Konoeda H, Yamaki T, Hamahata A, . Quantification of superficial venous reflux by duplex ultrasound-role of reflux velocity in the assessment the clinical stage of chronic venous insufficiency. Ann Vasc Dis 2014;7(4):376-82. PMID: 25593622.25593622
Kuo YS, Chen CJ, Chen JJ, . May-Thurner syndrome: correlation between digital subtraction and computed tomography venography. J Formos Med Assoc 2015;114(4):363-8. PMID: 25839771.25839771
Latif A, Farhan MA, Waliullah K, . Treatment and incidence of recurrence of varicose veins of lower limbs. Medical Forum Monthly 2014;25(6):33-37.
Marston W, Fish D, Unger J, . Incidence of and risk factors for iliocaval venous obstruction in patients with active or healed venous leg ulcers. J Vasc Surg 2011;53(5):1303-8. PMID: 21215568.21215568
Matic PA, Vlajinac HD, Marinkovic JM, . Chronic venous disease: Correlation between ultrasound findings and the clinical, etiologic, anatomic and pathophysiologic classification. Phlebology 2014;29(8):522-7. PMID: 23858025.23858025
McDermott S, oliveira G, Ergul E, . May-Thurner syndrome: can it be diagnosed by a single MR venography study?. Diagn Interv Radiol 2013;19(1):44-8. PMID: 22801870.22801870
onida S, Shalhoub J, Moore HM, . Factors impacting on patient perception of procedural success and satisfaction following treatment for varicose veins. Br J Surg 2016;103(4):382-90. PMID: 26830251.26830251
Raju S and Neglen P. High prevalence of nonthrombotic iliac vein lesions in chronic venous disease: a permissive role in pathogenicity. J Vasc Surg 2006;44(1):136-43; discussion 144. PMID: 16828437.16828437
Ravi R, Rodriguez-Lopez JA, Trayler EA, . Endovenous ablation of incompetent saphenous veins: a large single-center experience. J Endovasc Ther 2006;13(2):244-8. PMID: 16643080.16643080
Smith JJ, Brown L, Greenhalgh RM, . Randomised trial of pre-operative colour duplex marking in primary varicose vein surgery: outcome is not improved. Eur J Vasc Endovasc Surg 2002;23(4):336-43. PMID: 11991696.11991696
Subramonia S and Lees T. Radiofrequency ablation vs conventional surgery for varicose veins a comparison of treatment costs in a randomised trial. Eur J Vasc Endovasc Surg 2010;39(1):104-11. PMID: 19879166.19879166
Tassie E, Scotland G, Brittenden J, . Cost-effectiveness of ultrasound-guided foam sclerotherapy, endovenous laser ablation or surgery as treatment for primary varicose veins from the randomized CLASS trial. Br J Surg 2014;101(12):1532-40. PMID: 25274220.25274220
Wahlgren CM, Wahlberg E and olofsson P. Endovascular treatment in postthrombotic syndrome. Vasc Endovascular Surg 2010;44(5):356-60. PMID: 20484062.20484062