# Appendix C List of Included Studies

Abela R, Liamis A, Prionidis I, . Reverse foam sclerotherapy of the great saphenous vein with sapheno-femoral ligation compared to standard and invagination stripping: a prospective clinical series. Eur J Vasc Endovasc Surg 2008;36(4):485-90. DoI: 10.1016/j.ejvs.2008.06.029. PMID: 18718769.18718769
Aguilar-Ferrandiz ME, Castro-Sanchez AM, Mataran-Penarrocha GA, . A randomized controlled trial of a mixed Kinesio tapingcompression technique on venous symptoms, pain, peripheral venous flow, clinical severity and overall health status in postmenopausal women with chronic venous insufficiency. Clin Rehabil 2014;28(1):69-81. DoI: 10.1177/0269215512469120. PMID: 23426563.23426563
Aguilar-Ferrandiz ME, Castro-Sanchez AM, Mataran-Penarrocha GA, . Effects of kinesio taping on venous symptoms, bioelectrical activity of the gastrocnemius muscle, range of ankle motion, and quality of life in postmenopausal women with chronic venous insufficiency: a randomized controlled trial. Arch Phys Med Rehabil 2013;94(12):2315-28. DoI: 10.1016/j.apmr.2013.05.016. PMID: 23769763.23769763
Aguilar-Ferrandiz ME, Moreno-Lorenzo C, MataranPenarrocha GA, . Effect of a mixed kinesio taping-compression technique on quality of life and clinical and gait parameters in postmenopausal women with chronic venous insufficiency: doubleblinded, randomized controlled trial. Arch Phys Med Rehabil 2014;95(7):1229-39. DoI: 10.1016/j.apmr.2014.03.024. PMID: 24732169.24732169
Al Shammeri o, AlHamdan N, Al-Hothaly B, . Chronic Venous Insufficiency: prevalence and effect of compression stockings. Int J Health Sci (Qassim) 2014;8(3):231-6. PMID: 25505858.25505858
Almeida JI, Kaufman J, Gockeritz o, . Radiofrequency endovenous ClosureFAST versus laser ablation for the treatment of great saphenous reflux: a multicenter, single-blinded, randomized study (RECOVERY study). J Vasc Interv Radiol 2009;20(6):752-9. DoI: 10.1016/j.jvir.2009.03.008. PMID: 19395275.19395275
Antoch G, Pourhassan S, Hansen o, . Comparison of colour Doppler ultrasonography, ascending phlebography and clinical examination in the diagnosis of incompetent calf perforating veins. Br J Surg 2002;89(2):192-3. DoI: 10.1046/j.00071323.2001.02003.x. PMID: 11856132.11856132
Barwell JR, Davies CE, Deacon J, . Comparison of surgery and compression with compression alone in chronic venous ulceration (ESCHAR study): randomised controlled trial. Lancet 2004;363(9424):1854-9. DoI: 10.1016/s01406736(04)16353-8. PMID: 15183623.15183623
Basela H, Aydina C, Aya Y, . Endovenous laser ablation (EVLA) versus high ligation and striping (HL/S): Two-years follow up. Eastern Journal of Medicine 2011;17(2):83-7.
Belcaro G, Cesarone M, Di Renzo A, . Treatments for varicose veins: Surgery, sclerotherapy, foamsclerotherapy and combined (surgery+sclerotherapy) options. A 10-year, prospective, randomised, controlled, follow-up study. The VEDICO* trial and EST (European Sclerotherapy Trial). Angeiologie 2003;55(1):29-36.
Belcaro G, Cesarone MR, Di Renzo A, . Foamsclerotherapy, surgery, sclerotherapy, and combined treatment for varicose veins: a 10-year, prospective, randomized, controlled, trial (VEDICO trial). Angiology 2003;54(3):307-15. PMID: 12785023.12785023
Belcaro G, Dugall M and Corsi M. Superficial venous incompetence: Low-cost outpatient minisurgery, sclerotherapy and combined procedure as a management plan. Costs and efficacy. A 20-year, follow-up registry. Minerva Chir 2015; PMID: 26046959.26046959
Belcaro G, Nicolaides AN, Ricci A, . Endovascular sclerotherapy, surgery, and surgery plus sclerotherapy in superficial venous incompetence: a randomized, 10-year follow-up trial-final results. Angiology 2000;51(7):529-34. PMID: 10917577.10917577
Benarroch-Gampel J, Sheffield KM, Boyd CA, . Analysis of venous thromboembolic events after saphenous ablation. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2013;1(1):26-32.26993890
Biemans AA, Kockaert M, Akkersdijk GP, . Comparing endovenous laser ablation, foam sclerotherapy, and conventional surgery for great saphenous varicose veins. J Vasc Surg 2013;58(3):727-34.e1. DoI: 10.1016/j.jvs.2012.12.074. PMID: 23769603.23769603
Bootun R, Lane T, Dharmarajah B, . Intraprocedural pain score in a randomised controlled trial comparing mechanochemical ablation to radiofrequency ablation: The Multicentre Venefit versus ClariVein(R) for varicose veins trial. Phlebology. 2016;31(1):61-5. doi: 10.1177/0268355514551085. PMID: 25193822.25193822
Bountouroglou DG, Azzam M, Kakkos SK, . Ultrasound-guided foam sclerotherapy combined with sapheno-femoral ligation compared to surgical treatment of varicose veins: early results of a randomised controlled trial. Eur J Vasc Endovasc Surg 2006;31(1):93-100. DoI: 10.1016/j.ejvs.2005.08.024. PMID: 16233981.16233981
Brittenden J, Cotton SC, Elders A, . A randomized trial comparing treatments for varicose veins. N Engl J Med 2014;371(13):1218-27. DoI: 10.1056/NEJMoa1400781. PMID: 25251616.25251616
Brittenden J, Cotton SC, Elders A, . Clinical effectiveness and cost-effectiveness of foam sclerotherapy, endovenous laser ablation and surgery for varicose veins: results from the Comparison of LAser, Surgery and foam Sclerotherapy (CLASS) randomised controlled trial. Health Technol Assess 2015;19(27):1-342. DoI: 10.3310/hta19270. PMID: 25858333.25858333
Campos W, Jr., Torres Io, da Silva ES, . A prospective randomized study comparing polidocanol foam sclerotherapy with surgical treatment of patients with primary chronic venous insufficiency and ulcer. Ann Vasc Surg 2015;29(6):1128-35. DoI: 10.1016/j.avsg.2015.01.031. PMID: 26004968.26004968
Carpentier PH, Blaise S, Satger B, . A multicenter randomized controlled trial evaluating balneotherapy in patients with advanced chronic venous insufficiency. J Vasc Surg 2014;59(2):447-54.e1. DoI: 10.1016/j.jvs.2013.08.002. PMID: 24135621.24135621
Carradice D, Mekako AI, Hatfield J, . Randomized clinical trial of concomitant or sequential phlebectomy after endovenous laser therapy for varicose veins. Br J Surg 2009;96(4):369-75. DoI: 10.1002/bjs.6556. PMID: 19283745.19283745
Carradice D, Mekako AI, Mazari FA, . Clinical and technical outcomes from a randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg 2011;98(8):1117-23. DoI: 10.1002/bjs.7615. PMID: 21638277.21638277
Carradice D, Mekako AI, Mazari FA, . Randomized clinical trial of endovenous laser ablation compared with conventional surgery for great saphenous varicose veins. Br J Surg 2011;98(4):501-10. DoI: 10.1002/bjs.7394. PMID: 21283981.21283981
Carruthers TN, Farber A, Rybin D, . Interventions on the superficial venous system for chronic venous insufficiency by surgeons in the modern era: an analysis of ACS-NSQIP. Vasc Endovascular Surg 2014;48(7-8):482-90. DoI: 10.1177/1538574414561226. PMID: 25487248.25487248
Christenson JT, Gueddi S, Gemayel G, . Prospective randomized trial comparing endovenous laser ablation and surgery for treatment of primary great saphenous varicose veins with a 2-year followup. J Vasc Surg 2010;52(5):1234-41. DoI: 10.1016/j.jvs.2010.06.104. PMID: 20801608.20801608
Clarke-Moloney M, o’Brien JF, Grace PA, . Health-related quality of life during four-layer compression bandaging for venous ulcer disease: a randomised controlled trial. Ir J Med Sci 2005;174(2):21-5. PMID: 16094908.16094908
Coccheri S, Scondotto G, Agnelli G, . Randomised, double blind, multicentre, placebo controlled study of sulodexide in the treatment of venous leg ulcers. Thromb Haemost 2002;87(6):947-52. PMID: 12083500.12083500
Darwood RJ, Theivacumar N, Dellagrammaticas D, . Randomized clinical trial comparing endovenous laser ablation with surgery for the treatment of primary great saphenous varicose veins. Br J Surg 2008;95(3):294-301. DoI: 10.1002/bjs.6101. PMID: 18278775.18278775
De Franciscis S, Gasbarro V, Amato B, . Hemodynamic surgery versus conventional surgery in chronic venous disease: A multicenter retrospective study. Acta Phlebologica 2013;14(3):109-14.
de Roos KP, Nieman FH and Neumann HA. Ambulatory phlebectomy versus compression sclerotherapy: results of a randomized controlled trial. Dermatol Surg 2003;29(3):221-6. PMID: 12614412.12614412
del Rio Sola ML, Antonio J, Fajardo G, . Influence of aspirin therapy in the ulcer associated with chronic venous insufficiency. Ann Vasc Surg 2012;26(5):620-9. DoI: 10.1016/j.avsg.2011.02.051. PMID: 22437068.22437068
Depalma RG, Kowallek DL, Barcia TC, . Target selection for surgical intervention in severe chronic venous insufficiency: comparison of duplex scanning and phlebography. J Vasc Surg 2000;32(5):913-20. DoI: 10.1067/mva.2000.110347. PMID: 11054223.11054223
Disselhoff BC, Buskens E, Kelder JC, . Randomised comparison of costs and costeffectiveness of cryostripping and endovenous laser ablation for varicose veins: 2-year results. Eur J Vasc Endovasc Surg 2009;37(3):357-63. DoI: 10.1016/j.ejvs.2008.11.013. PMID: 19111485.19111485
Disselhoff BC, der Kinderen DJ, Kelder JC, . Five-year results of a randomized clinical trial comparing endovenous laser ablation with cryostripping for great saphenous varicose veins. Br J Surg 2011;98(8):1107-11. DoI: 10.1002/bjs.7542. PMID: 21633948.21633948
Disselhoff BC, der Kinderen DJ, Kelder JC, . Randomized clinical trial comparing endovenous laser with cryostripping for great saphenous varicose veins. Br J Surg 2008;95(10):1232-8. DoI: 10.1002/bjs.6351. PMID: 18763255.18763255
Elderman JH, Krasznai AG, Voogd AC, . Role of compression stockings after endovenous laser therapy for primary varicosis. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2014;2(3):289-96.26993388
Figueiredo M, Araujo S, Barros N, Jr., . Results of surgical treatment compared with ultrasoundguided foam sclerotherapy in patients with varicose veins: a prospective randomised study. Eur J Vasc Endovasc Surg 2009;38(6):758-63. DoI: 10.1016/j.ejvs.2009.07.015. PMID: 19744867.19744867
Flessenkamper I, Hartmann M, Hartmann K, . Endovenous laser ablation with and without high ligation compared to high ligation and stripping for treatment of great saphenous varicose veins: Results of a multicentre randomised controlled trial with up to 6 years follow-up. Phlebology. 2016 oct 22;31(1):23-33. doi: 10.1177/0268355514555547. PMID: 25342648.25342648
Flessenkamper I, Hartmann M, Stenger D, . Endovenous laser ablation with and without high ligation compared with high ligation and stripping in the treatment of great saphenous varicose veins: initial results of a multicentre randomized controlled trial. Phlebology 2013;28(1):16-23. DoI: 10.1258/phleb.2011.011147. PMID: 22451455.22451455
Franek A, Taradaj J, Polak A, . Efficacy of high voltage stimulation for healing of venous leg ulcers in surgically and conservatively treated patients. Phlebologie 2006;35(3):127-33.
Gale SS, Lee JN, Walsh ME, . A randomized, controlled trial of endovenous thermal ablation using the 810-nm wavelength laser and the ClosurePLUS radiofrequency ablation methods for superficial venous insufficiency of the great saphenous vein. J Vasc Surg 2010;52(3):645-50. DoI: 10.1016/j.jvs.2010.04.030. PMID: 20638231.20638231
Garg N, Gloviczki P, Karimi KM, . Factors affecting outcome of open and hybrid reconstructions for nonmalignant obstruction of iliofemoral veins and inferior vena cava. J Vasc Surg 2011;53(2):383-93. DoI: 10.1016/j.jvs.2010.08.086. PMID: 21146346.21146346
Gauw SA, Lawson JA, van Vlijmen-van Keulen CJ, . Five-year follow-up of a randomized, controlled trial comparing saphenofemoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anesthesia. J Vasc Surg. 2016 oct 22;63(2):420-8. doi: 10.1016/j.jvs.2015.08.084. PMID: 26602795.26602795
Gibson K and Kabnick L. A multicenter, randomized, placebo-controlled study to evaluate the efficacy and safety of Varithena(R) (polidocanol endovenous microfoam 1%) for symptomatic, visible varicose veins with saphenofemoral junction incompetence. Phlebology 2016. DoI: 10.1177/0268355516635386. PMID: 27013511.27013511
Ginsberg JS, Hirsh J, Julian J, . Prevention and treatment of postphlebitic syndrome: results of a 3part study. Arch Intern Med 2001;161(17):2105-9. PMID: 11570939.11570939
Gohel MS, Barwell JR, Earnshaw JJ, . Randomized clinical trial of compression plus surgery versus compression alone in chronic venous ulceration (ESCHAR study)--haemodynamic and anatomical changes. Br J Surg 2005;92(3):291-7. DoI: 10.1002/bjs.4837. PMID: 15584055.15584055
Gohel MS, Barwell JR, Taylor M, . Long term results of compression therapy alone versus compression plus surgery in chronic venous ulceration (ESCHAR): randomised controlled trial. Bmj 2007;335(7610):83. DoI: 10.1136/bmj.39216.542442.BE. PMID: 17545185.17545185
Gohel MS, Barwell JR, Wakely C, . The influence of superficial venous surgery and compression on incompetent calf perforators in chronic venous leg ulceration. Eur J Vasc Endovasc Surg 2005;29(1):78-82. DoI: 10.1016/j.ejvs.2004.09.016. PMID: 15570276.15570276
Goode SD, Chowdhury A, Crockett M, . Laser and radiofrequency ablation study (LARA study): a randomised study comparing radiofrequency ablation and endovenous laser ablation (810 nm). Eur J Vasc Endovasc Surg 2010;40(2):246-53. DoI: 10.1016/j.ejvs.2010.02.026. PMID: 20537570.20537570
Guest M, Smith JJ, Tripuraneni G, . Randomized clinical trial of varicose vein surgery with compression versus compression alone for the treatment of venous ulceration. Phlebology 2003;18(3):130-6.
Hamel-Desnos CM, Guias BJ, Desnos PR, . Foam sclerotherapy of the saphenous veins: randomised controlled trial with or without compression. Eur J Vasc Endovasc Surg 2010;39(4):500-7. DoI: 10.1016/j.ejvs.2009.11.027. PMID: 20097585.20097585
Helmy ElKaffas K, ElKashef o and ElBaz W. Great saphenous vein radiofrequency ablation versus standard stripping in the management of primary varicose veins-a randomized clinical trial. Angiology 2011;62(1):49-54. DoI: 10.1177/0003319710380680. PMID: 20724299.20724299
Holmes CE, Bambace NM, Lewis P, . Efficacy of a short course of complex lymphedema therapy or graduated compression stocking therapy in the treatment of post-thrombotic syndrome. Vasc Med 2014;19(1):42-8. DoI: 10.1177/1358863x14521883. PMID: 24558028.24558028
Houtermans-Auckel JP, van Rossum E, Teijink JA, . To wear or not to wear compression stockings after varicose vein stripping: a randomised controlled trial. Eur J Vasc Endovasc Surg 2009;38(3):387-91. DoI: 10.1016/j.ejvs.2009.05.025. PMID: 19608438.19608438
Jull A, Parag V, Walker N, . The prepare pilot RCT of home-based progressive resistance exercises for venous leg ulcers. J Wound Care 2009;18(12):497-503. DoI: 10.12968/jowc.2009.18.12.45606. PMID: 20081574.20081574
Kahle B and Leng K. Efficacy of sclerotherapy in varicose veins-- prospective, blinded, placebocontrolled study. Dermatol Surg 2004;30(5):723-8; discussion 728. DoI: 10.1111/j.15244725.2004.30207.x. PMID: 15099314.15099314
Kahn SR, Shrier I, Shapiro S, . Six-month exercise training program to treat post-thrombotic syndrome: a randomized controlled two-centre trial. Cmaj 2011;183(1):37-44. DoI: 10.1503/cmaj.100248. PMID: 21098066.21098066
Kalodiki E, Lattimer CR, Azzam M, . Long-term results of a randomized controlled trial on ultrasoundguided foam sclerotherapy combined with saphenofemoral ligation vs standard surgery for varicose veins. J Vasc Surg 2012;55(2):451-7. DoI: 10.1016/j.jvs.2011.08.040. PMID: 22104345.22104345
Kalteis M, Adelsgruber P, Messie-Werndl S, . Five-year results of a randomized controlled trial comparing high ligation combined with endovenous laser ablation and stripping of the great saphenous vein. Dermatol Surg 2015;41(5):579-86. DoI: 10.1097/dss.0000000000000369. PMID: 25899888.25899888
Kalteis M, Berger I, Messie-Werndl S, . High ligation combined with stripping and endovenous laser ablation of the great saphenous vein: early results of a randomized controlled study. J Vasc Surg 2008;47(4):822-9; discussion 829. DoI: 10.1016/j.jvs.2007.10.060. PMID: 18295441.18295441
Kayilioglu SI, Koksoy C and Alacayir I. Diagnostic value of the femoral vein flow pattern for the detection of an iliocaval venous obstruction. J Vasc Surg Venous Lymphat Disord 2016;4(1):2-8. DoI: 10.1016/j.jvsv.2015.08.002. PMID: 26946889.26946889
King JT, o’Byrne M, Vasquez M, . Treatment of Truncal Incompetence and Varicose Veins with a Single Administration of a New Polidocanol Endovenous Microfoam Preparation Improves Symptoms and Appearance. Eur J Vasc Endovasc Surg 2015;50(6):784-93. DoI: 10.1016/j.ejvs.2015.06.111. PMID: 26384639.26384639
Klem TM, Schnater JM, Schutte PR, . A randomized trial of cryo stripping versus conventional stripping of the great saphenous vein. J Vasc Surg 2009;49(2):403-9. DoI: 10.1016/j.jvs.2008.09.016. PMID: 19028042.19028042
Kumar S, Samraj K, Nirujogi V, . Intermittent pneumatic compression as an adjuvant therapy in venous ulcer disease. J Tissue Viability 2002;12(2):42-4, 46, 48 passim. PMID: 12001325.12001325
Kurstjens RL, de Wolf MA, Alsadah SA, . The value of hemodynamic measurements by air plethysmography in diagnosing venous obstruction of the lower limb. J Vasc Surg Venous Lymphat Disord 2016;4(3):313-9. DoI: 10.1016/j.jvsv.2016.01.005. PMID: 27318051.27318051
Lane T, Bootun R, Dharmarajah B, . A multicentre randomised controlled trial comparing radiofrequency and mechanical occlusion chemically assisted ablation of varicose veins - Final results of the Venefit versus Clarivein for varicose veins trial. Phlebology 2016. DoI: 10.1177/0268355516651026. PMID: 27221810.27221810
Lattimer CR, Azzam M, Kalodiki E, . Cost and effectiveness of laser with phlebectomies compared with foam sclerotherapy in superficial venous insufficiency. Early results of a randomised controlled trial. Eur J Vasc Endovasc Surg 2012;43(5):594-600. DoI: 10.1016/j.ejvs.2012.01.032. PMID: 22386383.22386383
Lattimer CR, Kalodiki E, Azzam M, . Interim results on abolishing reflux alongside a randomized clinical trial on laser ablation with phlebectomies versus foam sclerotherapy. Int Angiol 2013;32(4):394-403. PMID: 23822942.23822942
Lee W, Chung JW, Yin YH, . ThreeDimensional CT venography of varicose veins of the lower extremity: image quality and comparison with doppler sonography. AJR Am J Roentgenol 2008;191(4):1186-91. DoI: 10.2214/ajr.07.3471. PMID: 18806163.18806163
Liu P, Ren S, Yang Y, . Intravenous catheterguided laser ablation: a novel alternative for branch varicose veins. Int Surg 2011;96(4):331-6. PMID: 22808616.22808616
Liu X, Jia X, Guo W, . Ultrasound-guided foam sclerotherapy of the great saphenous vein with sapheno-femoral ligation compared to standard stripping: a prospective clinical study. Int Angiol 2011;30(4):321-6. PMID: 21747350.21747350
Lurie F, Creton D, Eklof B, . Prospective randomised study of endovenous radiofrequency obliteration (closure) versus ligation and vein stripping (EVoLVeS): two-year follow-up. Eur J Vasc Endovasc Surg 2005;29(1):67-73. DoI: 10.1016/j.ejvs.2004.09.019. PMID: 15570274.15570274
Lurie F, Creton D, Eklof B, . Prospective randomized study of endovenous radiofrequency obliteration (closure procedure) versus ligation and stripping in a selected patient population (EVoLVeS Study). J Vasc Surg 2003;38(2):207-14. PMID: 12891099.12891099
Lurie F, Creton D, Eklof B, . Reprinted article “Prospective randomised study of endovenous radiofrequency obliteration (closure) versus ligation and vein stripping (EVoLVeS): two-year followup”. Eur J Vasc Endovasc Surg 2011;42(Suppl 1):S107-13. DoI: 10.1016/j.ejvs.2011.06.019. PMID: 21855011.21855011
Mantoni M, Larsen L, Lund Jo, . Evaluation of chronic venous disease in the lower limbs: comparison of five diagnostic methods. Br J Radiol 2002;75(895):578-83. DoI: 10.1259/bjr.75.895.750578. PMID: 12145130.12145130
Massenburg BB, Himel HN, Blue RC, . Magnetic Resonance Imaging in Proximal Venous outflow obstruction. Ann Vasc Surg 2015;29(8):1619-24. DoI: 10.1016/j.avsg.2015.06.083. PMID: 26315799.26315799
Menyhei G, Gyevnar Z, Arato E, . Conventional stripping versus cryostripping: a prospective randomised trial to compare improvement in quality of life and complications. Eur J Vasc Endovasc Surg 2008;35(2):218-23. DoI: 10.1016/j.ejvs.2007.08.017. PMID: 17964821.17964821
Meyer T, Cavallaro A and Lang W. Duplex ultrasonography in the diagnosis of incompetent Cockett veins. Eur J Ultrasound 2000;11(3):175-80. PMID: 10874192.10874192
Michaels JA, Brazier JE, Campbell WB, . Randomized clinical trial comparing surgery with conservative treatment for uncomplicated varicose veins. Br J Surg 2006;93(2):175-81. DoI: 10.1002/bjs.5264. PMID: 16432825.16432825
Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial). Health Technol Assess 2006;10(13):1-196, iii-iv. PMID: 16707070.16707070
Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial). Health Technol Assess 2006;10(13):1-196, iii-iv. PMID: 16707070.16707070
Michaels JA, Campbell WB, Brazier JE, . Randomised clinical trial, observational study and assessment of cost-effectiveness of the treatment of varicose veins (REACTIV trial). Health Technol Assess 2006;10(13):1-196, iii-iv. PMID: 16707070.16707070
Moreno-Moraga J, Smarandache A, Pascu ML, . 1064 nm Nd:YAG long pulse laser after polidocanol microfoam injection dramatically improves the result of leg vein treatment: a randomized controlled trial on 517 legs with a three-year follow-up. Phlebology 2014;29(10):658-66. DoI: 10.1177/0268355513502786. PMID: 23989971.23989971
Morrison N, Gibson K, McEnroe S, . Randomized trial comparing cyanoacrylate embolization and radiofrequency ablation for incompetent great saphenous veins (VeClose). J Vasc Surg 2015;61(4):985-94. DoI: 10.1016/j.jvs.2014.11.071. PMID: 25650040.25650040
Mousa AY, Broce M, Yacoub M, . Validation of venous duplex ultrasound imaging in determining iliac vein stenosis after standard treatment of active chronic venous ulcers. J Vasc Surg Venous Lymphat Disord 2016;4(3):307-12. DoI: 10.1016/j.jvsv.2016.02.002. PMID: 27318050.27318050
Mozafar M, Atqiaee K, Haghighatkhah H, . Endovenous laser ablation of the great saphenous vein versus high ligation: long-term results. Lasers Med Sci 2014;29(2):765-71. DoI: 10.1007/s10103013-1389-z. PMID: 23942818.23942818
Nandhra S, El-sheikha J, Carradice D, . A randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. J Vasc Surg 2015;61(3):741-6. DoI: 10.1016/j.jvs.2014.09.037. PMID: 25720930.25720930
Nelson EA, Prescott RJ, Harper DR, . A factorial, randomized trial of pentoxifylline or placebo, four-layer or single-layer compression, and knitted viscose or hydrocolloid dressings for venous ulcers. J Vasc Surg 2007;45(1):134-41. DoI: 10.1016/j.jvs.2006.09.043. PMID: 17210398.17210398
Nikolovska S, Pavlova L, Petrova N, . Pentoxifylline--efficient in the treatment of venous ulcers in the absence of compression?. Acta Dermatovenerol Croat 2002;10(1):9-13. PMID: 12137725.12137725
Noppeney T, Storck M, Nüllen H, . Perioperative quality assessment of varicose vein surgery: Commission for quality assessment of the German Society for Vascular Surgery. Langenbeck’s Archives of Surgery 2016;401(3):375-80.
Nordon IM, Hinchliffe RJ, Brar R, . A prospective double-blind randomized controlled trial of radiofrequency versus laser treatment of the great saphenous vein in patients with varicose veins. Ann Surg 2011;254(6):876-81. DoI: 10.1097/SLA.0b013e318230af5a. PMID: 21934487.21934487
obi AT, Reames BN, Rook TJ, . outcomes associated with ablation compared to combined ablation and transilluminated powered phlebectomy in the treatment of venous varicosities. Phlebology 2015. DoI: 10.1177/0268355515604257. PMID: 26376824.26376824
o’Hare JL and Earnshaw JJ. Randomised clinical trial of foam sclerotherapy for patients with a venous leg ulcer. Eur J Vasc Endovasc Surg 2010;39(4):495-9. DoI: 10.1016/j.ejvs.2009.11.025. PMID: 20006528.20006528
o’Sullivan GJ, Semba CP, Bittner CA, . Endovascular management of iliac vein compression (May-Thurner) syndrome. J Vasc Interv Radiol 2000;11(7):823-36. PMID: 10928517.10928517
Pares Jo, Juan J, Tellez R, . Varicose vein surgery: stripping versus the CHIVA method: a randomized controlled trial. Ann Surg 2010;251(4):624-31. DoI: 10.1097/SLA.0b013e3181d0d0a3. PMID: 20224376.20224376
Perala J, Rautio T, Biancari F, . Radiofrequency endovenous obliteration versus stripping of the long saphenous vein in the management of primary varicose veins: 3-year outcome of a randomized study. Ann Vasc Surg 2005;19(5):669-72. DoI: 10.1007/s10016-005-6613-2. PMID: 16052388.16052388
Pronk P, Gauw SA, Mooij MC, . Randomised controlled trial comparing sapheno-femoral ligation and stripping of the great saphenous vein with endovenous laser ablation (980 nm) using local tumescent anaesthesia: one year results. Eur J Vasc Endovasc Surg 2010;40(5):649-56. DoI: 10.1016/j.ejvs.2010.08.007. PMID: 20888274.20888274
Rabahie GN, Waisberg DR, Martins LC, . Comparative study among the physical examination, echo-color Doppler mapping and operative approaching in the recurrent lower extremity varicose veins from the saphenofemoral junction. Jornal Vascular Brasileiro 2011;10(3):198-204.
Rabe E, Schliephake D, otto J, . Sclerotherapy of telangiectases and reticular veins: a double-blind, randomized, comparative clinical trial of polidocanol, sodium tetradecyl sulphate and isotonic saline (EASI study). Phlebology 2010;25(3):124-31. DoI: 10.1258/phleb.2009.009043. PMID: 20483861.20483861
Raju S, Kirk oK and Jones TL. Endovenous management of venous leg ulcers. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2013;1(2):165-72.26992338
Rasmussen L, Lawaetz M, Bjoern L, . Randomized clinical trial comparing endovenous laser ablation and stripping of the great saphenous vein with clinical and duplex outcome after 5 years. J Vasc Surg 2013;58(2):421-6. DoI: 10.1016/j.jvs.2012.12.048. PMID: 23768792.23768792
Rasmussen L, Lawaetz M, Serup J, . Randomized clinical trial comparing endovenous laser ablation, radiofrequency ablation, foam sclerotherapy, and surgical stripping for great saphenous varicose veins with 3-year follow-up. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2013;1(4):349-56.26992754
Rasmussen LH, Bjoern L, Lawaetz M, . Randomised clinical trial comparing endovenous laser ablation with stripping of the great saphenous vein: clinical outcome and recurrence after 2 years. Eur J Vasc Endovasc Surg 2010;39(5):630-5. DoI: 10.1016/j.ejvs.2009.11.040. PMID: 20064730.20064730
Rasmussen LH, Bjoern L, Lawaetz M, . Randomized trial comparing endovenous laser ablation of the great saphenous vein with high ligation and stripping in patients with varicose veins: short-term results. J Vasc Surg 2007;46(2):308-15. DoI: 10.1016/j.jvs.2007.03.053. PMID: 17600655.17600655
Rasmussen LH, Lawaetz M, Bjoern L, . Randomized clinical trial comparing endovenous laser ablation, radiofrequency ablation, foam sclerotherapy and surgical stripping for great saphenous varicose veins. Br J Surg 2011;98(8):1079-87. DoI: 10.1002/bjs.7555. PMID: 21725957.21725957
Rass K, Frings N, Glowacki P, . Comparable effectiveness of endovenous laser ablation and high ligation with stripping of the great saphenous vein: two-year results of a randomized clinical trial (RELACS study). Arch Dermatol 2012;148(1):49-58. DoI: 10.1001/archdermatol.2011.272. PMID: 21931012.21931012
Rass K, Frings N, Glowacki P, . Same Site Recurrence is More Frequent After Endovenous Laser Ablation Compared with High Ligation and Stripping of the Great Saphenous Vein: 5 year Results of a Randomized Clinical Trial (RELACS Study). Eur J Vasc Endovasc Surg 2015;50(5):648-56. DoI: 10.1016/j.ejvs.2015.07.020. PMID: 26319476.26319476
Rautio T, ohinmaa A, Perala J, . Endovenous obliteration versus conventional stripping operation in the treatment of primary varicose veins: a randomized controlled trial with comparison of the costs. J Vasc Surg 2002;35(5):958-65. PMID: 12021712.12021712
Roopram AD, Lind MY, Van Brussel JP, . Endovenous laser ablation versus conventional surgery in the treatment of small saphenous vein incompetence. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2013;1(4):357-63.26992756
Samuel N, Carradice D, Wallace T, . Randomized clinical trial of endovenous laser ablation versus conventional surgery for small saphenous varicose veins. Ann Surg 2013;257(3):419-26. DoI: 10.1097/SLA.0b013e318275f4e4. PMID: 23160149.23160149
Schouten R, Mollen RM and Kuijpers HC. A comparison between cryosurgery and conventional stripping in varicose vein surgery: perioperative features and complications. Ann Vasc Surg 2006;20(3):306-11. DoI: 10.1007/s10016-006-9051x. PMID: 16779510.16779510
Sell H, Vikatmaa P, Alback A, . Compression therapy versus surgery in the treatment of patients with varicose veins: A RCT. Eur J Vasc Endovasc Surg 2014;47(6):670-7. DoI: 10.1016/j.ejvs.2014.02.015. PMID: 24675145.24675145
Serra R, Buffone G, Molinari V, . Low molecular weight heparin improves healing of chronic venous ulcers especially in the elderly. Int Wound J 2015;12(2):150-3. DoI: 10.1111/iwj.12071. PMID: 23517508.23517508
Shadid N, Ceulen R, Nelemans P, . Randomized clinical trial of ultrasound-guided foam sclerotherapy versus surgery for the incompetent great saphenous vein. Br J Surg 2012;99(8):1062-70. DoI: 10.1002/bjs.8781. PMID: 22627969.22627969
Shepherd AC, Gohel MS, Brown LC, . Randomized clinical trial of VNUS ClosureFAST radiofrequency ablation versus laser for varicose veins. Br J Surg 2010;97(6):810-8. DoI: 10.1002/bjs.7091. PMID: 20473992.20473992
Shepherd AC, ortega-ortega M, Gohel MS, . Cost-effectiveness of radiofrequency ablation versus laser for varicose veins. Int J Technol Assess Health Care 2015; 31(5):289-96. DoI: 10.1017/s0266462315000537. PMID: 26715372.26715372
Stötter L, Schaaf I and Bockelbrink A. Comparative outcomes of radiofrequency endoluminal ablation, invagination stripping, and cryostripping in the treatment of great saphenous vein insufficiency. Phlebology 2006;21(2):60-4.
Subramonia S and Lees T. Randomized clinical trial of radiofrequency ablation or conventional high ligation and stripping for great saphenous varicose veins. Br J Surg 2010;97(3):328-36. DoI: 10.1002/bjs.6867. PMID: 20035541.20035541
Theivacumar NS, Dellagrammaticas D, Mavor AI, . Endovenous laser ablation: does standard aboveknee great saphenous vein ablation provide optimum results in patients with both above- and below-knee reflux? A randomized controlled trial. J Vasc Surg 2008;48(1):173-8. DoI: 10.1016/j.jvs.2008.01.062. PMID: 18440756.18440756
Todd KL, 3rd and Wright DI. The VANISH-2 study: a randomized, blinded, multicenter study to evaluate the efficacy and safety of polidocanol endovenous microfoam 0.5% and 1.0% compared with placebo for the treatment of saphenofemoral junction incompetence. Phlebology 2014;29(9):608-18. DoI: 10.1177/0268355513497709. PMID: 23864535.23864535
van den Bos RR, Malskat WS, De Maeseneer MG, . Randomized clinical trial of endovenous laser ablation versus steam ablation (LAST trial) for great saphenous varicose veins. Br J Surg 2014;101(9):1077-83. DoI: 10.1002/bjs.9580. PMID: 24981585.24981585
van der Velden SK, Biemans AA, De Maeseneer MG, . Five-year results of a randomized clinical trial of conventional surgery, endovenous laser ablation and ultrasound-guided foam sclerotherapy in patients with great saphenous varicose veins. Br J Surg 2015;102(10):1184-94. DoI: 10.1002/bjs.9867. PMID: 26132315.26132315
van Gent WB, Catarinella FS, Lam YL, . Conservative versus surgical treatment of venous leg ulcers: 10-year follow up of a randomized, multicenter trial. Phlebology 2015;30(1 Suppl):35-41. DoI: 10.1177/0268355514568848. PMID: 25729066.25729066
van Gent WB, Hop WC, van Praag MC, . Conservative versus surgical treatment of venous leg ulcers: a prospective, randomized, multicenter trial. J Vasc Surg 2006;44(3):563-71. DoI: 10.1016/j.jvs.2006.04.053. PMID: 16950434.16950434
Vandongen YK and Stacey MC. Graduated compression elastic stockings reduce lipodermatosclerosis and ulcer recurrence. Phlebology 2000;15(1):33-7.
Vanscheidt W, Rabe E, Naser-Hijazi B, . The efficacy and safety of a coumarin-/troxerutincombination (SB-LoT) in patients with chronic venous insufficiency: a double blind placebocontrolled randomised study. Vasa 2002;31(3):185-90. DoI: 10.1024/0301-1526.31.3.185. PMID: 12236023.12236023
Vasquez M and Gasparis AP. A multicenter, randomized, placebo-controlled trial of endovenous thermal ablation with or without polidocanol endovenous microfoam treatment in patients with great saphenous vein incompetence and visible varicosities. Phlebology 2016. DoI: 10.1177/0268355516637300. PMID: 26957489.26957489
Viarengo LM, Poterio-Filho J, Poterio GM, . Endovenous laser treatment for varicose veins in patients with active ulcers: measurement of intravenous and perivenous temperatures during the procedure. Dermatol Surg 2007;33(10):1234-42; discussion 1241-2. DoI: 10.1111/j.15244725.2007.33259.x. PMID: 17903157.17903157
Wang H, Chen Q, Fei Z, . Hemodynamic classification and CHIVA treatment of varicose veins in lower extremities (VVLE). International Journal of Clinical and Experimental Medicine 2016;9(2):2465-71.
Wong IK, Andriessen A, Charles HE, . Randomized controlled trial comparing treatment outcome of two compression bandaging systems and standard care without compression in patients with venous leg ulcers. J Eur Acad Dermatol Venereol 2012;26(1):102-10. DoI: 10.1111/j.14683083.2011.04327.x. PMID: 22077933.22077933
Wozniak W, Mlosek RK and Ciostek P. Assessment of the efficacy and safety of steam vein sclerosis as compared to classic surgery in lower extremity varicose vein management. Wideochir Inne Tech Maloinwazyjne 2015;10(1):15-24. DoI: 10.5114/wiitm.2015.48573. PMID: 25960788.25960788
Wright D, Gobin JP, Bradbury AW, . Varisolve® polidocanol microfoam compared with surgery or sclerotherapy in the management of varicose veins in the presence of trunk vein incompetence: European randomized controlled trial. Phlebology 2006;21(4):180-90.
Yang L, Wang XP, Su WJ, . Randomized clinical trial of endovenous microwave ablation combined with high ligation versus conventional surgery for varicose veins. Eur J Vasc Endovasc Surg 2013;46(4):473-9. DoI: 10.1016/j.ejvs.2013.07.004. PMID: 23911734.23911734
Yin M, Huang X, Cui C, . The effect of stent placement for May-Thurner syndrome combined with symptomatic superficial venous reflux disease. Journal of Vascular Surgery: Venous and Lymphatic Disorders 2015;3(2):168-72.26993835
Yin M, Shi H, Ye K, . Clinical Assessment of Endovascular Stenting Compared with Compression Therapy Alone in Post-thrombotic Patients with Iliofemoral obstruction. Eur J Vasc Endovasc Surg 2015;50(1):101-7. DoI: 10.1016/j.ejvs.2015.02.007;10.1016/j.ejvs.2015.03.029. PMID: 25920630.25920630
Zamboni P, Cisno C, Marchetti F, . Haemodynamic CHIVA correction surgery versus compression for primary venous ulcers: First year results. Phlebology 2004;19(1):28-34.
Zamboni P, Cisno C, Marchetti F, . Minimally invasive surgical management of primary venous ulcers vs. compression treatment: a randomized clinical trial. Eur J Vasc Endovasc Surg 2003;25(4):313-8. DoI: 10.1053/ejvs.2002.1871. PMID: 12651168.12651168