# Appendix B Data Abstraction Elements

## Study Characteristics

- Study Identifiers
  ○ Study Name or Acronym
  ○ NCT number or other trial registry identifier
  ○ Last name of first author
- Additional Articles Used in This Abstraction
- Study Sites
  ○ Single center, Multicenter, Unclear/Not reported
  ○ Number of sites
- Geographic Location (Select all that apply)
  ○ US, Canada, UK/Europe, Latin America, Middle East (includes Israel), Asia, Africa, Australia/NZ, Unclear/Not reported
- Study Design
  ○ RCT
  ○ observational
- Funding Source (Select all that apply)
  ○ Government, Industry, Non-government/non-industry, Unclear/Not reported
- Setting (Select all that apply)
  ○ Primary care, Specialty Care (e.g. surgery, cardiology, vein clinic), other, Unclear/Not reported
- Diagnostic tool or criteria used in the study
- Study Enrollment/Study Completion
  ○ N enrolled/included
  ○ N completed
- Key Question Applicability (Select all that apply)
  ○ KQ1, KQ2, KQ3
- Study patient population defined as
  ○ Symptomatic, Asymptomatic, Unclear/Not reported
- Conditions described in patient population
  ○ LE varicose veins, LE chronic venous insufficiency/reflux/incompetency, LE
  - venous thrombosis/obstruction, Post-thrombotic syndrome, Unclear/Not reported
- Comments

## Baseline Characteristics

- Record the following elements for Total Population, Arm 1, Ami 2, Arm 3, Arm 4, Arm 5, and Arm 6 (as applicable)
  ○ Number of Patients (N and %)
  ○ Male and Female (N and %)
  ○ Age in years
    - Mean
    - Median
    - Standard Deviation
    - Min
    - Max
    - 25% IQR
    - 75% IQR
    - Categorical
    - other, specify
  ○ Race/Ethnicity (N and %)
    - Hispanic or Latino
    - Black/African American
    - American Indian or Alaska Native
    - Asian
    - Native Hawaiian or Pacific Islander
    - White
    - Multiracial
    - other
  ○ Body Weight
    - Reported (describe), NR or Unclear
  ○ CEAP Classification
    - Reported (describe), NR or Unclear
  ○ VCSS Classification
    - Reported (describe), NR or Unclear
  ○ Villalta Score
    - Reported (describe), NR or Unclear
  ○ Severity of Disease
    - Reported (describe), NR or Unclear
  ○ Anatomic Segment
    - Reported (describe), NR or Unclear
  ○ Known Malignancy
    - Reported (describe), NR or Unclear
  ○ Presence of LE Ulcer
    - Reported (describe), NR or Unclear
- Were there relevant differences noted between groups in any other baseline characteristic? (Yes/No)
  ○ If yes, describe the differences.
- Comments

## KQ 2-3 Intervention Characteristics

- Intervention Descriptors (For each Arm)
  ○ Describe the intervention received by each patient group.
- Indicate components of the intervention (For each Arm – representing main categories)
  ○ Placebo or Control
  ○ Lifestyle Interventions
  ○ Medical Therapy
  ○ Local Skin Care/Wound Care
  ○ Mechanical Compression Therapy
  ○ Invasive Surgical/Endovascular Procedures
- Specify applicable components from the selected main categories (For each Arm)
  ○ Placebo or Control
    - Placebo
    - Usual care control/ optimal medical therapy
    - other, specify
  ○ Lifestyle Intervention
    - Smoking cessation
    - Leg elevation
    - Weight reduction
    - Exercise
    - other, specify
  ○ Medical Therapy
    - Diuretics
    - Anticoagulants
    - Aspirin
    - Pentoxifylline
    - Prostacyclins
    - Zinc sulfate
    - Warfarin
    - Apixaban
    - Rivaroxaban
    - Edoxaban
    - Dabigatran
    - other, specify
  ○ Mechanical Compression Therapy (indicate mmHg where applicable)
    - Pump
    - Wrap
    - other, specify
    - Unclear/NR
  ○ Invasive/Endovascular Procedures
    - Ablation - Chemical/Mechanicochemical
    - Ablation - Laser
    - Ablation - Radiofrequency
    - Ablation - Thermal
    - Angioplasty
    - Cryostripping
    - Phlebectomy
    - Sclerotherapy - Foam
    - Sclerotherapy - Glue
    - Sclerotherapy - Liquid
    - Stenting
    - Surgical stripping
    - Surgical thromboembolectomy
    - Ultrasound accelerated thrombolysis (e.g. Ekosonic)
    - Venous excision
    - Venous ligation
    - other, specify
- Comments

## KQ 1 Interventions/outcomes

- Indicate/ describe diagnostic tests applied
- Indicate/ describe gold standard used
- Findings for outcomes of interest
  ○ Sensitivity
  ○ Specificity
  ○ Positive predictive value
  ○ Negative predictive value
  ○ Inter-rater reliability
  ○ Internal consistency
  ○ Test-retest reliability
  ○ False positives
  ○ False negatives
  ○ Positive likelihood ratio
  ○ Negative likelihood ratio
- Comments

## KQ 2 and KQ 3 outcomes

- Select the outcome reported on this form:
  ○ Adverse effects of treatment:
    - Adverse drug reactions
    - Bleeding (including intracranial bleeding)
    - Venous wound infection
    - Contrast Nephropathy
    - Radiation-related injuries
    - Exercise-related harms
    - Periprocedural complications (vessel dissection, vessel perforation, and AV fistula)
    - Thrombophlebitis
    - Venous thromboembolic events (including PE)
    - Venous thrombosis (including stent thrombosis)
    - Death
  ○ Changes on standardized symptom scores
    - Symptom score used
    - Villalta
    - CEAP
    - VCSS
    - other, specify
  ○ Patient-reported quality of life (including AVVQ)
    - Was a summary score reported? (Yes/No)
    - Were subscores for that QOL measure reported? (Yes/No)
    - What subscores were reported?
  ○ Qualitative reduction in LE edema
  ○ Qualitative reduction in LE pain
  ○ Improvement in LE venous hemodynamics/reflux severity as measured by air plethysmography, duplex ultrasonography, or invasive venography
  ○ Venous wound healing
  ○ Recurrent ulceration
  ○ Repeat intervention
  ○ LE Amputation
- Is this outcome form for a subgroup of interest? (Yes/No)
  ○ What subpopulation is this outcome reported for on this form?
    - Age
    - Sex
    - Race/ethnicity
    - Body weight
    - CEAP classification
    - VCSS classification
    - Villalta score
    - Severity of Disease
    - Anatomic segment affected
    - Known malignancy
    - Presence of LE Ulcer
- Any additional description/ clarification of the outcome reported on this form
- Total N Analyzed for this outcome
- Timepoint reported on this form
  ○ Short-term (<30 days)
  ○ Intermediate-term (31 days to 6 months)
  ○ Long-term (6+ months)
- Specify actual timing of the outcome (Day(s)/Week(s)/Month(s)/Year(s))
- For each arm:
  ○ N Analyzed (enter UNK if unknown)
  ○ Unadjusted Result
    - Number of patients with outcome
    - % of patients with outcome
    - Events/denominator
    - odds ratio
    - Hazard ratio
    - Relative risk
    - Mean
    - Median
    - Mean within group change
    - Mean between group change
    - other (specify)
  ○ Unadjusted Result Variability
    - 95% CI
    - IQR
    - Standard Error (SE)
    - Standard Deviation (SD)
    - other % CI (specify)
    - other (specify)
  ○ Unadjusted Result, p-value between groups
  ○ Unadjusted Result, Reference group (for comparison between groups)
  ○ Adjusted Result
    - Number of patients with outcome
    - % of patients with outcome
    - Events/denominator
    - odds ratio
    - Hazard ratio
    - Relative risk
    - Mean
    - Median
    - Mean within group change
    - Mean between group change
    - other (specify)
  ○ Adjusted Result Variability
    - 95% CI
    - IQR
    - Standard Error (SE)
    - Standard Deviation (SD)
    - other % CI (specify)
    - other (specify)
  ○ Adjusted Result, p-value between groups
  ○ Adjusted Result, Reference group (for comparison between groups)
  ○ If adjusted data is recorded, indicate the adjustments applied
- Comments

## Quality

- Study Type (select one):
  ○ RCT
  ○ observational
    - Cohort
    - Case-control
- If RCT, select Yes/No/Unclear for each of the following questions:
  ○ Sequence generation
    - Was the allocation sequence generated adequately (e.g., random number table, computer-generated randomization)?
  ○ Allocation concealment
    - Was the allocation of treatment adequately concealed (e.g., pharmacycontrolled randomization or use of sequentially numbered sealed envelopes)?
  ○ Blinding of participants, personnel and outcome assessors
    - Was knowledge of the allocated intervention adequately prevented during the study?
  ○ Incomplete outcome data
    - Were incomplete outcome data adequately addressed?
    o Selective outcome reporting
    - Are reports of the study free of suggestion of selective outcome reporting?
  ○ other sources of bias
    - Was the study apparently free of other problems that could put it at a high risk of bias?
- If cohort, select the most appropriate option for each statement:
  ○ Selection bias
    - Representativeness of the exposed cohort...
      - truly representative of the average peripheral venous disease patient in the community
      - somewhat representative of the average peripheral venous disease patient in the community
      - selected group of users (e.g. nurses, volunteers)
      - no description of the derivation of the cohort
    - Selection of the non-exposed cohort...
      - drawn from the same community as the exposed cohort
      - drawn from a different source
      - no description of the derivation of the non-exposed cohort
    - Ascertainment of exposure...
      - secure record (e.g. surgical records)
      - structured interview
      - written self-report
      - no description
    - Demonstration that outcome of interest was not present at start of study? (Yes/No)
  ○ Comparability
    - Comparability of cohorts on the basis of the design or analysis...
      - study controls for underlying severity of disease and anatomic location
      - study controls for any additional factor
  ○ outcome
    - Assessment of outcome...
      - independent blind assessment
      - record linkage
      - self-report
      - no description
    - Was follow-up long enough for outcome to occur (Yes/No)?
    - Adequacy of follow up of cohorts...
      - complete follow up - all subjects accounted for
      - subjects lost to follow up unlikely to introduce bias - small number lost - > 90% follow up, or description provided of those lost
      - follow up rate < 90% and no description of those lost
      - no statement
- If case-control, select the most appropriate option for each statement:
  ○ Selection bias
    - Is the case definition adequate?
      - yes, with independent validation
      - yes, e.g. record linkage or base on self-reports
      - no description
    - Representativeness of the cases...
      - consecutive or obviously representative series of cases
      - potential for selection biases or not stated
    - Selection of Controls
      - community controls
      - hospital controls
      - no description
    - Definition of Controls
      - no history of disease (endpoint)
      - no description of source
○ Comparability
  - Comparability of cases and controls on the basis of the design or analysis
    - study controls for underlying severity of disease and anatomic location
    - study controls for any additional factor
○ Exposure
  - Ascertainment of exposure...
    - secure record (e.g. surgical records)
    - structured interview where blind to case/control status
    - interview not blinded to case/control status
    - written self-report or medical record only
    - no description
  - Was there the same method of ascertainment for cases and controls (Yes/No)?
  - Non-Response rate...
    - same rate for both groups
    - non respondent described
    - rate different and no designation
- overall Study Risk of Bias Rating (Good/Fair/Poor)
  ○ Good (low risk of bias). These studies have the least bias, and the results are considered valid. These studies adhere to the commonly held concepts of high quality, including the following: a clear description of the population, setting, approaches, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytical methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
  ○ Fair. These studies are susceptible to some bias, but not enough to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. o Poor (high risk of bias). These studies have significant flaws that may have invalidated the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.
  ○ If the study is rated as “Fair” or “Poor,” provide rationale.
- outcome-specific quality rating
  ○ Should any of the outcomes abstracted for this study should be assigned a quality rating DIFFERENT from the overall study rating? (No/Yes)
    - If yes, provide the outcome(s), rating(s) and rationale(s).
- For KQ1 Studies only:
  ○ QUADAS-2 Tool for Quality Assessment of Studies of Diagnostic Accuracy.
    - Domain 1: Patient Selection
      - Was a consecutive or random sample of patients enrolled? (Yes/No/Unclear)
      - Was a case-control design avoided? (Yes/No/Unclear)
      - Did the study avoid inappropriate exclusions? (Yes/No/Unclear)
      - Summary: Could the selection of patients have introduced bias? (Risk: Low, High, Unclear)
    - Domain 2: Index Tests
      - Were the index test results interpreted without knowledge of the reference standard? (Yes/No/Unclear)
      - If a threshold was used, was it pre-specified? (Yes/No/Unclear)
      - Summary: Could the conduct or interpretation of the index test have introduced bias? (Risk: Low, High, Unclear)
    - Domain 3: Reference Standards
      - Is the reference standard likely to correctly classify the target condition? (Yes/No/Unclear)
      - Were the reference standard results interpreted without knowledge of the results of the index test? (Yes/No/Unclear)
      - Summary: Could the reference standard, its conduct, or its interpretation have introduced bias? (Risk: Low, High, Unclear)
    - Domain 4: Flow and Timing
      - Was there an appropriate interval between index test(s) and reference standard? (Yes/No/Unclear)
      - Did all patients receive a reference standard? (Yes/No/Unclear)
      - Did all patients receive the same reference standard? (Yes/No/Unclear)
      - Were all patients included in the analysis? (Yes/No/Unclear)
      - Summary: Could the patient flow have introduced bias? (Risk: Low, High, Unclear)
  ○ overall QUADAS-2 Study Rating (Low/Medium/High risk of bias)
    - Low risk of bias. No major features that risk biased results. RCTs are considered a high-quality study design, but studies that include consecutive patients representative of the intended sample for whom diagnostic uncertainty exists may also meet this standard. A “low risk” study avoids the multiple biases to which medical test studies are subject (e.g., use of an inadequate reference standard, verification bias), and key study features are clearly described, including the comparison groups, outcomes measurements, and characteristics of patients who failed to have actual state (diagnosis or prognosis) verified.
    - Medium risk of bias. Susceptible to some bias, but flaws not sufficient to invalidate the results. The study does not meet all the criteria required for a rating of low risk, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
    - High risk of bias. Significant flaws imply biases of various types that may invalidate the results. The study has significant biases determined a priori to be major or “fatal” (i.e., likely to make the results either uninterpretable or invalid).
    - If the study is rated as “Medium” or “High” risk of bias, provide rationale.
  ○ QUADAS-2 outcome-specific quality rating
    - Should any of the outcomes abstracted for this study should be assigned a quality rating DIFFERENT from the overall study rating? (No/Yes)
      - If yes, provide the outcome(s), rating(s) and rationale(s).
- Comments

Applicability – Use the PICoTS format to identify specific issues, if any, which may limit the applicability of the study.

- Population (P)
  ○ Narrow eligibility criteria and exclusion of those with comorbidities
  ○ More complex patients than typical of the community
  ○ Run-in period with high exclusion rate for non-adherence or side effects
  ○ Narrow or unrepresentative severity, stage of illness, or comorbidities
- Intervention (I)
  ○ Diagnostic tools used differently than as recommended or commonly used in practice
  ○ Dosing not reflective of current practice
  ○ Co-intervention that are likely to modify the effectiveness of therapy
  ○ Highly selected intervention team or level of training/proficiency not widely available
  ○ Follow-up not reflective of current practice
- Comparator (C)
  ○ Diagnostic tools used differently than as recommended or commonly used in practice
  ○ Comparator unclear
  ○ Inadequate comparison therapy or use of a substandard alternative therapy
- outcomes (o)
  ○ Composite outcomes that mix outcomes of different significance
  ○ Short-term follow-up
  ○ Surrogate outcomes
- Timing (T)
  ○ Duration of participant followup was inadequate
- Setting (S)
  ○ Study conducted solely outside the US
  ○ Study was conducted only at a single site
- Any other concerns regarding the applicability of this study? (Yes/No)
  ○ If yes, describe.
- Comments