# Appendix A Exact Search Strings

## PubMed^®^ search strategy (June 30, 2016)

KQ 1:

#1 | “Varicose Veins”[Mesh] OR “Venous Insufficiency”[Mesh] OR “Venous Thromboembolism”[Mesh] OR “May-Thurner Syndrome”[Mesh] OR “Thrombophlebitis”[Mesh] OR “varicose vein”[tiab] OR “varicose veins”[tiab] OR varicosity[tiab] OR “venous ulcer”[tiab] OR “vein ulcer”[tiab] OR “varicose ulcer”[tiab] OR “venous ulcers”[tiab] OR “vein ulcers”[tiab] OR “varicose ulcers”[tiab] OR “stasis dermatitis”[tiab] OR “venous stasis”[tiab] OR “vein insufficiency”[tiab] OR “venous insufficiency”[tiab] OR “vein incompetence”[tiab] OR “venous incompetence”[tiab] OR “vein reflux”[tiab] OR “venous reflux”[tiab] OR “post-thrombotic syndrome”[tiab] OR “postthrombotic syndrome”[tiab] OR “venous obstruction”[tiab] OR “vein obstruction”[tiab] OR thrombophlebitis[tiab] OR “venous outflow disease”[tiab] OR “venous outflow obstruction”[tiab] OR “impaired venous outflow”[tiab] OR “post phlebitis”[tiab] OR “post phlebitic”[tiab] OR postphlebitic[tiab] OR postphlebitis[tiab] OR “post thrombotic”[tiab] OR postthrombosis[tiab] OR postthrombotic[tiab] OR “post thrombosis”[tiab] OR “chronic venous thrombosis”[tiab] OR “chronic vein thrombosis”[tiab] OR “May-Thurner Syndrome”[tiab] OR ((“Venous Thrombosis”[Mesh] OR “deep vein thrombosis”[tiab] OR “venous thrombosis”[tiab] OR dvt[tiab]) AND chronic[tiab])
#2 | “Varicose Veins/diagnosis”[Majr] OR “Venous Insufficiency/diagnosis”[Majr] OR “Venous Thromboembolism/diagnosis”[Majr] OR “May-Thurner Syndrome/diagnosis”[Majr] OR “Thrombophlebitis/diagnosis”[Majr] OR “Phlebography”[Mesh] OR “Ultrasonography”[Mesh] OR “Veins/ultrasonography”[Mesh] OR “Varicose Veins/ultrasonography”[Mesh] OR “Diagnostic Techniques and Procedures”[Mesh] OR phlebography[tiab] OR venography[tiab] OR “D-Dimer”[tiab] OR “villalta”[tiab] OR diagnosis[tiab] OR diagnostic[tiab]
#3 | “Sensitivity and Specificity”[Mesh] OR “Diagnostic Errors”[Mesh] OR sensitivityf[tiab] OR specificity[tiab] OR accuracy[tiab] OR “positive predictive value”[tiab] OR “negative predictive value”[tiab] OR “likelihood ratio”[tiab] OR (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR “evaluation studies”[pt] OR “evaluation studies as topic”[MeSH] OR “evaluation study”[tiab] OR evaluation studies[tiab] OR “intervention studies”[MeSH] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “case-control studies”[MeSH] OR “case-control”[tiab] OR “cohort studies”[MeSH] OR cohort[tiab] OR “longitudinal studies”[MeSH] OR “longitudinal”[tiab] OR longitudinally[tiab] OR ”prospective“[tiab] OR prospectively[tiab] OR ”retrospective studies“[MeSH] OR ”retrospective“[tiab] OR ”Cross-Sectional Studies“[Mesh] OR cross-sectional[tiab] OR ”comparative study“[pt] OR ”comparative study“[tiab] OR systematic[sb] OR ”meta-analysis“[pt] OR ”meta-analysis as topic“[MeSH] OR ”meta-analysis“[tiab] OR ”meta-analyses“[tiab]) NOT (Editorial[ptyp] OR Letter[pt] OR Case Reports[pt] OR Comment[pt]) NOT (animals[mh] NOT humans[mh]) AND English[la]
#4 | #1 AND #2 AND #3
#5 | #4, Limit: Publication Date from 2000/01/01 – present

KQs 2-3:

#1 | “Varicose Veins”[Mesh] OR “Venous Insufficiency”[Mesh] OR “Venous Thromboembolism”[Mesh] OR “May-Thurner Syndrome”[Mesh] OR “Thrombophlebitis”[Mesh] OR “varicose vein”[tiab] OR “varicose veins”[tiab] OR varicosity[tiab] OR “venous ulcer”[tiab] OR “vein ulcer”[tiab] OR “varicose ulcer”[tiab] OR “venous ulcers”[tiab] OR “vein ulcers”[tiab] OR “varicose ulcers”[tiab] OR “stasis dermatitis”[tiab] OR “venous stasis”[tiab] OR “vein insufficiency”[tiab] OR “venous insufficiency”[tiab] OR “vein incompetence”[tiab] OR “venous incompetence”[tiab] OR “vein reflux”[tiab] OR “venous reflux”[tiab] OR “post-thrombotic syndrome”[tiab] OR “postthrombotic syndrome”[tiab] OR “venous obstruction”[tiab] OR “vein obstruction”[tiab] OR thrombophlebitis[tiab] OR “venous outflow disease”[tiab] OR “venous outflow obstruction”[tiabl OR “impaired venous outflow”[tiabl OR “post phlebitis”[tiabl OR “post phlebitic”[tiab] OR postphlebitic[tiab] OR postphlebitis[tiab] OR “post thrombotic”[tiab] OR postthrombosis[tiab] OR postthrombotic[tiab] OR “post thrombosis”[tiab] OR “chronic venous thrombosis”[tiab] OR “chronic vein thrombosis”[tiab] OR “May-Thurner Syndrome”[tiab] OR ((“Venous Thrombosis”[Mesh] OR “deep vein thrombosis”[tiab] OR “venous thrombosis”[tiab] OR dvt[tiab]) AND chronic[tiab])
#2 | “Varicose Veins/prevention and control”[Majr] OR “Varicose Veins/therapy”[Majr] OR “Venous Insufficiency/prevention and control”[Majr] OR “Venous Insufficiency/therapy”[Majr] OR “Venous Thromboembolism/therapy”[Majr] OR “Venous Thromboembolism/prevention and control”[Majr] OR “May-Thurner Syndrome/prevention and control”[Majr] OR “May-Thurner Syndrome/therapy”[Majr] OR “Thrombophlebitis/therapy”[Majr] OR “Thrombophlebitis/prevention and control”[Majr] OR “Anticoagulants”[Mesh] OR “Anticoagulants” [Pharmacological Action] OR “Diuretics”[Mesh] OR “Diuretics” [Pharmacological Action] OR “Platelet Aggregation Inhibitors”[Mesh] OR “Platelet Aggregation Inhibitors”[Pharmacological Action] OR “prasugrel”[Supplementary Concept] OR “Ticagrelor”[Supplementary Concept] OR “Prostaglandins l”[Mesh] OR “Sclerotherapy”[Mesh] OR “Sclerosing Solutions”[Mesh] OR “Stockings, Compression”[Mesh] OR “Intermittent Pneumatic Compression Devices”[Mesh] OR “Laser Therapy”[Mesh] OR “Catheter Ablation”[Mesh] OR “Ablation Techniques”[Mesh] OR “Vena Cava Filters”[Mesh] OR “Stents”[Mesh] OR “Tissue Plasminogen Activator”[Mesh] OR “Streptokinase”[Mesh] OR “Urokinase-Type Plasminogen Activator”[Mesh] OR “Mechanical Thrombolysis”[Mesh] OR “Bandages”[Mesh] OR “Pressure”[Mesh] OR “Wounds and Injuries/therapy”[Mesh] OR “Negative-Pressure Wound Therapy”[Mesh] OR “Skin Care”[Mesh] OR “Exercise”[Mesh] OR “Exercise Therapy”[Mesh] OR “Ligation”[Mesh] OR “Angioplasty”[Mesh] OR “Zinc Sulfate”[Mesh] OR “Hyperbaric Oxygenation”[Mesh] OR “Weight Loss”[Mesh] OR “Nutrition Therapy”[Mesh] OR “Smoking Cessation”[Mesh] OR “Ultrasonography”[Mesh] OR anticoagulants[tiab] OR Apixaban[tiab] OR Coumadin[tiab] OR dabigatran[tiab] OR edoxaban[tiab] OR Eliquis[tiab] OR Jantoven[tiab] OR Lixiana[tiab] OR Marevan[tiab] OR Pradaxa[tiab] OR Prazaxa[tiab] OR rivaroxaban[tiab] OR Savaysaftiab] OR warfarin[tiab] OR Xarelto[tiab] OR coumarol[tiab] OR phenocoumarol[tiab] OR diuretics[tiab] OR Aldactone[tiab] OR amiloride[tiab] OR Aquatensen[tiab] OR bendroflumethiazide[tiab] OR bumetanide[tiab] OR Bumex[tiab] OR chlorothiazide[tiab] OR chlorthalidone[tiab] OR Demadex[tiab] OR Diuril[tiab] OR Dyrenium[tiab] OR Edecrin[tiab] OR Enduron[tiab] OR Esidrix[tiab] OR “ethacrynic acid”[tiab] OR furosemide[tiab] OR hydrochlorothiazide[tiab] OR HydroDIURIL[tiab] OR hydroflumethiazide[tiab] OR Hygroton[tiab] OR Lasix[tiab] OR Metahydrin[tiab] OR methyclothiazide[tiab] OR metolazone[tiab] OR Microzide[tiab] OR Midamor[tiab] OR Mykrox[tiab] OR Naqua[tiab] OR Naturetin[tiab] OR Oretic[tiab] OR Saluron[tiab] OR spironolactone[tiab] OR Thalitone[tiab] OR torsemide[tiab] OR triamterene[tiab] OR Trichlorex[tiab] OR trichlormethiazide[tiab] OR Zaroxolyn[tiab] OR antiplatelets[tiab] OR “platelet aggregation inhibitors”[tiab] OR Aspirin[tiab] OR Agrylin[tiab] OR anagrelide[tiab] OR Brilinta[tiab] OR cilostazol[tiab] OR clopidogrel[tiab] OR dipyridamole[tiab] OR Effient[tiab] OR Pentoxifylline[tiab] OR pentoxil[tiab] OR Persantine[tiab] OR Plavix[tiab] OR Pletal[tiab] OR prasugrel[tiab] OR ticagrelor[tiab] OR Ticlid[tiab] OR ticlopidine[tiab] OR trental[tiab] OR vorapaxar[tiab] OR Zontivity[tiab] OR epoprostenol[tiab] OR prostacyclins[tiab] OR “prostaglandins 1”[tiab] OR “prostaglandins l”[tiab] OR sclerotherapy[tiab] OR Asclera[tiab] OR Aethoxysklerol[tiab] OR “chromated glycerin”[tiab] OR Cyanoacrylate[tiab] OR Dermabond[tiab] OR polidocanol[tiab] OR Scleremo[tiab] OR Sclerodex[tiab] OR “sodium chloride”[tiab] OR “sodium tetradecyl sulfate”[tiab] OR Sotradecol[tiab] OR Varisolve[tiab] OR Varithena[tiab] OR compression[tiab] OR Flexitouch[tiab] OR CircuFlow[tiab] OR BioCryo[tiab] OR Flowtron[tiab] OR VPulse[tiab] OR “laser ablation”[tiab] OR VenaCure[tiab] OR “Pro V Laser”[tiab] OR CoolTouch[tiab] OR ELVes[tiab] OR “Lumenis Sharplan”[tiab] OR Medilas[tiab] OR “catheter ablation”[tiab] OR “closure catheter”[tiab] OR venefit[tiab] OR (“vena cava”[tiab] AND (filter[tiab] OR filters[tiab])) OR stenting[tiab] OR stent[tiab] OR stents[tiab] OR activase[tiab] OR alteplase[tiab] OR kinlytic[tiab] OR streptase[tiab] OR streptokinase[tiab] OR “tissue plasminogen activator”[tiab] OR urokinase[tiab] OR “mechanical thrombectomy”[tiab] OR ekosonic[tiab] OR trerotola[tiab] OR amplatzer[tiab] OR trellis[tiab] OR angiojet[tiab] OR penumbra[tiab] OR Exercise[tiab] OR “physical therapy”[tiab] OR “zinc sulfate”[tiab] OR “elastic stockings”[tiab] OR bandage[tiab] OR bandages[tiab] OR bandaged[tiab] OR “pressure”[tiab] OR “wound therapy”[tiab] OR “skin care”[tiab] OR (leg[tiab] AND elevat*[tiab]) OR ablation[tiab] OR phlebectomy[tiab] OR ligation[tiab] OR excision[tiab] OR ((hyperbaric[tiab] OR “high pressure”[tiab] OR “high tension”[tiab]) AND (oxygen[tiab] OR oxygenation[tiab])) OR HBO[tiab] OR HBOT[tiab] OR HBO2[tiab] OR HBO2T[tiab] OR “hyperbaric chamber”[tiab] OR “hyperbaric chambers”[tiab] OR boots[tiab] OR “wound vac”[tiab] OR “wound vacuum”[tiab] OR angioplasty[tiab] OR “weight loss”[tiab] OR diet[tiab] OR smoking[tiab] OR tobacco[tiab] OR ultrasound[tiab] OR thromboembolectomy[tiab]
#3 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR “evaluation studies”[pt] OR “evaluation studies as topic”[MeSH] OR “evaluation study”[tiab] OR evaluation studies[tiab] OR “intervention studies”[MeSH] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “case- control studies”[MeSH] OR “case-control”[tiab] OR “cohort studies”[MeSH] OR cohort[tiab] OR “longitudinal studies”[MeSH] OR “longitudinal”[tiab] OR longitudinally[tiab] OR ”prospective“[tiab] OR prospectively[tiab] OR ”retrospective studies“[MeSH] OR ”retrospective“[tiab] OR ”follow up“[tiab] OR ”comparative study“[pt] OR ”comparative study“[tiab] OR systematic[subset] OR ”meta-analysis“[pt] OR ”meta-analysis as topic“[MeSH] OR ”meta-analysis“[tiab] OR ”meta-analyses“[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh]) AND English[la]
#4 | #1 AND #2 AND #3
#5 | #4, Limit: Publication Date from 2000/01/01 – present

## Embase^®^ search strategy (June 30, 2016)

Platform: Embase.com

KQ 1:

#1 | ‘varicosis’/de OR ‘leg varicosis’/exp OR ‘spider vein’/exp OR ‘vein insufficiency’/exp OR ‘venous thromboembolism’/de OR ‘lower extremity deep vein thrombosis’/exp OR ‘thrombophlebltis’/exp OR ‘leg thrombophlebitis’/exp OR ‘postthrombosis syndrome’/exp OR “varicose vein”:ab,ti OR “varicose velns”:ab,ti OR varicosity:ab,ti OR “venous ulcer”:ab,ti OR “vein ulcer”:ab,ti OR “varicose ulcer”:ab,ti OR “venous ulcers”:ab,ti OR “vein ulcers”:ab,ti OR “varicose ulcers”:ab,ti OR “stasis dermatitis”:ab,ti OR “venous stasis”:ab,ti OR “vein insufficiency”:ab,ti OR “venous insufficiency”:ab,ti OR “vein incompetence”:ab,ti OR “venous Incompetence”:ab,ti OR “vein reflux”:ab,ti OR “venous reflux”:ab,ti OR “post thrombotic syndrome”:ab,ti OR “postthrombotic syndrome”:ab,ti OR “venous obstruction”:ab,ti OR “vein obstructlon”:ab,ti OR thrombophlebitis:ab,ti OR “venous outflow disease”:ab,ti OR “venous outflow obstructlon”:ab,ti OR “impaired venous outflow”:ab,ti OR “post phlebitis”:ab,ti OR “post phlebitic”:ab,ti OR postphlebitic:ab,ti OR postphlebitis:ab,ti OR “post thrombotic”:ab,ti OR postthrombosis:ab,ti OR postthrombotic:ab,ti OR “post thrombosis”:ab,ti OR “chronic venous thrombosis”:ab,ti OR “chronic vein thrombosis”:ab,ti OR “May Thurner Syndrome”:ab,ti OR ((‘deep vein thrombosis’/exp OR “deep vein thrombosis”:ab,ti OR “venous thrombosis”:ab,ti OR dvt:ab,ti) AND chronic:ab,ti)
#2 | ‘varicosis’/exp/mj/dm_di OR ‘vein insufficiency’/exp/mj/dm_di OR ‘venous thromboembollsm’/de/mj/dm_di OR ‘lower extremity deep vein thrombosis’/exp/mj/dm_di OR ‘leg thrombophlebitis’/exp/mj/dm_di OR ‘postthrombosis syndrome’/exp/mj/dm_di OR ‘phlebography’/exp OR ‘echography’/de OR ‘D dimer’/exp OR phlebography:ab,ti OR venography:ab,ti OR "D Dimer":ab,ti OR "villalta":ab,ti OR diagnosis:ab,ti OR diagnostic:ab,ti
#3 | (‘sensitivity and specificity’/exp OR ‘predictive value’/exp OR ‘diagnostic error’/exp OR sensltlvlty:ab,ti OR specificity:ab,ti OR accuracy:ab,ti OR misdiagnos*:ab,ti OR ‘predictive value’:ab,ti OR ‘likelihood ratio’:ab,ti OR ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘cross-sectional study’/exp OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysls’/exp OR cohort:ab,ti OR “cross sectional”:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp OR ‘conference abstract’/exp)
#4 | #1 AND #2 AND #3
#5 | #4 AND [embase]/lim NOT [medilne]/lim AND [humans]/lim AND [engllsh]/lim
#6 | #5 AND [2000-2016]/py

KQs 2-3:

#1 | ‘varicosis’/de OR ‘leg varicosis’/exp OR ‘spider vein’/exp OR ‘vein insufficiency’/exp OR ‘venous thromboembolism’/de OR ‘lower extremity deep vein thrombosis’/exp OR ‘thrombophlebitis’/exp OR ‘leg thrombophlebitis’/exp OR ‘postthrombosis syndrome’/exp OR “varicose vein”:ab,ti OR “varicose veins”:ab,ti OR varicosity:ab,ti OR “venous ulcer”:ab,ti OR “vein ulcer”:ab,ti OR “varicose ulcer”:ab,ti OR “venous ulcers”:ab,ti OR “vein ulcers”:ab,ti OR “varicose ulcers”:ab,ti OR “stasis dermatitis”:ab,ti OR “venous stasis”:ab,ti OR “vein insufficiency”:ab,ti OR “venous Insufficiency”:ab,ti OR “vein incompetence”:ab,ti OR “venous Incompetence”:ab,ti OR “vein reflux”:ab,ti OR “venous reflux”:ab,ti OR “post thrombotic syndrome”:ab,ti OR “postthrombotic syndrome”:ab,ti OR “venous obstruction”:ab,ti OR “vein obstructlon”:ab,ti OR thrombophlebitis:ab,ti OR “venous outflow disease”:ab,ti OR “venous outflow obstruction”:ab,ti OR “Impaired venous outflow”:ab,ti OR “post phlebitis”:ab,ti OR “post phlebitic”:ab,ti OR postphlebitic:ab,ti OR postphlebitis:ab,ti OR “post thrombotic”:ab,ti OR postthrombosis:ab,ti OR postthrombotic:ab,ti OR “post thrombosis”:ab,ti OR “chronic venous thrombosis”:ab,ti OR “chronic vein thrombosis”:ab,ti OR “May Thurner Syndrome”:ab,ti OR ((‘deep vein thrombosis’/exp OR “deep vein thrombosis”:ab,ti OR “venous thrombosis”:ab,ti OR dvt:ab,ti) AND chronic:ab,ti)
#2 | ‘varicosis’/exp/mj/dm_dt,dm_su,dm_th,dm_rh,dm_rt,dm_dm,dm_pc OR ‘vein insufficiency’/exp/mj/dm_dt,dm_su,dm_th,dm_rh,dm_rt,dm_dm,dm_pc OR ‘venous thromboembolism’/mj/dm_dt,dm_su,dm_th,dm_rh,dm_rt,dm_dm,dm_pc OR ‘lower extremity deep vein thrombosis’/exp/mj/dm_dt,dm_su,dm_th,dm_rh,dm_rt,dm_dm,dm_pc OR ‘thrombophlebitis’/exp/mj/dm_dt,dm_su,dm_th,dm_rh,dm_rt,dm_dm,dm_pc OR ‘leg thrombophlebitis’/exp/mj/dm_dt,dm_su,dm_th,dm_rh,dm_rt,dm_dm,dm_pc OR ‘postthrombosis syndrome7exp/mj/dm_dt,dm_su,dm_th,dm_rh,dm_rt,dm_dm,dm_pc OR ’anticoagulant agent‘/exp OR ’diuretic agent‘/exp OR ’antithrombocytic agent‘/exp OR ’prasugrel‘/exp OR ’tlcagrelor‘/exp OR ’prostaglandin‘/exp OR ’sclerotherapy‘/exp OR ’sclerosing agent‘/exp OR ’compression stocking‘/exp OR ’Intermittent pneumatic compression devlce‘/exp OR ’low level laser therapy‘/exp OR ’ablation catheter‘/exp OR ’ablation therapy‘/exp OR ’vena cava filter‘/exp OR ’stent‘/exp OR ’tissue plasminogen activator‘/exp OR ’streptokinase‘/exp OR ’urokinase‘/exp OR ’mechanical thrombectomy‘/exp OR ’bandages and dressings‘/exp OR ’pressure‘/exp OR ’wound care‘/exp OR ’skin care‘/exp OR ’exercise‘/exp OR ’kinesiotherapy‘/exp OR ’ligation‘/exp OR ’angioplasty‘/exp OR ’zinc sulfate‘/exp OR ’hyperbaric oxygen‘/exp OR ’weight reduction‘/exp OR ’diet therapy‘/exp OR ’smoking cessation‘/exp OR ’echography‘/exp OR ’catheter‘/exp OR anticoagulants:ab,ti OR Apixaban:ab,ti OR Coumadin:ab,ti OR dabigatran:ab,ti OR edoxaban:ab,ti OR Eliquis:ab,ti OR Jantoven:ab,ti OR Lixiana:ab,ti OR Marevan:ab,ti OR Pradaxa:ab,ti OR Prazaxa:ab,ti OR rivaroxaban:ab,ti OR Savaysa:ab,ti OR warfarin:ab,ti OR Xarelto:ab,ti OR coumarol:ab,ti OR phenocoumarol:ab,ti OR diuretics:ab,ti OR Aldactone:ab,ti OR amllorlde:ab,ti OR Aquatensen:ab,ti OR bendroflumethiazide:ab,ti OR bumetanide:ab,ti OR Bumex:ab,ti OR chlorothiazide:ab,ti OR chlorthalidone:ab,ti OR Demadex:ab,ti OR Diuril:ab,ti OR Dyrenium:ab,ti OR Edecrin:ab,ti OR Enduron:ab,ti OR Esidrix:ab,ti OR “ethacrynic acid”:ab,ti OR furosemide:ab,ti OR hydrochlorothiazide:ab,ti OR HydroDIURIL:ab,ti OR hydroflumethiazide:ab,ti OR Hygroton:ab,ti OR Lasix:ab,ti OR Metahydrin:ab,ti OR methyclothiazide:ab,ti OR metolazone:ab,ti OR Microzide:ab,ti OR Midamor:ab,ti OR Mykrox:ab,ti OR Naqua:ab,ti OR Naturetin:ab,ti OR Oretic:ab,ti OR Saluron:ab,ti OR spironolactone:ab,ti OR Thalitone:ab,ti OR torsemide:ab,ti OR triamterene:ab,ti OR Trichlorex:ab,ti OR trichlormethlazide:ab,ti OR Zaroxolyn:ab,ti OR antiplatelets:ab,ti OR “platelet aggregation inhibitors”:ab,ti OR Aspirin:ab,ti OR Agrylin:ab,ti OR anagrelide:ab,ti OR Brilinta:ab,ti OR cilostazol:ab,ti OR clopidogrel:ab,ti OR dipyridamole:ab,ti OR Effient:ab,ti OR Pentoxifylline:ab,ti OR pentoxil:ab,ti OR Persantine:ab,ti OR Plavix:ab,ti OR Pletal:ab,ti OR prasugrel:ab,ti OR ticagrelor:ab,ti OR Ticlid:ab,ti OR ticlopidine:ab,ti OR trental:ab,ti OR vorapaxar:ab,ti OR Zontivity:ab,ti OR epoprostenol:ab,ti OR prostacyclins:ab,ti OR “prostaglandins 1 ”:ab,ti OR prostaglandins:ab,ti OR sclerotherapy:ab,ti OR Asclera:ab,ti OR Aethoxysklerol:ab,ti OR “chromated glycerin”:ab,ti OR Cyanoacrylate:ab,ti OR Dermabond:ab,ti OR polidocanol:ab,ti OR Scleremo:ab,ti OR Sclerodex:ab,ti OR “sodium chloride”:ab,ti OR “sodium tetradecyl sulfate”:ab,ti OR Sotradecol:ab,ti OR Varisolve:ab,ti OR Varithena:ab,ti OR compression:ab,ti OR Flexitouch:ab,ti OR CircuFlow:ab,ti OR BioCryo:ab,ti OR Flowtron:ab,ti OR VPulse:ab,ti OR “laser ablation”:ab,ti OR VenaCure:ab,ti OR “Pro V Laser”:ab,ti OR CoolTouch:ab,ti OR ELVes:ab,ti OR “Lumenis Sharplan”:ab,ti OR Medilas:ab,ti OR “catheter ablation”:ab,ti OR “closure catheter”:ab,ti OR venefit:ab,ti OR (“vena cava”:ab,ti AND (filter:ab,ti OR filters:ab,ti)) OR stenting:ab,ti OR stent:ab,ti OR stents:ab,ti OR activase:ab,ti OR alteplase:ab,ti OR kinlytlc:ab,ti OR streptase:ab,ti OR streptokinase:ab,ti OR “tissue plasminogen activator”:ab,ti OR urokinase:ab,ti OR “mechanical thrombectomy”:ab,ti OR ekosonlc:ab,ti OR trerotola:ab,ti OR amplatzer:ab,ti OR trellis:ab,ti OR angiojet:ab,ti OR penumbra:ab,ti OR Exercise:ab,ti OR “physical therapy”:ab,ti OR “zinc sulfate”:ab,ti OR “elastic stockings”:ab,ti OR bandage:ab,ti OR bandages:ab,ti OR bandaged:ab,ti OR “pressure”:ab,ti OR “wound therapy”:ab,ti OR “skin care”:ab,ti OR (leg:ab,ti AND elevat*:ab,ti) OR ablation:ab,ti OR phlebectomy:ab,ti OR ligation:ab,ti OR excision:ab,ti OR ((hyperbaric:ab,ti OR “high pressure”:ab,ti OR “high tension”:ab,ti) AND (oxygen:ab,ti OR oxygenation:ab,ti)) OR HBO:ab,ti OR HBOT:ab,ti OR HBO2:ab,ti OR HBO2T:ab,ti OR “hyperbaric chamber”:ab,ti OR “hyperbaric chambers”:ab,ti OR boots:ab,ti OR “wound vac”:ab,ti OR “wound vacuum”:ab,ti OR angioplasty:ab,ti OR “weight loss”:ab,ti OR diet:ab,ti OR smoking:ab,ti OR tobacco:ab,ti OR ultrasound:ab,ti OR thromboembolectomy:ab,ti
#3 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorlal*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘Intervention study’:ab,ti OR ‘Intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp OR ‘conference abstract’/exp)
#4 | #1 AND #2 AND #3
#5 | #4 AND [embase]/lim NOT [medline]/lim AND [humans]/lim AND [english]/lim
#6 | #5 AND [2000-2016]/py

## Cochrane search strategy (June 30, 2016)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews

#1 | [mh “varicose veins”] or [mh “venous insufficiency”] or [mh “venous thromboembolism”] or [mh “may thurner syndrome”] or [mh thrombophlebitis]
#2 | “Varicose Veins”:ab,ti,kw or “varicosity”:ab,ti,kw or “venous ulcer”:ab,ti,kw or “vein ulcer”:ab,ti,kw or “varicose ulcer”:ab,ti,kw or “venous ulcers”:ab,ti,kw or “vein ulcers”:ab,ti,kw or “varicose ulcers”:ab,ti,kw or “stasis dermatitis”:ab,ti,kw or “venous stasis”:ab,ti,kw or “vein insufficiency”:ab,ti,kw or “venous insufficiency”:ab,ti,kw or “vein incompetence”:ab,ti,kw or “venous incompetence”:ab,ti,kw or “vein reflux”:ab,ti,kw or “venous reflux”:ab,ti,kw or “post-thrombotic syndrome”:ab,ti,kw or “postthrombotic syndrome”:ab,ti,kw or “venous obstruction”:ab,ti,kw or “vein obstruction”:ab,ti,kw or thrombophlebitis:ab,ti,kw or “venous outflow disease”:ab,ti,kw or “venous outflow obstruction”:ab,ti,kw or “impaired venous outflow”:ab,ti,kw or “post phlebitis”:ab,ti,kw or “post phlebitic”:ab,ti,kw or postphlebitic:ab,ti,kw or postphlebitis:ab,ti,kw or “post thrombotic”:ab,ti,kw or postthrombosis:ab,ti,kw or postthrombotic:ab,ti,kw or “post thrombosis”:ab,ti,kw or “chronic venous thrombosis”:ab,ti,kw or “chronic vein thrombosis”:ab,ti,kw or “chronic deep vein thrombosis”:ab,ti,kw or “chronic dvt”:ab,ti,kw or “May- Thurner Syndrome”:ab,ti,kw
#3 | [mh “venous thrombosis”]
#4 | chronic:ab,ti,kw
#5 | #3 AND #4
#6 | #1 OR #2 OR #5
#7 | #6, Limits: 2000/01/01 and Cochrane Reviews

## Gray Literature Searches

ClinicalTrials.gov (September 26, 2016)

Conditions | varicose veins OR venous insufficiency OR venous thromboembolism OR may-thurner OR thrombophlebitis OR deep vein thrombosis OR peripheral venous disease
Recruitment | Completed studies
Study Results | All studies
Study type | interventional studies
Age group | Adult (18–65), Senior (66+)
Phase | Phase 2, Phase 3, Phase 4

Total number of results: 285

### WHO: International Clinical Trials Registry Platform Search Portal (September 26, 2016)

Title: venous disease

OR

Condition: venous disease

Recruiting status: All

Total number of results: 37 records for 31 trials

### National Guidelines Clearinghouse (September 26, 2016)

Platform: www.guideline.gov

Keyword | venous disease AND extremity
Clinical Specialty | Cardiology, Internal Medicine, Surgery (For the original search, these terms were searched in an OR combination. Due to a change in the database format that no longer allowed OR functionality, the Sep 2016 update searches were performed individually.)

Total number of results: 94