# Results

## Results of Literature Searches

Figure 2 shows the process of reducing our initial list of 6,022 potentially relevant publications to a final included set of 40 publications. We excluded 2,647 publications at the title level (as not relevant to the topic), and another 2,771 at the abstract level. The most common reasons for exclusion at the abstract level were wrong population (1,112 exclusions) and a lack of psychometric property data in studies being considered for Key Question [KQ]1B or KQ1C (890 exclusions). We examined 603 articles in full, and excluded 565 of these for various reasons, the most common being wrong or unclear population (225 exclusions) and no psychometric data (120 exclusions). A complete list of articles excluded at the full-text level appears in Appendix B. Two included articles were identified by peer reviewers.

Figure 2 Study attrition diagram

* The numbers do not add to 21 because some studies contributed to multiple KQs

** The number of full length studies reviewed does not include the 2 studies identified by peer reviewers

KQ=key question, RP=retinitis pigmentosa, RPS=retinal prosthesis system

Figure 2 shows the counts of articles at various stages of searching. The box at the top stated that searches identified 6,021 articles that were potentially relevant. Title screening for relevance excluded 2,647 of these. Screening of the abstracts excluded 2,771 more, for many different reasons, which are listed in the upper right box. The most common reason was that the article was not a low vision retinal degenerative population (1,112 articles). Other reasons included no psychometric data reported (890 articles), not a relevant RPS (387 articles), no patient-centered outcomes (134 articles), narrative reviews (124 articles), technical reports without human data (102 articles), other (11 articles), editorials (7 articles), cost studies (3 articles), and published before 2000 (1 article). We then reviewed 603 full articles, and 565 of these were excluded for various reasons, listed in the box on the lower right. The most common reason for exclusion at the full article level was Either <67% of the patients had low vision retinal degenerative conditions, or it was unclear whether patients had low vision retinal degenerative conditions (225 articles), no psychometric data reported (120 articles), not a relevant RPS (69 articles), no patient-centered outcomes (50 articles), narrative reviews (40 articles), other reasons such as duplicate data (27 articles), editorials (18 articles) and technical reports without human data (16 articles). We included a total of 40 publications reporting 21 unique studies.

The 40 included publications described 21 unique studies. Per KQ, we included:

- Eleven studies included for KQ1A (outcomes reported in retinal prosthesis system [RPS] studies)
- Four studies included for KQ1B (psychometric properties of outcomes reported in RPS studies)
- Nine studies included for KQ1C (psychometric properties of other possible outcomes of low-vision treatment)
- Eleven studies included for KQ2 (effectiveness of RPS)
- Three studies included for KQ3 (arrest progression of retinitis pigmentosa [RP] with RPS)
- Ten studies included for KQ4 (adverse events of RPS)
- No studies included for KQ5 (off-label use and other uses of RPS)

(These numbers do not add to 21 because some studies contributed data to multiple KQs.) The remainder of the Results section summarizes the evidence separately for each of the KQs.

## Key Question 1A Outcome Measures Used in RPS Studies

### Description of Included Studies

For KQ1A we included 30 publications of 11 RPS studies:

- Alpha IMS study by Stingl et al., reported in 2013 and 2015^63,64^
- Alpha IMS study by Zrenner et al. 2011^14^
- Argus II study by Arevalo et al. 2015^65,66^
- Argus II study by Ho et al. 2015, also reported by other authors^15,30,67-76^
- Argus II study by Seider and Hahn 2015^77^
- Argus II study by Rizzo et al. 2014^78^
- Artificial Silicon Retina (ASR) study by Chow et al. 2004 and Khan et al. 2015^22,79^
- Artificial Silicon Retina (ASR) extension study by Chow et al. 2010, also reported by Geruschat et al. 2012^80,81^
- Bionic Vision study by Ayton et al. 2014^18^
- EPIRET3 study by Klauke et al. 2011 and also reported by other authors^82-86^
- Suprachoroidal Transretinal Stimulation (STS) study by Fujikado et al. 2011^23^

Both Alpha IMS studies were conducted in Germany; the four Argus II studies were conducted in the United States, Europe, and Saudi Arabia; the two ASR studies were conducted in the United States; the Bionic Vision study was conducted in Australia; the EPIRET3 study was conducted in Germany; and the STS study was conducted in Japan.

The studies were all small, with enrollments ranging from 1 to 30 patients (the median was 6 patients per study). Study durations ranged from 7 weeks to 10 years. Mean patient age at implantation ranged from 40.7 to 69.5 years, and more than half of the patients were male (median 67 percent among the 10 studies reporting the sex distribution). For more information, including other patient characteristics, intervention details, comparators, and outcome data, see tables in Appendix C. This KQ focuses on types of outcome metrics used in these 11 studies.

### Key Points

- The 30 publications reported 74 different outcomes. Most outcomes involved either visual function (31 percent), visual acuity (26 percent), or laboratory-based visual performance measures (30 percent). Four studies measured day-to-day visual function, and one study measured vision-specific quality of life.
- Only three outcomes were reported by three or more studies: the percentage of patients who passed the light localization task of the Basic Assessment of Light and Motion (BaLM), the percentage of patients whose square localization results were significantly better with system ON than system OFF, and the percentage of patients whose Grating Visual Acuity results were significantly better with system ON than system OFF. Seven other outcomes were reported by two studies each. Little consensus exists among authors of RPS studies about which specific measures are important.

### Detailed Synthesis

Table 4 below shows the 74 types of outcomes reported by the 11 studies. We categorized outcomes as follows:

- Visual function: 23 outcomes, reported by 9 studies
- Visual acuity: 19 outcomes, reported by 9 studies
- Visual field: 4 outcomes, reported by 2 studies
- Color vision: 1 outcome, reported by a single study
- Laboratory-based visual performance measures: 22 outcomes, reported by 6 studies
- Day-to-day function: 4 outcomes, reported by 4 studies
- Quality of life: 1 outcome reported by a single study

Table 4 Outcomes reported in included retinal prosthesis system studies

Category | Outcome | Alpha IMS study by Stingl et al. 2013 and 2015^63,64^ | Alpha IMS study by Zrenner et al. 2011^14^ | Argus II study by Ho et al. 2015 and other authors^15,30,67-75^ | Argus II study by Seider and Hahn 2015^77^ | Argus II study by Rizzo et al. 2014^78^ | Argus II study by Arevalo et al. 2015^65,66^ | Artificial Silicon Retina (ASR) study by Chow et al. 2004 and Kahn et al. 2015^22,79^ | Artificial Silicon Retina (ASR) extension study by Chow et al. 2010 and Geruschat et al. 2012^80,81^ | Bionic Vision study by Ayton et al. 2014^18^ | EPIRET3 study by Klauke et al. 2011 and other authors^82-86^ | Suprachoroidal transretinal stimulation (STS) study by Fujikado et al. 2011^23^
Visual function | Ability to differentiate spatiotemporal patterns | | | | | | | | | | ✓
Visual function | Ability to perceive 2 distinct phosphenes better than chance when stimuli were delivered through 2 channels | | | | | | | | | | | ✓
Visual function | Ability to perceive phosphenes at all | | | | | | | | | | | ✓
Visual function | Ability to see any light | ✓
Visual function | BaLM, light localization, % passing the test | ✓ | ✓ | | | | | | | ✓
Visual function | BaLM, light perception, % passing the test | ✓ | ✓
Visual function | BaLM, movement,% passing the test | ✓ | ✓
Visual function | Direction of motion test, number of correct responses | | | | ✓ | ✓
Visual function | Direction of motion test, % of subjects whose system ON results were better than system OFF | | | ✓ | | | ✓
Visual function | False-positive responses to stimulation | | | | | | | | | | ✓
Visual function | Grid detection, % passing the test | | ✓
Visual function | Motion direction test, better than chance | | | | | | | | | | | ✓
Visual function | Object detection with head scanning better than chance | | | | | | | | | | | ✓
Visual function | Object discrimination with head scanning better than chance | | | | | | | | | | | ✓
Visual function | Pattern U in 4 directions, % passing the test | | ✓
Visual function | Positive response to first stimulation pulses | | | | | | | | | | ✓
Visual function | Reliable phosphene precepts | | | | | | | | | ✓
Visual function | Seeing visual percepts at all | | | | | | | | | | ✓
Visual function | Seeing visual percepts in all sessions | | | | | | | | | | ✓
Visual function | Single pulse oblique line, % passing the test | | ✓
Visual function | Single pulse, row of 4 electrodes, % passing the test | | ✓
Visual function | Square localization, mean distance from target center | | | | | ✓
Visual function | Square localization: % of subjects whose system ON results were significantly better than system OFF | | | ✓ | ✓ | | ✓
Visual acuity | ETDRS, logMAR average | | | | | | | | ✓
Visual acuity | ETDRS, logMAR, % who improved | | | | | | | | ✓
Visual acuity | ETDRS: number of letters seen by each eye | | | | | | | ✓
Visual acuity | GAT, logMAR, average | | | | | | | | ✓
Visual acuity | GAT, logMAR. % who improved | | | | | | | | ✓
Visual acuity | GAT, % of subjects whose system ON results were better than system OFF | ✓ | | | ✓ | ✓ | ✓
Visual acuity | Grating visual acuity: % of subjects who scored between 2.9 and 1.6 logMAR with the system ON | | | ✓
Visual acuity | Landolt C rings, LogMAR | | | | | | | | | ✓
Visual acuity | Landolt C rings, % passing the test | ✓ | ✓
Visual acuity | Letter recognition, mean seconds for correctly identified letters | | | ✓
Visual acuity | Letter recognition, % correct | | | ✓
Visual acuity | Letter size reduction test, total number of letters identified correctly | | | ✓
Visual acuity | Multiple letters, % passing the test | | ✓
Visual acuity | Reading letters, % passing the test | ✓
Visual acuity | Seeing optotypes at all | | | | | | | | | ✓
Visual acuity | Single letter detection, % passing the test | | ✓
Visual acuity | Word recognition, number of 4-letter words identified | | | ✓
Visual acuity | Word recognition, number of 3-letter words identified | | | ✓
Visual acuity | Word recognition, number of 2-letter words identified | | | ✓
Visual field | Central Humphrey visual field test, % who consistently positively responded | | | | | | | ✓
Visual field | Goldmann visual field test, % who improved | | | | | ✓
Visual field | Subjective visual field, % of patients who indicated perception of light sensation to infrared light in the projected visual field | | | | | | | ✓
Visual field | Visual field light threshold testing, % of patients who improved | | | | | | | ✓
Color vision | Pseudoisochromatic color plate test, % who improved | | | | | | | ✓
Laboratory-based visual performance measures | Clock task, % of patients passing the test | ✓ | ✓
Laboratory-based visual performance measures | Controlled mobility course, % who successfully completed the course | | | | | | | | ✓
Laboratory-based visual performance measures | Dining objects identification, mean score out of 4 (4 being best) | ✓
Laboratory-based visual performance measures | Dining objects localization, mean score out of 4 (4 being best) | ✓
Laboratory-based visual performance measures | Dining objects localization, % of patients passing | | ✓
Laboratory-based visual performance measures | Dining objects number, mean score out of 4 (4 being best) | ✓
Laboratory-based visual performance measures | Finding the door, % of patients successful | | | ✓
Laboratory-based visual performance measures | Following the line, % of patients successful | | | ✓
Laboratory-based visual performance measures | Geometric shape identification, mean score out of 4 (4 being best) | ✓
Laboratory-based visual performance measures | Geometric shape identification, % of patients passing | | ✓
Laboratory-based visual performance measures | Geometric shape location, mean score out of 4 (4 being best) | ✓
Laboratory-based visual performance measures | Geometric shapes number, mean score out of 4 (4 being best) | ✓
Laboratory-based visual performance measures | Grasping objects, % of patients who were better than chance | | | | | | | | | | | ✓
Laboratory-based visual performance measures | Gray levels test: % of patients passing the test | ✓ | ✓
Laboratory-based visual performance measures | Meander Maze Tracing, whether tracing errors reduced | | | ✓
Laboratory-based visual performance measures | Meander Maze Tracing, whether tracing time improved | | | ✓
Laboratory-based visual performance measures | Mobility test, % of patients successful | | | | | ✓
Laboratory-based visual performance measures | Object prehension (locate, reach and grasp), % of patients successful | | | ✓
Laboratory-based visual performance measures | Reading Braille, whether single-letter recognition was better than chance | | | ✓
Laboratory-based visual performance measures | Touch panel test, % of patients who were better with system ON than OFF | | | | | | | | | | | ✓
Laboratory-based visual performance measures | Path reproduction | | | ✓
Laboratory-based visual performance measures | Triangle path | | | ✓
Day-to-day function | FLORA | | | ✓
Day-to-day function | Patients' impression of their visual experiences in home and daily life, % reporting improvement | ✓
Day-to-day function | Patients' impression of vision improvement for specific activities (e.g., watching son play basketball), % who reported improvement | | | | | | | | ✓
Day-to-day function | Patients' impression of visual perceptions for 7 aspects of visual function (brightness, contrast, color, shape, resolution, movement, and visual field size), % who reported improvement | | | | | | | ✓
Quality of life | NEI-VFQ-25 visual-specific quality of life questionnaire | | | | | | | | | | ✓

BaLM=Basic Assessment of Light and Motion test; ETDRS=Early Treatment of Diabetic Retinopathy Study; FLORA=Functional Low-Vision Observer Rated Assessment; GAT=Grating Acuity Test; logMAR=logarithm of the minimum angle of resolution; NEI-VFQ-25=National Eye Institute Visual Function Questionnaire 25-item

Only 3 outcomes were reported by 3 or more of the 11 studies: the percentage of patients who passed the light localization task of BaLM, the percentage of patients whose square localization results were significantly better with system ON than system OFF, and the percentage of patients whose Grating Visual Acuity results were significantly better with system ON than system OFF. Seven other outcomes were reported by two studies each: (1) BaLM, light perception subtask, percentage passing the test; (2) BaLM, movement subtask, percentage passing the test; (3) Direction of motion test, percentage who performed better with the device ON than OFF; (4) Direction of motion test, number of correct responses; (5) Landolt C, percent passing the test; and (6) Clock task, percentage passing the test; and (7) Gray levels test: percentage passing the test. Thus, there is little consensus among authors of RPS studies about which specific measures are important. Once released, the Harmonization of Outcomes and Vision Endpoints in Vision Restoration (HOVER) Trials Taskforce recommendations may rectify this situation. The committee's goal is to guide the conduct of research and standardize outcome reporting in trials of patients with visual prosthetic devices.^87,88^

## Key Question 1B Psychometric Properties of Outcome Measures Used in RPS Studies

### Description of Included Studies

We included four studies of psychometric properties of the outcome metrics used in studies of RPS. The four studies investigated four metrics: Early Treatment of Diabetic Retinopathy Study (ETDRS), the Chow GAT, the Chow Color test (CCT), and the Functional Low-Vision Observer Rated Assessment (FLORA). For general information about the studies, patient characteristics, interventions, comparators, and outcome data, see Table C-4 of Appendix C. In this section as well as Key Question 1C, when we refer to the “responsiveness” of a measure, we mean whether the measure has demonstrated improvements after a treatment with known efficacy. Since the efficacy of RPS is not known (and indeed is the focus of Key Question 2), we address pre-post changes after RPS in Key Question 2.

### Key Points

- The ETDRS has acceptable test-retest reliability, but no included studies measured its validity or responsiveness.
- The GAT and the CCT have acceptable test-retest reliability and construct validity, but no included studies measured their responsiveness.
- The FLORA has acceptable face validity, but no included studies measured its reliability or responsiveness.

### Detailed Synthesis

We included evidence on the psychometric properties of four outcome measurements that have been used in RPS studies: ETDRS, FLORA, the Chow GAT, and the CCT. The psychometric properties were reported in a total of four studies.^31,80,89,90^ Evidence tables in Appendix C provide the following: general information about the studies (Table C-1), patient characteristics (Table C-2), details about the measurements (Table C-3), psychometric data (Table C-4), and risk-of-bias assessments (Table C-5). Below, we discuss the outcome measurements in separate sections.

#### Visual Acuity: Early Treatment of Diabetic Retinopathy Study (ETDRS)

The Snellen visual acuity chart is the standard chart most people associate with an eye exam and was first created in the 19th century. Despite its wide spread use even today, the visual acuity fractions are not amenable to statistical comparisons. To address this shortcoming, the ETDRS chart was developed. With standard spacing between lines and letters and with letters of equal discrimination difficulty, the chart is considered a standard measure of visual acuity for clinical trials. Results of Snellen acuity in clinical studies are typically reported on the scale of logarithm of the minimum angle of resolution (logMAR) to attempt to correct for the lack of statistical basis between different acuity lines. Normal vision is a logMAR of 0, meaning the ability to see details as small as one minute of visual acute angle (i.e., log_10_(1)=0). Legal blindness is defined as a patient with a logMAR of 1.0 or higher, and/or less than 20 degrees of visual field. A logMAR of 1.0 corresponds to 20/200 vision as measured by the classic Snellen chart.

We included two studies of the test-retest reliability of the ETDRS.^89,90^ Bittner et al.^89^ performed ETDRS under regular illumination, and we judged it at Low risk of bias. Kiser et al.^90^ performed it under both regular and dim illumination, and we judged it at Low risk of bias. Both studies reported data in terms of the coefficient of repeatability (CR_.95_). This is on the scale of logMAR, and is interpreted as how much variation can be expected from an initial value (e.g., if a patient's logMAR is 1.2 at one visit, and the test has a CR_.95_ of 0.15, then one would expect with 95 percent confidence that the next visit's logMAR will be within 0.15 of the first visit, i.e., between 1.05 and 1.35).

Bittner et al.^89^ reported median CR_.95_ values of 0.10 for patients with RP and 0.16 for patients with other retinopathies. These values are relatively low, indicating good test-retest reliability. By contrast, Kiser et al.^90^ reported somewhat higher CR_.95_ values, ranging from 0.13 to 0.26 for patients with RP, 0.21 to 0.27 for patients with macular degeneration, 0.18 for those with diabetic retinopathy, and 0.20 for those with other retinopathies. These medians are all for regular illumination; under dim illumination, the investigators^90^ generally found similar CR_.95_ values to those under regular illumination. Neither study reported additional psychometric properties of the ETDRS.

#### Visual acuity: Chow Grating Acuity Test (GAT)

The GAT was developed to be more sensitive than the ETDRS for patients with very low vision. Patients are shown a series of lines in one of four orientations: vertical, horizontal, diagonal left-right, or diagonal right-left, and asked to choose which orientation they are viewing. Results are provided on the logMAR scale for easy comparison with ETDRS results. The two studies that we included^80,89^ were each at Moderate risk of bias for both test-retest reliability and construct validity.

Results for test-retest reliability were good, with CR_.95_ values around 0.16 for patients with RP in both studies, and even better (0.11) for patients with other retinopathies in one of the studies.^89^ Both studies tested construct validity by determining the correspondence between GAT and ETDRS, and both found strong associations (e.g., a correlation of 0.92 in Chow et al. 2010),^80^ with regression slopes near 1.0. These data provide evidence that GAT has good test-retest reliability and construct validity. One caveat is that both studies found that the construct validity of GAT was restricted to patients who had RP. For patients with other retinopathies, when GAT and ETDRS were compared, authors only found a weak correspondence, as GAT appeared to overestimate patients' visual acuity.

#### Color Vision: Chow Color Test (CCT)

The CCT was developed to be more sensitive for patients with low vision than the standard low color vision testing, the Farnsworth PV-16. The CCT is composed of both high saturation and low saturation discs, and the best possible score is 40. One Moderate risk-of-bias study^80^ has tested its test-retest reliability as well as its construct validity (by comparing CCT results to the PV-16).

For test-retest reliability, authors reported a mean CR_.95_ values of 5.8. However, this mean included all patients in the study. When results were given specifically for patients with RP, CR_.95_ was slightly better at 4.8. Thus, for an average patient with RP, if his or her color vision tested at 13 of 40 at one visit (13 was the RP average), then the next visit would be expected (with 95 percent confidence) to be between 8 and 18 of 40. The median CR_.95_ value for patients with macular degeneration was even lower (3.9), and they had better color vision than patients with RP (mean 30 of 40).

Regarding construct validity, because higher scores on the CCT mean better color vision but higher scores on the PV-16 mean worse color vision, good construct validity would be indicated by a large negative correlation. The study found a strong negative correlation of r=-0.77, suggesting good construct validity. Authors felt that the PV-16 was less sensitive to differences among patients, because the PV-16 scores appeared to cluster in the middle of the range, whereas for patients receiving CCT, scores were more evenly dispersed across its range.

#### Day-to-Day Function: Functional Low-Vision Observer Rated Assessment (FLORA)

FLORA was developed specifically for patients with very low vision and has three components: (1) patient self-report, which includes 14 open-ended questions (e.g., “What would you like me to know about how the system has affected you?”), and any of the 14 can be skipped if the assessor so decides; (2) observation of performance in 26 activities, in which the assessor observes the patient performing common activities of daily living, and any can be skipped if the assessor so decides; and (3) the case summary, which is a narrative case report summarizing the assessor's findings.

One low risk-of-bias study^31^ reported the face validity of FLORA. A team of experts in blind and low-vision rehabilitation met to draft a first assessment. During multiple rounds of revision, the team reviewed commonly accepted instruments and tailored FLORA to the challenges of this population. For the self-report questions, the assessor chose to address all 14 questions for 22 of 26 patients. For the 26 activities, assessors asked patients to perform an average of 20. Based on these methods, FLORA appears to have acceptable face validity. The study reported no other psychometric properties of FLORA.

## Key Question 1C Psychometric Properties of Other Possible Outcome Measures

### Description of Included Studies

We included nine studies of the psychometric properties of other instruments that could be used to measure the effects of RPS. These studies investigated 10 outcome measures: dark adaptometry, dark-adapted Humphrey perimetry, the full-field flash test (also known as the full field stimulus test), the Pelli-Robson contrast sensitivity test, the Grating Contrast Sensitivity (GCS) test, the Veterans Health Administration-13 (VA-13; formerly the Blind Rehabilitation Service Follow-up Outcomes Survey), the Functional Assessment of Self-Reliance on Tasks (FAST), the Very Low Vision Instrumental Activities of Daily Living (IADL-VLV), the Modified National Eye Institute Visual Function 25 Item (NEI-VFQ-25) plus supplement, and the Modified Impact of Vision Impairment (IVI) questionnaire. For general information about the studies, patient characteristics, interventions, comparators, and outcome data, see tables C-6 through C-10 of Appendix C.

### Key Points

- For measuring vision in relative darkness, the full-field flash test (also known as the full field stimulus test) has better psychometric properties than either dark adaptometry with SST-1 or dark-adapted Humphrey perimetry. For the latter two tests, many patients with RP do not provide measurable or reliable results. The full-field flash test has acceptable test-retest reliability and construct validity.
- For measuring contrast sensitivity, the GCS has better test-retest reliability than the Pelli-Robson test. The Pelli-Robson test may not produce meaningful results in some patients with RP, due to their limited vision.
- The FAST instrument has acceptable reliability, validity, and responsiveness. Further, its psychometric properties are better than those of the VA-13. Both clinician-completed and patient-completed versions of the FAST instrument have reliability and responsiveness, but they yield somewhat different answers.
- The IADL-VLV and Modified NEI-VFQ-25 plus supplement have acceptable reliability, validity, and responsiveness.
- The IVI has acceptable reliability and validity; no included studies measured its responsiveness.

### Detailed Synthesis

We included evidence on the psychometric properties of 10 outcome measurements that have not been used in RPS studies. Their psychometric properties were reported in eight studies.^89-96^ Evidence tables in Appendix C provide the following: general information about the studies (Table C-6), patient characteristics (Table C-7), details about the measurements (Table C-8), psychometric data (Table C-9), and risk-of-bias assessments (Table C-10). Below, we discuss the outcome measurements in separate sections.

#### Light Sensitivity Tests: Dark Adaptometry, Dark-Adapted Humphrey Perimetry, and Full-Field Flash Test

We discuss the psychometric properties of dark adaptometry with SST-1, dark-adapted Humphrey perimetry, and full-field flash test together, because they were directly compared in the same study.^91^ All three tests were used in patients with very low vision as an attempt to assess their visual abilities in the dark (see test details in Table C-8 of Appendix C). The study reported test-retest reliability for all three measures and also measured construct validity as the correlation between the measures. We graded the risk of bias as Low for test-retest reliability, and Moderate for construct validity.

Two of the three tests—dark adaptometry with SST-1 and dark-adapted Humphrey perimetry—had the problem that only about half of the patients with RP could both complete the tests and provide measurable or reliable results. By contrast, 75 of 77 patients (97 percent) could sensibly complete the full-field flash test.^91^ Below, we first discuss each test's test-retest reliability, and then we turn to inter-test correlations.

For dark adaptometry with SST-1, researchers determined each person's threshold for detecting faint light (with lower decibel [dB] thresholds indicating greater sensitivity), as well as the amount of time it took to determine the person's threshold (shorter time indicates greater sensitivity). They measured test-retest reliability using the coefficient of variation (CoV), which is the standard deviation (SD) of the time required to reach the person's light perception threshold divided by the average time the person needed to reach the threshold. CoV is on a percentage scale, and lower numbers indicate greater test-retest reliability. The various patient groups in the study averaged about 10 percent to 20 percent, which is generally good. The authors did not report results specifically for patients with RP (although, as noted above, only 16 of 33 of these patients could actually complete this test).^91^

For dark-adapted Humphrey perimetry, patients focused on a red light-emitting diode (LED) in the middle of a 4- by 4-inch square after being dark-adapted. Researchers determined each person's threshold for detecting faint light over the visual field. Data were on the dB scale, with higher dB indicating greater sensitivity. The authors measured test-retest reliability using the CR._95_ (discussed earlier), which is also expressed as dB. The authors reported CR._95_ values separately for (1) rod-based sensitivity, (2) cone-based sensitivity, and (3) rod-cone sensitivity ratios. Further, they reported CR._95_ values separately for several different groups of patients (see Table C-9 in Appendix C). The three RP groups had means ranging from about 1 dB to 18 dB; mean CR._95_ values ranged from 1 dB to 10 dB. Variability within a given patient visit was less than variability across patient visits. For this report, the most pertinent finding is that only 15 of 33 patients with RP could provide measurable or reliable results.^91^

After dark adaptation for 45 minutes, patients underwent the full-field flash test (also known as the full field stimulus test). Two studies provided psychometric data on the full-field flash test: Kiser et al.^91^ and Roman et al.^97^ In Kiser et al.,^91^ two white-light flashes appeared (one at maximum attenuation, the other at a level to determine the patient's threshold for detecting faint light), and each patient's threshold was determined. Higher dB thresholds indicate greater sensitivity. Test completion was not problematic, as 75 of 77 patients provided measurable and reliable results. The authors measured test-retest reliability using the CR_.95_. Mean values for the full-field flash thresholds for the four RP groups (grouped by varying levels of visual acuity) ranged from 20 to 43 dB, with CR._95_ values ranging from 6 to 12 dB. For example, a typical RP-I patient (vision 20/40 or worse but with limited visual field) had a threshold of 43 dB, and one would expect with 95 percent probability that a retest would be between 37 dB and 49 dB. This appears to be reasonably good test-retest reliability.^91^

For construct validity, the authors measured two types of associations: (1) between dark adaptometry and full-field flash tests and (2) between Humphrey perimetry and full-field flash tests. The first correlation was weak (r=0.37) and the authors theorized that the adequacy of adaptometry had device concerns (“limited response range of the SST” [scotopic sensitivity test instrument]). The second correlation was stronger (r=0.60); authors noted that macular disease (MD)-I patients were outliers, and after removing them, the correlation became even stronger (r=0.80). Overall, among the three methods, the data suggest that the full-field flash test is the best for assessing dark-adapted vision in patients with very low vision.^91^

Roman et al.^97^ compared two versions of the full-field flash test after 45 minutes of dark adaptation: FST1 and FST2. They confirmed construct validity of the FST2 by showing its high correlation with FST1 (r=0.98) as well as demonstrating poorer light sensitivity among patients than among people with normal vision. Further, they found good test-retest reliability of FST2 (SD of only 1.41 dB from an approximate patient median of 17 dB). We rated the Roman et al. 2007^97^ study as risk of bias as Low for test-retest reliability, and Moderate for construct validity.

#### Contrast Sensitivity: Pelli-Robson Contrast Sensitivity Test

The Pelli-Robson test is a standard contrast-sensitivity test using letter charts, and two studies^89,90^ have reported its test-retest reliability in patients with very low vision. The authors reported CR._95_ and median values, and results are on the logMAR scale. The low risk-of-bias Bittner et al.^89^ study reported a median CR._95_ value of 0.14 for patients with RP and 0.24 for patients with other retinopathies. The low risk-of-bias Kiser et al.^90^ study reported poorer test-retest reliability, with median CR._95_. values ranging from 0.39 to 0.49 for various RP groups. Kiser et al.^90^ also reported the test-retest reliability of the Pelli-Robson test under two alternate illumination conditions: dim and glare. For dim illumination, median CR._95_ values ranged from 0.22 to 0.50 for various RP groups, whereas for glare illumination, they were 0.25 for the best-vision RP group, 0.68 for the next-best-vision RP group, and only 0.10 for the poorest-vision patients with RP.

#### Contrast Sensitivity: Grating Contrast Sensitivity (GCS) Test

Bittner et al.^89^ described the GCS test as an alternative to the Pelli-Robson test. Gratings are presented in varying shades of gray, and each patient's threshold is determined. This low risk-of-bias study reported test-retest reliability using CR._95_ values (logMAR scale). For patients with RP, results were generally good, with median CR._95_ values of 0.13 for within-visit testing and 0.15 for between-visit testing. For patients with other retinopathies, within-visit data were similarly good; however, between-visit reliability was poor (medians of 0.34 and 0.41 for the two pertinent subgroups).^89^

The authors also measured construct validity by determining the correlation between the GCS and the Pelli-Robson contrast sensitivity test. The correlation was low, which may indicate that the two tests measure different abilities.^89^

#### Day-to-day Function: VA-13 and Functional Assessment of Self-Reliance on Tasks (FAST)

We discuss VA-13 and FAST together because the two pertinent studies on these instruments were published by the same authors from a single Veterans Health Administration (VA) hospital in Tucson, AZ,^92,93^ and they were the only included studies of these instruments. All patients in both studies had undergone a low-vision rehabilitation program at the Tucson VA hospital. The first study^93^ compared the clinician-completed FAST (both before and after the program) to the patient-completed VA-13 (after the program), whereas the second study^92^ compared the clinician-completed FAST to a patient-completed FAST (both were administered before and after the program).

Regarding reliability, only the first study reported pertinent data (Low risk of bias), and the authors measured it in three ways: (1) separation reliability, which is how well the instrument classified respondents into different levels of the trait; (2) internal consistency reliability for persons, which is whether the items are measuring the same underlying construct of patient ability; and (3) internal consistency reliability for items, which is whether the items are measuring the same underlying construct of item difficulty. They used a priori thresholds for acceptable levels of these metrics. For VA-13, only the second of the three had acceptable reliability, but FAST met criteria for all three.^93^

The first study also discussed face validity of each item, based on whether the distribution of pretreatment item difficulty (assessed using a Rasch-based analysis) was “the same order of difficulty that is observed in clinical practice at admission or in pre-test self-reports.”^93^ For VA-13, 11 of 13 items achieved the expected ordering, and for FAST it was achieved for all 13 items. Furthermore, the VA-13 at discharge requires patients to remember their pretreatment levels of vision functionality, and therefore has less face validity.^93^

Both studies reported data on construct validity and both were at Low risk of bias. Babcock-Parziale et al. theorized that the estimated item difficulties should not change before and after vision rehabilitation because the items do not change, and they found this to be true for both the VA-13 and the clinician-completed FAST.^93^ Both instruments also met their criteria for response category thresholds (whether participants could discriminate between items). McKnight and Babcock-Parziale^92^ assumed that item difficulty should not change depending on whether patients or clinicians complete the FAST instrument. They found a near-linear relationship between the two types of administrations (i.e., Rasch statistical analysis generally found that if an item was relatively difficult based on clinician-completed forms, it was also relatively difficult based on patient-completed forms). However, McKnight and Babcock-Parziale^92^ found real differences based on the respondent, because only 55 percent of the variance in patient scores was explained by clinician scores. They performed a multiple regression to investigate this further, and found that the timing of administration (at admission or at discharge) was the primary explanatory factor.

For responsiveness (Moderate risk of bias for both studies), both versions of the FAST were acceptably responsive to changes in patient abilities after the program. The VA-13, however, was judged by Babcock-Parziale et al.^93^ to be insufficiently responsive, based on their opinion that amount of improvement as measured by the VA-13 was considerably less than what is typically observed in the field.

Overall, these data suggest that for veterans with low vision in Arizona, FAST is a better instrument than VA-13, and that for the FAST, patients and clinicians give different answers.

#### Day-to-day Function: Very Low Vision Instrumental Activities of Daily Living (IADL-VLV)

A small study by Finger et al.^94^ in Australia (n=40) tested the IADL-VLV instrument for its reliability and validity. Patients were observed attempting up to 53 different tasks (e.g., searching a shelf for a can of tomato soup), and they were scored on successful completion and the number of attempts needed. We rated the study's data on face validity as Low risk of bias, and its data on reliability and validity as Moderate risk of bias (because of the small enrollment).^94^

For reliability, authors measured both separation reliability (how well the instrument classified respondents into different levels of the trait) and internal consistency reliability of persons (whether the items are measuring the same underlying construct of patient ability). Both metrics met the authors' predefined criteria for acceptability.^94^

For face validity, the authors began with 296 items from existing activities of living (ADLs) tools. These were reduced to 25 general activities based on importance rankings with 62 participants with severe low vision. A panel of low vision experts then reduced the 25 activities to 11, which were comprised of 53 specific tasks.^94^

The 53 tasks were then subjected to construct validity testing based on task observance in 40 legally blind patients. Authors tested the construct validity of the 28-item instrument in 4 ways: (1) response category thresholds (whether participants could discriminate between items); (2) a test of unidimensionality based on the residuals of the first factor in principal components analyses; (3) another test of unidimensionality based on the first contrast of residuals; and (4) whether responses were associated with non-vision–related aspects of health, such as age and sex. For the first three metrics, all three acceptability thresholds were met. For targeting (whether the items adequately target the ability of respondents), authors noted that the questionnaire was “slightly suboptimal,” but “still well within acceptable levels.” Various analyses reduced the initial 28 items into a final list of 23 items. This final list satisfied the first two metrics for construct validity. The third was not satisfied because the analyses indicated various separate domains of tasks related to table search, recognition of symbols, clock reading, signature placement, clothes sorting, and recognition of hand gestures. For the fourth metric, authors found no associations with age and sex after controlling for both cognitive impairment and depression. Thus, patients' abilities to perform the activities are associated with both cognitive impairment and depression.^94^

#### Quality of Life: Modified NEI-VFQ-25 Plus Supplement

The NEI-VFQ-25 is a standard instrument for assessing visual function. Stelmack et al.^95^ modified it to improve the assessment of veterans with very low vision such as legal blindness. Authors started with the 25 items from the NEI-VFQ-25 and 14 supplemental items. Directions were modified to add consideration of low-vision devices, directions were repeated if necessary because the patients frequently forgot the instructions, the driving-related items were removed (because few of the patients were driving), and the general vision/health questions were removed (items A1 and A2 in the supplement). The final instrument contained 34 items.

Data on construct validity (Low risk of bias) involved a Rasch analysis and an assessment of whether item difficulty and/or person ability fit statistics changed before and after the low-vision rehabilitation. Neither did, indicating construct validity.

For responsiveness (Moderate risk of bias), authors found that 7 of the 34 items became statistically significantly easier after treatment (see a list of the 7 items in Table C-9 in Appendix C). Furthermore, 69 of 77 patients had a higher estimate of visual ability after treatment than before treatment. The typical degree of improvement corresponded to a four-line improvement in visual acuity. These data suggest acceptable responsiveness of the modified instrument.

#### Quality of Life: Modified Impact of Vision Impairment (IVI) Questionnaire

The IVI questionnaire was tested in Australia by Finger et al. in a single moderate-quality study.^96^ It differs from the IADL-VLV mentioned earlier in that the IADL-VLV asks patients to perform tasks, whereas the IVI is a self-administered questionnaire to measure patients' assessments of their general abilities and difficulties. The IVI was modified by the authors in an effort to measure the functional limitations of people with severe vision loss. It contains 28 items in two domains (activities of daily living mobility and safety [ADLMS] and emotional well-being [EWB]; higher scores indicate higher functionality). An example item is “In the PAST MONTH, how much has YOUR EYESIGHT INTERFERED with…handling money” (to which the patient answers “Not at all/A Little/Sometimes/A lot/Don't do this for other reasons”).

Authors reported three types of reliability: (1) separation reliability, which is how well the instrument classified respondents into different levels of the trait; (2) internal consistency reliability for persons, which is whether the items are measuring the same underlying construct of patient ability; and (3) internal consistency reliability for items, which is whether the items are measuring the same underlying construct of item difficulty. They used a priori thresholds for the acceptability of these metrics, and the final version of the questionnaire met all three reliability criteria.

The face validity of their modifications of the standard IVI was established through focus-group discussions and telephone interviews with vision-impaired patients, healthy controls, and professionals. The item pool was reduced from an initial 76 items to 52, and then further reduced to 28 based on telephone interviews with 198 legally blind people.

Authors tested the construct validity of the 28-item instrument in seven ways: (1) response category thresholds, which is whether participants could discriminate between items; (2) a test of unidimensionality based on the residuals of the first factor in principal components analyses; (3) another test of unidimensionality based on the first contrast of residuals; (4) targeting, which is whether the items adequately target the ability of respondents; (5) differential item functioning, which is whether sample subgroups with similar underlying ability (e.g., of different age or sex) have similar scores on the instrument; (6) whether responses were associated with patients' eye conditions; and (7) whether responses were associated with other aspects of health. For the first three metrics, all three acceptability thresholds were met. For targeting, authors noted that the questionnaire was “slightly suboptimal,” but “still well within acceptable levels.”

For differential item functioning, authors tested six demographic patient characteristics that (theoretically) should not be associated with visual function scores, and none were statistically significantly associated for either domain. Thus, the questionnaire appears to specifically measure visual function and vision-related quality of life. In the sixth test, authors found that ADLMS scores were associated with the type of eye condition: patients with RP had relatively high scores, whereas those with age-related macular degeneration (AMD) and glaucoma had relatively low scores. EWB scores, however, showed no relationship with the eye condition. For the seventh and final test of construct validity, authors found that both ADLMS and EWB subscores correlated with four other measures of health (general health, other health problems, do other health problems interfere, and anxiety/depression). As expected, higher ADLMS and EWB subscores predicted better health responses to these questions.

Overall, these data indicate good reliability and validity of the modified IVI for patients with very low vision.

## Key Question 2 Effect of RPS on Health-related Quality of Life, Activities of Daily Living, Visual Function, and Other Outcomes

### Description of Included Studies

We included the same 11 studies that were included for KQ 1A. See Appendix C (Table C-11 through Table C-18) for more details.

### Key Points

- Some patients clearly improve on measures of visual function, visual acuity, visual field, color vision, laboratory-based function, and day-to-day function from RPS, but evidence is insufficient to estimate the proportion of patients who would benefit.
- Visual function was improved in 40 percent to 100 percent of patients with an implanted device.
- Visual acuity was improved in 0 percent to 100 percent of patients with an implanted device.
- Visual field was improved in 17 percent to 100 percent of patients with an implanted device.
- One study assessed color vision and found improvement in one patient out of six.
- Laboratory-based function measures were varied, and patients improved on some tasks but not on others.
- Day-to-day function measures were varied, and patients improved on some tasks but not on others. Results from FLORA, the only validated measure used to assess day-to-day function, found patients improved on most tasks assessed with these exceptions: travel within the home independently, identify bottom steps, negotiate stairs, chop food, heat/reheat food, and maintain safety from falls.
- Quality of life was assessed in one study using the NEI-VFQ-25-German version, which has not been validated in a RP population. The authors found no significant change in six patients 3 weeks after implantation or after planned explantation of the device (at 5-month and at 2-year followup).

### Detailed Synthesis

Below, we discuss the effectiveness evidence in seven categories: visual function, visual acuity, visual field, color vision, laboratory-based visual performance measures, day-to-day function, and quality of life. Then we provide our strength-of-evidence assessments for six of them (we did not assess the strength of evidence for color vision because of its lesser importance).

#### Visual Function

At least one measure of visual function was reported by nine studies. Seven studies reported direction of motion.^14,15,23,30,63-74,77,78^ The percentage of patients passing or with improved performance on this test ranged from a low of 21 percent in the Stingl et al. study of the Alpha IMS to a high of 100 percent in the case report by Seider and Hahn of Argus II. Four studies reported the ability to detect percepts (light).^14,18,23,82-86^ In all studies, 100 percent of patients could detect percepts. Four studies, all testing Argus II, reported square localization.^15,30,65-74,77,78^ The percentage of patients who performed better with the system ON versus OFF or who improved on this test ranged from a low of 80 percent in the Arevalo et al. study to a high of 100 percent in the case report by Seider and Hahn. Three studies reported light localization.^14,18,63,64^ The percentage of patients passing this test or performing better with the system in the ON versus OFF mode ranged from a low of 33 percent in the Zrenner et al. study of the Alpha IMS device to a high of 100 percent in the Ayton et al. study of a suprachoroidal retinal prosthesis. Two studies, both testing the Alpha IMS device, reported light detection.^14,63,64^ The percentage of patients who did better when the system was in the ON versus OFF mode ranged from 86 percent in the Stingl et al. study to 100 percent in the Zrenner et al. study.

Examining only the four Argus II studies results, square localization was improved in 80 percent to 100 percent of subjects in all four studies and direction of motion was improved in 40 percent (Arevalo et al.), 56 percent (Ho et al.), 60 percent (Rizzo et al.) and 100 percent (Seider and Hahn) of Argus II patients.

See Figure 3 for a plot of the data on the proportion of patients whose visual function improved when comparing ON to OFF or comparing before-implantation to after-implantation. Additional details are provided in Table C-13 of Appendix C.

Figure 3 Visual function: proportion of patients improved

Note: Each filled circle shows the proportion of patients who experienced any improvement with RPS ON, and the horizontal bar shows the 95% confidence interval around the proportion. BaLM=Basic Assessment of Light and Motion; RPS=retinal prosthesis system; STS=Suprachoroidal Transretinal Stimulation

Figure 3 is a plot of a subset of the visual function data. Each dark circle is the reported proportion of patients who experienced improvement in visual acuity with RPS ON, either compared to RPS OFF or before implantation. The horizontal lines indicate the 95% confidence interval around each proportion. The labels to the right of each datapoint indicate which RPS device was used, the specific measure, and the study that reported the datapoint.

#### Visual Acuity

Nine studies reported at least one measure of visual acuity. Six studies reported some measure of grating visual acuity.^15,30,63-74,77,78,80,81^ The percentage of patients experiencing an improvement ranged from a low of 0 percent in the case report by Seider and Hahn of Argus II to a high of 100 percent in the Chow et al. extension study of the ASR device. Two studies reported Freiburg Acuity and Contrast Test (FrACT) visual acuity.^14,18^ One study administered the test to one out of three patients enrolled and found that that patient did significantly better with the system ON than OFF.^18^ The other study administered this test to all three patients enrolled and one out of three passed with the system in ON mode. That patient then went on to take the test with the system in OFF mode and failed.^14^

Examining only the four Argus II studies results, grating acuity was improved by 0/1 patients (Seider and Hahn), 17 percent of patients (Rizzo et al.), 33 percent (Ho et al.), and an unspecified majority percent (Arevalo et al.). See Figure 4 for a plot of the data on the proportion of patients whose visual acuity improved when comparing ON to OFF or comparing before-implantation to after-implantation. Additional details are provided in Table C-13 in Appendix C.

Figure 4 Visual acuity: proportion of patients improved

Note: Each filled circle shows the proportion of patients who experienced any improvement with RPS ON, and the horizontal bar shows the 95% confidence interval around the proportion. ETDRS=Early Treatment of Diabetic Retinopathy Study test; logMAR=logarithm of the minimum angle of resolution; RPS=retinal prosthesis system

Figure 4 is a plot of a subset of the visual acuity data. Each dark circle is the reported proportion of patients who experienced improvement in visual acuity with RPS ON, either compared to RPS OFF or before implantation. The horizontal lines indicate the 95% confidence interval around each proportion. The labels to the right of each datapoint indicate which RPS device was used, the specific measure, and the study that reported the datapoint.

To determine if visual acuity gains were maintained over time, we chose one visual acuity measure from each study that reported a measure of visual acuity. We chose measures that were commonly reported and for which the most timepoints were presented. A majority of studies reported only one timepoint. For the Ho and colleagues Argus II trial, visual acuity results were better in Year 1 and 2 than Year 3 and 5 but approximately 40% of patients were still showing gains at the final followup visit. Alpha IMS gains, as reported by Stingl, declined over the one year followup period. Both Chow ASR studies found that the two patients who had the biggest gains by the Month 1 postoperative visit (patients 5 and 6) experienced a decrease in those gains over the course of the study. Seven patients did not improve over time and one patient (patient 7) experienced steadily improved over time but had a sharp decline at the final followup visit. See the table below for more details.

Table 5 Visual Acuity Results Over Time

Study | Outcomes | Comparator | <1 year | 1 to 3 Years | 3 to 5 Years | ≥5 Years | Change
Arevalo et al. 2015^65,66^ Argus II | GAT | Pre-implantation: 1 L projection, 7 LP | NA | Post-implantation: 4 HM, 2 L projection, 2 LP. | NA | NA | A majority of patients improved. Study did not report how many improved.
Ho et al. 2015 and other authors^15,30,67-76^ Argus II | GAT: percentage of subjects who scored between 2.9 and 1.6 logMAR with the system ON. None of the subjects scored with the system OFF | Stimulator OFF/Fellow eye: No subject could score on the scale at baseline. | NR | Stimulator ON Year 1 (n=29 patients): 48.2% did significantly better than with the stimulator OFF Stimulator ON Year 2 (n=29 patients): 49% did significantly better than with the stimulator OFF | Year 3 (n=27): 33.3% did significantly better than with the stimulator OFF Year 4 (n=22): 28% did significantly better than with the stimulator OFF | Year 5 (n=21) 38.1% of patients did significantly better with the stimulator ON than with the stimulator OFF | Proportion of subjects with significantly better system ON than OFF results was not significantly different between 1 and 3 years for this test. Performance has remained better with the System ON than OFF on all visual tests, with these results sustained out beyond 5 years of chronic use.
Seider and Hahn 2015^77^ Argus II | Grating visual acuity | System OFF: NR | NA | Year 1 System ON: NR | NA | NA | Patient did not benefit from the System being ON
Stingl et al. 2015, 2013^63,64^ Alpha IMS | Grating acuity and VA with standardized Landolt C-rings in contrast reversal | Stimulator OFF Grating acuity, percentage of patients passing test Month 1 (n=22) 15% Month 3 (n=17) 8% Month 6 (n=15) 0% Month 9 (n=10) 0% Month 12 (n=6) 0% Landolt C-rings, percentage of patients passing test Month 1(13) 0% Month 3 (n=9) 0% Month 6 (n=4) 0% Month 9 (n=4) 0% Month 12 (n=1) 0% | Grating acuity, percentage of patients passing test Month 1 (n=22) 50% Month 3 (n=17) 46% Month 6 (n=15) 20% Month 9 (n=10) 30% For grating acuity, only comparisons at months 1–3 were statistically significant. Landolt C-rings, percentage of patients passing test Month 1 (n=13) 17% Month 3 (n=9) 22% Month 6 (n=4) 0% Month 9 (n=4) 0% No time points showed statistically significant comparison for Landolt C rings. | Grating acuity Month 12 (n=6) 18% Landolt-C rings Month 12 (n=1) 0% No time points showed statistically significant comparisons | NA | NA | Significantly better for implant ON versus OFF for visits months 1–3. Grating acuity resolutions with the implant ON ranged from 0.1 to 3.3 cycles per degree. 5 patients passed the grating acuity test with the implant OFF but all 5 patients had higher percentage of correct responses with the implant ON. 4 patients completed standardized VA testing with contrast reversal Landolt C-rings with VA of v20/2000, 20/2000, 20/606, and v320/546 with the implant ON.
Ayton et al. 2014^18^ Bionic Vision | Visual acuity was assessed with the Landolt C optotype recognition subtest from FrACT, presented in a darkened room. Floor effect (unable to estimate VA lower than 3.24 logMAR). | Device OFF no optotypes were seen (n=1) | NA | Year 1 Device ON: 2.62 mean logMAR, Rng 2.35–3.02 across 19 sessions (n=1) | NA | NA | Significant difference in favor of the device ON condition, n=1 patient (who was enrolled in the trial the longest)
Rizzo et al. 2014^78^ | Grating acuity was tested only in implanted eye with the device ON | Pre-implantation: 0 patients could identify gratings | NA | 12 months Post-implantation: 1 patient was able to identify gratings, grating VA 2.2 logMAR in the operative eye with stimulator ON | NA | NA | 1 patient improved
Zrenner et al. 2011^14^ Alpha IMS | Standardized FrACT test with Landolt C optotypes and an up and down staircase procedure. If Landolt C was passed, single letters were used subsequently. | Stimulator OFF Only presented to patient who passed with the stimulator ON: patient failed | 4 month followup: 1/3 could see the Landolt C rings and discern letters with VA logMAR 1.69, 2 patients failed (but one of these patients reported seeing the Landolt ring gap clearly). | NA | NA | NA | 1/3 passed test. Authors note that patient performance improved over the course of the 4 month study.
Chow et al. 2010 and Geruschat et al.^80,81^ Extension study ASR | ETDRS acuity | Implanted eyes baseline Patient 5: 21.0 (16–25) letters Patient 6: 0 (0–0) letters Patient 7: 0 (0–0) letters Patient 8: 0 (0–0) letters Patient 9: 0 (0–0) letters Patient 10: 0 (0–0) letters | Implanted Eye Patient 5: Month 1: 42 letters Month 6: 38 letters Patient 6: Month 1: 26 letters Month 6: 27 letters Patient 7: Month 1: 0 letters Month 6: 2.5 letters Patient 8: Month 1: 0 letters Month 6: 0 letters Patient 9: Month 1: 0 letters Month 6: 1.7 letters Patient 10: Month 1: 0.5 letters Month 6: 3.7 letters | Implanted Eye Patient 5: Year 1: 30.5 letters Year 2: 25 letters Patient 6: Year 1: 24 letters Year 2: 15 letters Patient 7: Year 1: 2.7 letters Year 2: 4.7 letters Patient 8: Year 1: 0.3 letters Year 2: 0.7 letters Patient 9: Year 1: 0.7 letters Year 2: 1 letters Patient 10: Year 1: 2 letters Year 2: 0.7 letters | Implanted Eye Patient 5: Year 4: 25 letters Patient 6: Year 4: 17.3 letters Patient 7: Year 3.5 to 4.5: 12.3 to 10 letters Patient 8: Year 4: 0.3 letters Patient 9: Through 3.5 years: 0 to 1.5 letters Patient 10: Years 2 to 6: 0.3 to 0.7 letters | Implanted Eye Patient 5: Year 8: 22.7 letters Patient 6: Year 8: 5 letters Patient 7: Year 7.5: 1 letter Patient 8: Year 6.5: 0.7 letters Patient 9: NR Patient 10: Years 2 to 6: 0.3 to 0.7 letters | 4/6 patients improved from pre- to post-operative period.
Chow et al. 2004^22,79^ ASR | Letter recognition | ETDRS VA Patients 1–4: 0 letters Patient 5: 16–25 letters OD, 24–28 letters OS Patient 6: 0 letters OD, 0 to 3 letters OS | ETDRS Patient 5 at 6-month followup: 35–41 letters OD, 21–28 letters OS Patient 6 at 6-month followup: 25–29 letters OD, 0 letters OS | ETDRS Patients 1 through 4: 0 letters (3 patients), able to see some of the largest letters OD only (20/1280 to 20/1600) at 12–18 month followup (1 patient) | NA | NA | 3/6 patients experienced some improvement

ETDRS=Early Treatment of Diabetic Retinopathy Study test; FrACT=Freiburg Acuity and Contrast Test; GAT=grating acuity test; logMAR=logarithm of the minimum angle of resolution; NA=not applicable; NR=not reported; OD=ocular dextrus; OS=ocular sinister; VA=visual acuity

#### Visual Field

Two studies out of 11 reported visual field outcome data but the studies reported different measures of visual field. The Chow et al.^22^ study of the ASR device reported Humphrey visual field test results, Nine Sector Test results, and patient subjective impression of their visual field, while the Rizzo et al.^78^ study of Argus II reported Goldmann visual field results. Compared with the unoperated eye or their subjective impression of their visual field before implantation, patients reported their visual field improved in the following proportions: one of the six subjects tested with Humphrey visual field, three of six patients tested with the Nine Sector test, and four of six patients reporting subjective impressions of their visual field.^22^

The single Argus II study to examine this outcome tested the Goldmann visual field and found all of the patients improved with the system in OFF mode at the 12-month followup compared to pre-implantation.^78^

See Figure 5 for a plot of the data on the proportion of patients whose visual field testing improved when comparing ON to OFF or comparing before-implantation to after-implantation. Additional details are provided in Table C-14 in Appendix C.

Figure 5 Visual field: proportion of patients improved

Note: Each filled circle shows the proportion of patients who experienced any improvement with RPS ON, and the horizontal bar shows the 95% confidence interval around the proportion. ASR=Artificial Silicon Retina; RPS=retinal prosthesis system

Figure 5 is a plot of a subset of the visual field data. Each dark circle is the reported proportion of patients who experienced improvement in visual acuity with RPS ON, either compared to RPS OFF or before implantation. The horizontal lines indicate the 95% confidence interval around each proportion. The labels to the right of each datapoint indicate which RPS device was used, the specific measure, and the study that reported the datapoint.

#### Color Vision

One of the 11 studies reported color vision. Chow et al. reported that one of the six patients who received the ASR implant device improved on the pseudoisochromatic test plates. The improved patient could correctly identify blue and orange dots on the control isochromatic plate and red and green dots on the test plate in the operated eye. This same patient reported that he gained the ability to detect colors in the environment (e.g., red and white of stop signs, green and white of street signs) after implantation. When the unoperated eye was tested, no patient could perceive or discriminate color.^22^ Additional details are provided in Table C-15 in Appendix C.

#### Laboratory-based Visual Performance Measures

Six of the 11 studies reported some measure of laboratory-based visual performance measures. The ability to grasp an object was measured by two studies.^15,23,30,67-75^ Only one patient in the Fujikado et al. study of the Suprachoroidal Transretinal Stimulation (STS) device performed this test and outperformed chance with the system in ON mode but failed when the system was in OFF mode. Subjects in the Ho et al. study of Argus II also performed significantly better when the device was in ON mode versus OFF mode. Multiple authors reporting on three studies reported patient performance on a mobility course.^15,30,67-75,78,80,81^ The Chow et al. extension study of the ASR device found no differences in patient performance of this task in the pre- versus post-implantation period. The Ho et al. study of Argus II found patients performed the Meandering Maze Test significantly better with the device in the ON mode, but results were mixed for other similar tests, including the Triangle Path and Path Reproduction Test. The Rizzo et al. study, also of the Argus II device, found all patients able to perform the task in the postoperative period. Two studies, both testing the Alpha IMS device, reported patients' abilities to recognize shades of gray.^14,63,64^ Only one patient in the Zrenner et al. study completed this test and that person passed with the system in ON mode but failed when it was turned to OFF. Stingl et al. also found patients performed significantly better with the system ON than OFF. Two studies, both reporting on the Alpha IMS device, reported the ability of patients to read a clock.^14,63,64^ Stingl et al. found no significant benefit to having the device in ON versus OFF mode, while the one patient tested in the Zrenner et al. study passed when the system was ON but failed when it was turned OFF. These same two studies of Alpha IMS also reported the ability of patients to recognize geometric shapes and flatware.^14,63,64^ Again, patients passed the test with the system in ON mode but failed when it was turned to OFF. They also did significantly better when the system was ON versus OFF in the Stingl et al. study but only for the first few months, after which no statistically significant difference was noted. All other laboratory-based visual performance measures were either reported by a single study or the tests performed did not seem to have been conducted in the same way across studies.

Examining the Argus II studies separately, Ho et al. found subjects performed significantly better when the device was in ON mode versus OFF mode. For mobility course tests, the Ho et al. study found patients performed the Meandering Maze Test significantly better with the device in the ON mode, but results were mixed for other similar tests, including the Triangle Path and Path Reproduction Test. The Rizzo et al. study found all patients able to perform the task in the postoperative period.

See Figure 6 for a plot of the data on the proportion of patients whose laboratory-based function improved when comparing ON to OFF or comparing before-implantation to after-implantation. See also Table C-16 of Appendix C for more detailed outcomes data.

Figure 6 Laboratory-based visual performance measures: proportion of patients improved

Note: Each filled circle shows the proportion of patients who experienced any improvement with RPS ON, and the horizontal bar shows the 95% confidence interval around the proportion. RPS=retinal prosthesis system; STS=Suprachoroidal Transretinal Stimulation

Figure 6 is a plot of a subset of the laboratory-based visual performance data. Each dark circle is the reported proportion of patients who experienced improvement in visual acuity with RPS ON, either compared to RPS OFF or before implantation. The horizontal lines indicate the 95% confidence interval around each proportion. The labels to the right of each datapoint indicate which RPS device was used, the specific measure, and the study that reported the datapoint.

#### Day-to-Day Function

Four studies out of 11 reported on measures of day-to-day function. Chow et al. asked patients to rate their subjective impression of their visual acuity by comparing their eye implanted with the ASR device to the nonimplanted eye and reported that all six patients reported better vision in the implanted eye.^22^ The Chow et al. extension study also had patients subjectively rate their visual acuity in the implanted eye, but the comparator was to their memory of preimplantation visual acuity. This study also found that all six patients improved.^80,81^ Stingl et al. asked patients in whom Alpha IMS device was implanted if it was useful, a little useful, or not useful in their daily life. Of the 29 patients enrolled, 13 described the device as useful, and 8 patients each described it as a little useful or not useful.^63,64^

The final study to report day-to-day function was by Ho et al. and was the only study of Argus II to report this outcome. Ho et al. reported day-to-day function with the FLORA test, which was administered at 1 and 3 years after implantation.^15,30,67-72,74,75^ Low vision specialists interviewed subjects using FLORA about their functional vision performance on day-to-day tasks compared with how they remembered their functioning before implantation. Low vision specialists also observed subjects functioning and rated the effect of the Argus II System on their lives. At the 1-year followup, 80 percent were rated as having received a positive or mild positive benefit, 20 percent experienced a neutral effect or self-reported functional benefits in the past that could not be demonstrated at the time of observation, and none were judged as having received a negative effect. A similar pattern emerged at the 3-year followup visit, but with only 65 percent of patients rated as having received a positive or mild positive effect from the system. Additionally, all patients did significantly better with the System ON in the day-to-day function subcategories of visual orientation, mobility, and interactions with others. For most tasks in the daily life subcategory, patients did better with the System ON, but for a few tasks, they performed better with the System OFF.

See Figure 7 for a plot of the data on the proportion of patients whose daily function improved when comparing ON to OFF or comparing before-implantation to after-implantation. See also Table C-17 in Appendix C for more detailed outcomes data.

Figure 7 Day-to-day function: proportion of patients improved

Note: Each filled circle shows the proportion of patients who experienced any improvement with RPS ON, and the horizontal bar shows the 95% confidence interval around the proportion. ASR=Artificial Silicon Retina; RPS=retinal prosthesis system

Figure 7 is a plot of a subset of the day-to-day function data. Each dark circle is the reported proportion of patients who experienced improvement in visual acuity with RPS ON, either compared to RPS OFF or before implantation. The horizontal lines indicate the 95% confidence interval around each proportion. The labels to the right of each datapoint indicate which RPS device was used, the specific measure, and the study that reported the datapoint.

#### Quality of Life

One study out of 11 included data on quality of life. Klauke et al. administered the German version of the NEI-VFQ-25 to six patients who had received the EPIRET3, before implantation and at the 3-week, 6-month, and 27- to 29-month after-implantation visits. Patients underwent planned device explantation after 1 month. Klauke et al. and other authors found no statistically significant difference in quality of life for the six patients at 3 weeks after implantation of the EPIRET3 compared to baseline. Repeat measurements at 5 months and at 26 to 28 months after explanation also showed no significant change.^82-86^

#### Strength of Evidence

Table 6 below shows our ratings of the strength of evidence and each domain that contributed to it.

Table 6 Strength of evidence for effectiveness of retinal prosthesis systems for retinitis pigmentosa for each outcome

Strength of Evidence Domain | Visual function | Visual Acuity | Visual Field | Laboratory-based Visual Performance Measures | Day-to-day Function | Quality of Life^a^
Study limitations | High | High | Moderate | Moderate | High | Moderate
Directness | Direct | Direct | Direct | Direct | Direct | Direct
Consistency | Inconsistent | Inconsistent | Inconsistent | Inconsistent | Inconsistent | Inconsistent
Precision | Imprecise | Imprecise | Imprecise | Imprecise | Imprecise | Imprecise
Reporting bias | Undetected | Undetected | Undetected | Undetected | Undetected | Undetected
Strength-of-evidence rating | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

a Quality of life measurement in the single study measuring it was used to detect adverse consequences following device explantation.

We rated the strength of evidence for visual field, laboratory-based visual performance measures, and quality of life as Moderate and visual function, visual acuity and day-to-day function as High. In cases in which half of the studies received a study-limitation rating of Moderate and the other half a rating of High, we rated that domain as Moderate. For individual study ratings, to receive a rating of Low, studies needed to have a “Yes” response for the first five risk-of-bias items (confounder controlling, concurrent intervention controlling, intervention protocol fidelity, attrition handled appropriately, and outcome assessor blinding). For a rating of Moderate, studies needed at least three “Yes” responses on risk-of-bias items 1 through 5 and a “Not Reported” or “Yes” on items 6 and 7. All other studies were rated High risk of bias. See Appendix C, Table C-20 through Table C-25 for our assessment on each item for each study.

We considered all outcomes reported to be Direct because the patients enrolled in these studies had diagnoses (e.g., RP, choroideremia) and visual acuities (e.g., light perception, hand motion) that that met the U.S. Food and Drug Administration (FDA) requirements or European requirements for implantation with an RPS and because the comparators evaluated (e.g., system ON vs. OFF) are appropriate choices, given that no other treatments are available for this patient population.

We rated all outcomes as Inconsistent and Imprecise because although some patients clearly benefit from these devices, the percentage who benefit is highly variable across studies for any given outcome and the number of patients enrolled was small (≤30 patients).

We did not detect any evidence of reporting bias for any outcome. We made this determination by looking for studies reported at the National Clinical Trials (ClinicalTrials.gov) registry that should have been completed and published but for which we could not find a publication. No instances of that were found. See Appendix C, Table C-27 through Table C-34.

Overall, for all outcomes assessed, the evidence bases were found to be insufficient to estimate the proportion of patients who would benefit from RPS.

## Key Question 3 RPSs to Arrest the Progression of Retinitis Pigmentosa

### Description of Included Studies

Of the 11 included studies of RPS devices for KQ1A and KQ2, the two Chow et al. studies^22,80^ of the ASR and the Rizzo et al. study of Argus II reported the neuroprotective effects of device implantation. “It should be noted that the focus of RPS devices is to provide some degree of visual perception to patients whose severe RP indications otherwise render them functionally blind. No rigorous scientific clinical studies on humans with RPS have investigated operational aspects attendant to halting disease progression.”^98^ For details about these studies, see tables in Appendix C.

### Key Points

- Limited evidence has been interpreted as possibly indicating that implanted RPS devices may arrest RP progression. Patients in whom the Argus II was implanted for 12 months experienced improved visual fields even when the system was in OFF mode.
- Evidence from animal studies has suggested a possible neuroprotective effect from electrical stimulation of the retina, mediated through induction of certain growth factors.
  ○ Electroretinographic waveforms in rat eyes with an active implant experienced temporary preservation compared with unoperated rat eyes through 6–7 weeks of followup.
  ○ Electroretinographic b-waves were significantly larger in rat eyes with active implants versus rat eyes without active implants at the 4- to 6-week followup.
  ○ Rat eyes with and without active implants were similar on electroretinographic a-waves.
  ○ Rat eyes with active implants had four to six rows of photoreceptors compared with a single sparse layer of photoreceptor cells in unoperated eyes 8 weeks after implantation.
  ○ Photoreceptor preservation occurred in all rat eyes that received an implant, even if it was an inactive implant.
  ○ Growth factor expression of fibroblast growth factor 2 (Fgf2) was significantly higher in rat eyes with active implants by postoperative day 9 compared with eyes with minimally active implants, eyes that underwent sham surgery, and unoperated eyes, and a dose-response relationship was evident.
  ○ Rat eyes with active implants and those without an active implant were similar on growth factor expression of fibroblast growth factor 1 (Fgf1), ciliary neurotrophic factor (Cntf), insulin-like growth factor (Igf), glial cell line-derived neurotrophic factor (Gdnf), and brain-derived neurotrophic factor (Bdnf).

### Detailed Synthesis

Of the 11 included studies of RPS devices for KQ1A and KQ2, the two Chow et al. studies^22,80^ of the ASR device and the Rizzo et al. study of Argus II^78^ reported apparent neuroprotective effects of device implantation. In the Chow et al. extension study,^80^ investigators completed two studies on Royal College of Surgeons (RCS) rats with a genetic mutation that causes photoreceptor loss starting at 12 days of age and ending by 77 days of age. They also conducted a cadaver study on one human patient with RP who had been implanted with the ASR device for 5 years before dying of natural causes.

The ASR device containing 5,000 microelectrode-tipped microphotodiodes was implanted in the superior to superior temporal retina, stimulating a small portion of the retina. Chow et al.^22^ noted that visual fields distant from the implant, including the macular region and far peripheral field regions, were improved from about 1 week to 2 months after implantation, and these improvements were maintained at 6–12 months postoperatively. They theorize that patients' experiences of complex visual capabilities including improved contrast, color, resolution, movement, and visual field size are the result of low-level electrical stimulation inducing up-regulation of protective neurotrophic factors. This up-regulation, in turn, improves the functioning of remaining photoreceptors. To support this hypothesis, they note that patients' improvements were not immediate after implantation but took weeks to 2 months to take effect. They also note that patients with better baseline vision, or more viable retinas, experienced greater gains from the implant than those with worse preoperative vision.^22^

In the Chow et al. extension study,^80^ RCS rats were implanted subretinally at postnatal age 3 weeks with either active or inactive ASR chips, or underwent sham surgery or no surgery. Fifteen rats were studied. Thirteen were implanted with active devices in the right eye and the left eye was either implanted with an inactive implant, had sham surgery, or had no surgery. Two of the 15 rats served as unoperated controls. Cage luminance was controlled. Implants used in this study were similar to those used in humans but modified for use in animals. Electroretinographic (ERG) recordings were performed weekly for 8 weeks after surgery, and then the animals were sacrificed.

ERG waveforms on unoperated rats demonstrated a rapid drop over the 8-week followup period while rats with an active implant experienced a temporary preservation of ERG waveforms, most notable at 4–7 weeks after implantation. At the 6-week followup, ERG amplitudes were four times greater in the rats with an active implant than in those without; however, this difference was no longer significant by the final followup at week 8. ERG b-wave responses were similar across groups at the 2-week followup, with the exception of the inactive implant group, whose b-waves were significantly smaller. By weeks 4 and 6, rats with the active implant had significantly larger b-waves than the other three groups, but this difference disappeared at week 8.^80^

Histologic examination of the rats' eyes showed a single sparse layer of photoreceptor cells in unoperated eyes compared to four to six rows of photoreceptor cells in active implant eyes. However, in rats with an active implant in one eye and an inactive implant in the other eye, photoreceptor preservation occurred over both implants. The two eyes were indistinguishable in terms of morphologic preservation, but this did not result in functional preservation as measured by ERG. Only the superior region of the retina near the implant experienced this morphologic preservation.^80^

The second of the Chow et al. extension studies was designed to measure growth factor expression of Fgf2 and was composed of the same four arms as the first study, with the exception that inactive implants are referred to as “minimally electrically active implants.” By week 4, the active implant group demonstrated significantly larger dark-adapted and light-adapted ERG b-waves than the control and minimally active implant groups. No group differences were noted in a-wave amplitudes.^80^

At day 9, Fgf2 expression was significantly elevated in the active implant eyes compared with all other eyes, and there appeared to be a dose-response relationship (i.e., higher to lower Fgf2 expression in the active, minimally active, sham, and unoperated groups). At 30 days after implantation, the active implant eyes still had significantly greater expression of Fgf2 than the other three treatment arms, but Fgf2 expression was slightly lower than at postoperative day 9. This finding suggests that subretinal electrical stimulation from an implant confers benefit over and above the presence of nonactive chip placement or the surgical procedure alone. No between-group differences were observed in Fgf1, Cntf, Igf, Gdnf, or Bdnf.^80^

Before his death, the RP patient in the cadaver study reported subjective improvements after ASR implantation, but these subjective impressions did not correlate with objective tests. Chow et al. attributed this lack of correlation to insensitivity of the objective tests. Upon death, the man's eyes were enucleated within 10 minutes and examined. Both retinas appeared to be in late stages of photoreceptor degeneration, with massive reorganization and remodeling. However, in the area over and in close proximity to the implant, the retina maintained some inner nuclear layer cells and inner plexiform layer structure. This pattern was not observed in the man's unimplanted eye. Compared with other retinal regions, both eyes showed a thicker fibrous glial cell layer on the inner side of the retina and around the implant, indicating substantial remodeling.^80^

Rizzo et al. found that compared to preimplantation, all six patients in whom the Argus II was implanted for 12 months experienced an improvement in their visual field when tested with the Goldmann visual field test. The authors did not present visual field test results with the System in ON mode.^78^

## Key Question 4 Adverse Events of RPSs

### Description of Included Studies

Of the 11 studies included for KQ2, 10 reported adverse events (the only exception was Chow et al. 2010 and Geruschat et al. 2013 reports on the extension study).^80,81^ The reported adverse event data appear in Table C-26 of Appendix C.

### Key Points

- Intraoperative adverse events occurred in more than half of studies reporting this outcome, with trauma to the optic nerve being the most serious.
- Postimplantation adverse events were common and typically mild, including inflammation, temporary intraocular pressure (IOP) increase, eye scratchiness, and eye-movement restrictions.
- Intraoperative explantation adverse events were reported in two-thirds of the studies reporting this outcome, the most serious being a central retinal defect caused by removal of loose tacks.
- Post-explantation adverse events were reported by two-thirds of the studies reporting this outcome, with the most serious events including a decrease in visual acuity and a retinal detachment.
- Serious adverse events were reported by just under half of the studies reporting this outcome and included IOP increase, hypotony, and presumed endophthalmitis.
- Device-related adverse events were reported by more than a third of studies reporting this outcome and included device failure and need for retacking.
- Adverse events at the long-term followup were reported by just over half of studies reporting this outcome and were varied.

### Detailed Synthesis

Device implantation intraoperative adverse events were reported by six studies.^14,18,63,64,75,77,78,82-86^ Two studies indicated no intraoperative events.^18,82-86^ One study each reported subretinal bleeding with complete reabsorption by day 10 in one patient,^14^ device malfunction associated with optic disc swelling due to trauma to the optic nerve in one patient,^63,64^ and touching and pulling of the ciliary body in one patient.^78^

Five studies reported the occurrence of adverse events in the post-implantation period. Klauke et al. and other authors found a mild inflammatory response in two patients, a significant inflammatory response with a painless hypopyon without chemosis in one patient, and hypotony with a flat anterior chamber, inflammation, and epiretinal proliferation at the central tack in one patient.^82-86^ All three patients in the study conducted by Ayton et al. experienced a subretinal hemorrhage, pain, and mild inflammation while one patient each experienced eye-movement limitations and a staphylococcus infection.^18^ Both patients in the study conducted by Fujikado et al. also experienced eye-movement restriction.^23^ Chow et al. reported that several patients experienced eye scratchiness, three patients had elevated IOP, and one patient each had aniseikonia (image in one eye differs in size and shape from the image seen by the other eye) and syneresis (floaters).^22^ Rizzo et al. also found elevated IOP in one patient and a choroidal detachment in one patient.^78^

Intraoperative explantation adverse events were reported in three studies. Klauke et al. and other authors reported two patients with loose tacks requiring removal, which led to a central retinal defect in one of these patients;^82-86^ Zrenner et al. reported one patient with a mild skin infection of the retroauricular cable exit;^14^ and Fujikado et al.^23^ found no intraoperative adverse events during explantation surgery.

Post-explantation adverse events were reported in three studies. Klauke et al. and other authors found mild epiretinal gliosis formation at the tack fixation site in four patients and a temporary decrease in visual acuity in one patient through the 6-month followup visit.^82-86^ Stingl et al. reported a retinal detachment immediately after explantation, which was treated surgically and resolved with local retinal fibrotic changes in one patient.^63,64^ Fujikado et al.^23^ reported no post-explantation adverse events.

Five investigators categorized adverse events as serious or nonserious and did not tie those events to a specific followup time. Arevalo et al.,^65,66^ Zrenner et al.,^14^ and Rizzo et al.^78^ reported that no serious adverse events occurred throughout the study period. Stingl et al.^63,64^ reported IOP elevation to 46 mm Hg in one patient, which was treated without sequel. Ho et al. and other authors^15,30,67-74^ reported subconjunctival erosion and hypotony in four patients, conjunctival dehiscence and presumed endophthalmitis in three patients, and corneal opacity, rhegmatogenous retinal detachment, tractional and serous retinal detachment, retinal tear, uveitis, infective uveitis, and corneal melt in one patient each. Ho et al. reported that most serious adverse events occurred within the first 6 months after implantation and those that occurred more than 1 year after implantation were “part of a cascade of events that had begun earlier.”

Seven investigators reported the incidence of device-related adverse events. Arevalo et al.,^65,66^ Ayton et al.,^18^ Chow et al.,^22^ and Rizzo et al.^78^ reported that no device-related events occurred throughout the study followup period. Stingl et al.^63,64^ reported that an unspecified number of patients experienced infraorbital cable-part breaks due to stress from eye movements and one patient each experienced a device technical failure, retinal perfusion overlying the device, and retinal edema leading to device failure. Ho et al. and other authors^15,30,67-75^ reported that seven patients elected to have revision surgery, two patients required retacking, and one patient experienced fibrosis around the tack, but no device failures occurred. Through an average of 6.2 years of followup, 24 patients still had functioning devices. Seider and Hahn reported that one patient experienced tack malrotation and speculated that the patient's previously unrecognized posterior staphyloma made this adverse event more likely.^77^

The occurrence of adverse events over the course of long-term followup (>6 months) was reported by five investigators. Klauke et al. and other authors^82-86^ reported nonprogressive gliosis in four patients, slightly reduced visual acuity (in one case in association with retinal tack removal) in two patients, conjunctivitis in one patient, and an inflammatory reaction due to corneal sutures in one patient. Arevalo et al.^65,66^ reported edema in two patients, and elevated IOP, pain, suture irritation, and conjunctival erosion in one patient each over the approximate 1.5-year followup period. Ho et al. and other authors reported a long list of nonserious adverse events through the 3-year followup, with most occurring within the first year after implantation.^15,30,67-74^ The most common events included epiretinal membrane in 11 patients, conjunctival congestion in 10 patients, ocular pain in 9 patients, hypotony in 7 patients, suture irritation and choroidal detachment in 6 patients, and uveitis and macular edema in 5 patients. Additionally, both patients who received the Argus II implant and subsequently had a magnetic resonance imaging (MRI) scan experienced local moderate paramagnetic artifacts approximately 50×50 mm that precluded clear visualization of the intraorbital space near the implant. Chow et al.^22,79^ and Rizzo et al.^78^ found no adverse events at their studies' final followup visits, which occurred 6–18 months after implantation for 5 patients and 10 years for 1 patient for Chow and at 12 months for Rizzo.

Studies using the subretinal approach (ASR^22,79^ and Alpha IMS^14,63,64^ implanted in 38 patients total) reported the following adverse events: elevated IOP (3), aniseikonia (1), mild skin infection (1), subretinal bleeding that resolved quickly (1), syneresis of images seen in the implanted eye (1), and scratchiness (NR). The epiretinal approach (Argus II^15,30,67-76^ and EPIRET^82-86^3 implanted in 53 patients total) reported a larger variety of adverse events, including a large number of events classified as serious, including a central retinal defect, hypotony, presumed endophthalmitis, conjunctival erosion and dehiscence, corneal opacity, retinal detachment and tear, corneal melt, uveitis, and enucleation.

## Key Question 5A Off-label use of RPSs

### Description of Included Studies

We identified a single ongoing clinical trial of Argus II in severely sight-impaired patients with advanced dry AMD that is due to be completed in June 2019. We also identified two relevant press releases.

### Key Points

- One clinical trial of Argus II in patients with advanced dry AMD is ongoing.

### Detailed Synthesis

For the Argus II, the FDA indication is “for use in patients with severe to profound retinitis pigmentosa who meet the following criteria:

- Adults, age 25 years or older.
- Bare light or no light perception in both eyes. (If the patient has no residual light perception, then evidence of intact inner layer retina function must be confirmed.)
- Previous history of useful form vision.
- Aphakic or pseudophakic. (If the patient is phakic prior to implant, the natural lens will be removed during the implant procedure.)
- Patients who are willing and able to receive the recommended post-implant clinical followup, device fitting, and visual rehabilitation.”

In Europe, the device is approved for use in patients with slightly better, hand motion vision,^99^ and can be used in patients 18 years of age or older, based on patient recruitment at sites outside the United States.

Numerous reviews have suggested that patients with advanced AMD may be candidates for retinal prostheses and, outside of investigational studies, this would be an off-label use, according to FDA criteria. No completed studies in AMD have been identified, but one clinical trial is under way. See Table C-27.

One news release from November 2015 indicated that both Pixium Vision and Second Sight are developing next-generation products to target AMD.^100^ A 2015 press release of the American Society of Retina Specialists quotes one Argus II investigator suggesting that the company may explore the use of Argus II or another similar RPS in patients with a retinal detachment, whose retina has been reattached but whose vision has not been restored to an acceptable level.^99^

## Key Question 5B Other Uses of RPSs

We did not identify any information to address the use of RPSs for nonvisual uses. As noted above, one trial is ongoing, testing the Argus II device in patients diagnosed with dry AMD which, outside of an investigational trial, would be an off-label use (NCT02227498 (https://clinicaltrials.gov/ct2/show/NCT02227498)).

Other visual uses of RPSs include modifying the Argus II device for use as a cortical implant, Orion I (Second Sight, Sylmar, CA, USA), with human trials planned to commence in 2017.^101^