# Methods

The methods for this systematic review follow the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (available at http://www.effectivehealthcare.ahrq.gov/methodsguide.cfm) and the PRISMA checklist. See the review protocol (http://www.ahrq.gov/sites/default/files/wysiwyg/research/findings/ta/topicrefinement/rentinal-prosthesis-protocol.pdf) for full details.

## Topic Refinement and Review Protocol

With input from the Task Order Officer, we recruited Key Informants (KIs). As partners, the U.S. Centers for Medicare & Medicaid Services (CMS) representatives were included among our KIs. We selected additional KIs with expertise in each of the following areas: clinical and research ophthalmology, low vision and blindness rehabilitation research, patient advocacy, health care insurance administration, psychometrics, and industry. KIs were interviewed in groups of two to four.

Each KI must have disclosed any financial conflicts of interest (COIs) greater than $10,000 and any other relevant business or professional conflicts of interest. Perspectives of KIs with potential COIs were balanced by perspectives of other neutral participants. We asked ophthalmologists about retinal prosthesis system (RPS) candidate selection criteria—specifically about diagnoses, vision characteristics, age, and comorbidities. We also asked which management strategies for RPS devices should be compared with optimal care for RPS candidates and what comprises optimal care.

All KIs were asked which outcome measures could potentially be improved by RPS devices, in the following categories: vision, activities of daily living (ADLs), instrumental activities of daily living (IADLs), health-related quality of life (HRQoL), and others. All were asked about which outcome measures have empirically established favorable psychometric properties such as validity, reliability, and responsiveness. KIs were asked to what extent their statements were based on evidence and if so, what evidence sources they considered. At the Evidence-based Practice Center (EPC), we used KI input to refine the literature search concerning the psychometric properties of outcome measures and to enhance our understanding of the strengths and limitations of available outcome measures. The EPC followed the requirements of the Office of Management and Budget in limiting the number of KIs asked the same questions to no more than nine participants. We submitted summaries of the discussion with the KIs to the Task Order Officer.

## Literature Search Strategy

### Search Strategy

#### Published Literature Searches

Medical librarians performed systematic literature searches following established systematic review protocols. In seeking references for RPS devices, we searched the following databases using controlled vocabulary and text words: Medline, EMBASE, Cumulative Index to Nursing and Allied Health (CINAHL), the Cochrane Library, and PubMed (unprocessed records only). The search concerning RPS devices covered the literature published from January 1, 2000, through April 25, 2016. This time frame was chosen because preliminary searches did not find relevant references before 2002, and early devices have either been abandoned or replaced by technologically improved versions in development or commercially available in some market. The literature search on psychometric properties of outcome measures covered the same databases as the device search but also included PsycINFO. Search limits spanned January 1, 1990, through April 25, 2016. Literature searches were updated after the draft report was posted to the AHRQ Technology Assessment Web site. Search strategies appear in Appendix A.

#### Gray Literature Search

Gray literature includes reports, articles, abstracts, and presentations produced by government agencies, private organizations, educational institutions, consulting firms, and corporations that typically do not appear in peer-reviewed journal literature. For this report, we searched gray literature sources to identify RPS manufacturers, obtain descriptions of RPS devices, and identify unpublished studies.

Among sources we consulted were conference proceedings over the past 3 years for the following organizations: the American Academy of Ophthalmology, the Association for Research in Vision and Ophthalmology, the American Society of Retina Specialists, and the Retina Society. We also searched the trial registry National Clinical Trials (ClinicalTrials.gov).

Web sites and databases associated with the following institutions and organizations were searched using text words: U.S. Food and Drug Administration (FDA), CMS, U.S. Centers for Disease Control and Prevention, Healthcare Common Procedure Coding System, National Guideline Clearinghouse, the UK's National Institute for Health and Care Excellence, Trip database, Healthcare Standards database, Medline Plus, Medscape, and MediRegs. ECRI Institute resources that we searched included reports produced for ECRI's subscribers and the periodical Health Devices. We also searched manufacturer and health care insurer Web sites. We requested that manufacturers and other stakeholders submit scientific information packets and other relevant information to the AHRQ Scientific Resource Center.

### Study Selection

We included RPS device articles that met the following criteria: it reported use of an RPS device in development or on the market, reported at least one patient-centered outcome, included any number of human participants with any retinal degeneration disorder or macular disorder diagnosis, described any study design, and was published in any language. We excluded studies of the IRIS system because the current version began studies only in late 2015. For psychometric properties (Key Question [KQ]1B and KQ1C), we required that articles be published in English; be primarily designed to evaluate reliability, validity, and/or responsiveness of relevant outcome measures; and have at least two-thirds of patients with very low vision (as defined by logarithm of the minimum angle of resolution [logMAR]≥1.0 and/or visual field≤20 degrees) due to retinal conditions. Correlations between different outcome categories (e.g., visual acuity and quality of life) were not taken as validity studies because they measure fundamentally different traits.

### Data Extraction

We performed redundant title and abstract screening using the Distiller SR tool (Evidence Partners, Ottawa, Ontario, Canada). All articles that were excluded by one reviewer in title and abstract screening were submitted to duplicate review. Only one reviewer's selection was required for full-text article retrieval. Dual independent review was performed on all full-text articles. Resolution of full-text article review disagreements was achieved by consensus. A PRISMA diagram was produced (see “Results of Literature Searches”).

Data extraction was performed by a single reviewer and was fully verified by a second reviewer. Extracted data are stored in Microsoft Word and Microsoft Excel files. Information extracted included the following: study design, psychometric properties assessment methods (from COnsensus-based Standards for the selection of health Measurement INstruments [COSMIN] checklist items),^61^ patient blinding to experimental condition, outcome assessor blinding to experimental condition, experimental condition randomly presented, number of outcome assessors, country/site, number of patients enrolled, patient inclusion criteria, patient exclusion criteria, RPS treatment details, prior treatment, concurrent treatment, study duration, diagnosis, age at diagnosis, age at implantation, eye implanted, time from implantation to study participation, sex, race, visual acuity at time of implantation, outcomes, and outcome definitions.

## Risk-of-Bias Assessment of Individual Studies

Because we did not expect to identify randomized controlled trials, our risk-of-bias assessment of RPS device studies focused on single-group designs (case series: pretest-posttest, posttest only, device ON/OFF, fellow eye). These risk-of-bias items have been selected from the AHRQ Methods Guide^62^:

- Does the design or analysis control or account for important confounding and modifying variables through matching, stratification, multivariable analysis, or other approaches?
- Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
- Did the study maintain fidelity to the intervention protocol?
- If attrition (overall or differential nonresponse, dropout, loss to followup, or exclusion of participants) was a concern, were missing data handled appropriately (e.g., intention-to-treat analysis and imputation)?
- Were the outcome assessors blinded to the intervention or exposure status of participants?
- Were outcomes assessed/defined using valid and reliable measures and implemented consistently across all study participants?
- Were the potential outcomes prespecified by the researchers? Are all prespecified outcomes reported?

Risk-of-bias assessment of studies addressing the effectiveness of RPS was based on seven predetermined items. To receive a rating of Low, studies needed to have a Yes response for the first five risk-of-bias items (confounder controlling, concurrent intervention controlling, intervention protocol fidelity, attrition handled appropriately, and outcome assessor blinding). For a rating of Moderate, studies needed at least three Yes responses on risk-of-bias items 1 through 5 and a Not Reported or Yes on items 6 and 7 (outcomes assessed using valid and reliable measures and outcomes prespecified by investigators). All other studies were rated High risk of bias.

Risk-of-bias assessment of studies addressing outcome-measures psychometric properties was based on the COSMIN checklist.^61^ This instrument was developed using rigorous methods including Delphi procedures. Items addressed the following domains: internal consistency, reliability, measurement error, content validity, structural validity, hypothesis testing, cross-cultural validity, criterion validity, and responsiveness.

## Data Synthesis

Because of the designs of the studies (i.e., single-group designs), this review was limited to qualitative synthesis. To permit a clear synthesis, we placed each reported outcome into one of seven categories:

- Visual function
- Visual acuity
- Visual field
- Color vision
- Laboratory-based visual performance measures
- Day-to-day function
- Vision-related quality of life

## Strength of the Body of Evidence

We used the strength-of-evidence grading approach described in the AHRQ Methods Guide.^62^ Domains addressed were study limitations, directness, consistency, precision, and reporting bias. If relevant, we also considered a dose-response association (e.g., whether more electrodes yielded greater effects) and magnitude of effect. We did not use the domain involving plausible confounders reducing an observed effect, because studies did not have separate control groups. We assigned a grade of High, Moderate, Low, or Insufficient, according to definitions stated below, in Table 3.

Table 3 Evidence grade definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable (i.e., another study would not change the conclusions).
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

Thus, when the evidence did not permit a conclusion (e.g., RPS either improves or does not improve an outcome), we graded the evidence as Insufficient. A lack of statistical significance was not assumed to imply the lack of an effect, since nonsignificance may simply mean low statistical power. We graded the strength of evidence only for KQ2 and the following outcomes because of their relative importance: visual acuity, visual field, laboratory-based visual performance measures, day-to-day function, and quality of life. We did not grade the strength of evidence for other outcomes or other KQs.

## Applicability

Factors of interest in assessing applicability focused on the framework defined by population, intervention, comparators, outcomes, timing, and setting (PICOTS). More specifically, applicability was determined mainly by patient-selection methods, patient-sample characteristics, intervention characteristics, and magnitude of effects on outcomes.

## Peer Review and Public Commentary

The full draft report was posted for public and peer review after review by the AHRQ EPC Task Order Officer and Associate Editor. Peer reviewers, chosen by methods similar to KI selection, were invited to provide written comments on the draft report based on their clinical, content, or methodologic expertise. Peer review comments on the preliminary draft of the report were considered by the EPC in preparation of the final report. The dispositions of the peer review comments will be documented and posted on the AHRQ Technology Assessment Program Web site.