# Introduction

Recent advances in technology have permitted the first attempts to “restore” sight by combining a patient's native intrinsic visual pathway with advanced light sensing, signal processing, and stimulation components in the form of an ocular prosthesis. With this technology, patients do not regain their lost vision, but instead learn how to interpret novel visual stimuli (artificial vision) for the purpose of improving their activities of daily living. Because of the novelty that this technology represents and the recent approval by the U.S. Food and Drug Administration (FDA) for use of one such system in patients with retinitis pigmentosa (RP), the Agency for Healthcare Research and Quality (AHRQ) commissioned an Evidence-based Practice Center to prepare this Technology Assessment to provide an overview of retinal prosthesis systems (RPSs). This assessment summarizes the current state of RPS technology as well as the existing evidence addressing the clinical utility of RPSs and potential future directions for research in areas in which information is limited.

## Background

### Retinitis Pigmentosa

The retina is the light-sensitive layer of tissue within the eye and is responsible for converting light into electrical impulses. These impulses are delivered through the visual pathway and interpreted in the visual centers of the brain, leading to sight. Central to this functioning is the outermost layer of the retina, the photoreceptors, including rods and cones. These cells act as the “ignition switch” that starts the process of sight by initiating the visual pathway. Diseases that preferentially affect the photoreceptors (or their support cells, the retinal pigment epithelium) are ideally suited for sight restoration by RPSs because the rest of the native pathway remains intact.

RP is one such disease. It is a collection of genotypically and phenotypically diverse eye disorders, all of which attack the rods and cones within the retina. This inherited disease is often identified by its main clinical features, which typically include symptoms of poor night vision, visual field loss, and peripheral flickering lights. As the disease progresses and more photoreceptors are lost, patients experience an indolent, progressive constriction of their visual field until legal and functional blindness occurs, typically by age 40.^1^ Upon ophthalmic examination, a triad of clinical findings is typically noted: attenuation of retinal blood vessels, “bone spicule” clumping and mottling of the retinal pigment epithelium (a single layer of pigmented cells that nourishes the retina photoreceptors), and optic nerve head pallor. All of these findings are a direct result of the main pathophysiologic action of RP, atrophy of the photoreceptor layer.

RP is thought to occur in 1 of every 4,000 people and affects nearly 1 million people worldwide.^2-5^ More than 100 different genes have been implicated as causing the various forms of RP, representing all possible modes of genetic inheritance—autosomal dominant, autosomal recessive, X-linked, and mitochondrial.^4^ Despite the numerous genes associated with RP, only 60 percent of the cases can be associated with a known mutation.^4^ Clinical and family histories are of extreme importance in the diagnosis of RP, because the time course of disease and prognosis are well correlated to the pattern of inheritance, with X-linked disease being the most severe and autosomal dominant RP having later onset and milder symptoms.^4,6^

Common to many inherited diseases, age of onset is typically early in life, with patients who have autosomal recessive inheritance first exhibiting symptoms at about age 10 and those with autosomal dominant inheritance around age 23.^7^ This age of onset is in contrast to other, more familiar vision-threatening maladies including cataracts, glaucoma, and age-related macular degeneration (AMD), all of which most commonly occur in elderly populations. Because of these population age differences, blindness from RP has much higher direct medical and societal costs than other common causes of vision loss.^8,9^

### Age-Related Macular Degeneration

The RP population, particularly those with vision poor enough to qualify for an RPS, is rather small. The broader goal for most of the companies developing retinal prosthesis technology would be for implementation in more common disease states. The most logical of these is late-stage nonexudative AMD, because many of the pathologic aspects of RP for RPS can also be found in AMD, namely physiologic damage limited to the outer retina. This work has already begun, with a clinical trial under way in patients with end-stage AMD and poor vision.^10^ AMD is the leading cause of irreversible visual loss in industrialized countries,^11^ and in the United States, it accounts for about half of severe sight loss. However, the number of patients with advanced AMD who could possibly benefit from RPS is much smaller.

Diagnosis of AMD does not depend on the presence of visual symptoms^12^ but can include metamorphopsia (distorted wavy vision), loss in visual acuity, blurred vision, scotoma (partially diminished area in the visual field), impaired color perception, and loss in contrast sensitivity. The American Academy of Ophthalmology AMD guideline adopts a disease classification system developed for the Age-Related Eye Disease Study (AREDS) and described in 2013 by Ferris et al.^13^ Early AMD is defined as a combination of multiple small drusen, few intermediate drusen, and mild retinal pigment epithelium (RPE) abnormalities (e.g., hyper- or hypopigmentation). Intermediate AMD can include numerous intermediate drusen, at least one large druse, or geographic atrophy (GA, defined as a sharply demarcated, usually round or oval area of atrophy of the RPE not involving the center of the fovea). Advanced AMD can involve one or more of the following features:

- GA of the RPE within the foveal center
- Choroidal neovascularization (CNV; choroidal angiogenesis extending through a defect in Bruch's membrane)
- Serous and/or hemorrhagic detachment of the neurosensory retina or RPE
- Retinal hard exudates
- Subretinal and sub-RPE fibrovascular proliferation
- Disciform scar

AMD is often separated into nonexudative/nonneovascular (“dry”) and exudative/neovascular (“wet”) subtypes. Dry AMD is more common, accounting for about 90 percent of cases. Advanced dry AMD is characterized by GA. Wet AMD can feature CNV or pigment epithelial detachment and progresses more rapidly than dry AMD.^11^

### Retinal Prosthesis Systems

Multiple types of ocular prosthetic devices are under development.^14-17^ The devices stimulate different parts of the visual pathway, including the visual cortex,^16^ the optic nerve,^17^ and the retina when placed in the suprachoroidal,^18^ epiretinal,^15^ and subretinal^14^ spaces. A literature search identified seven RPS devices for which there was at least one published article describing human recipients of the technology. Regarding placement of intraocular electrode arrays/stimulation components, three implants are inserted on the retinal surface (epiretinal), two are placed in a subretinal space, and two are implanted suprachoroidally.

In March 2013, the U.S. Food and Drug Administration provided guidance to industry with respect to pre-clinical and clinical testing of retinal prosthesis systems.^19^ For clinical testing, the document recommended (among other things) that studies identify a primary safety endpoint, that studies use effectiveness outcomes appropriate for the specific device (e.g., low-level visual acuity, grating acuity, spatial mapping of simulated visual phosphine fields, form vision assessment, orientation and mobility testing, activities of daily living, and self-reported patient outcomes), and that patients be followed for three years or longer.^19^

Of the seven RPS devices, the only one to date to receive FDA approval is the Argus II epiretinal RPS (Second Sight Medical Products, Inc., Sylmar, CA). Another device originating in the United States is the subretinal Artificial Silicon Retina (ASR), developed by Optobionics (Glen Ellyn, IL). The subretinal Alpha-IMS was created by Retina Implant AG (Reutlingen, Germany). Another German manufacturer is Fraunhofer IMS Biohybrid Systems (Duisburg, Germany), which developed the epiretinal EPIRET3 device. The IRIS device began development in Germany but is now produced by the French manufacturer Pixium Vision (Paris, France). The suprachoroidal Bionic Eye RPS comes from BionicVision in Parkville, Victoria, Australia. Nidek Co., Ltd. (Gamagori, Japan), produces the Suprachoroidal Transretinal Stimulation (STS) Artificial Vision System.

In 2011, the Argus II retinal prosthesis system was approved for use in Europe, which was followed by FDA approval in 2013 for use in the United States for patients with RP.^15^ This system has three parts: an implantable 60-electrode array, a pair of glasses with a video camera attached, and a video-processing unit worn typically on the belt of the user. The video camera captures surrounding visual images, which are processed by the wearable unit and transmitted wirelessly to the implanted array. The array then stimulates the inner retina with electrical impulses, which follow the “typical” visual processing pathway. The Argus II RPS is a second-generation unit, with the most notable difference from the first generation being an increase in the electrode-array size, from 16 to 60 electrodes.

The French manufacturer of the epiretinal IRIS device, Pixium Vision, uses extraocular and intraocular components similar to the Argus II, but the electrode array contains 150 electrodes.^20^ This company is also developing the PRIMA device, not yet implanted in humans, that uses similar extraocular components, including video camera input, but introduces subretinal microchips in modules of up to several thousand electrodes. The Argus II and IRIS devices use induction for energy and data transmission, and the German EPIRET3 uses video camera input with radiofrequency telemetric transmission from the eyeglass to a posterior chamber receiver. From the receiver, data are relayed via micro-cable to an epiretinal array containing 25 electrodes.

The German Alpha-IMS device may be distinguished from the Argus II, IRIS, and EPIRET3 devices because rather than providing data to the electrode array via a video camera, it uses incident light projected through the recipient's native lens.^21^ The subretinal microchip implant contains 1,500 pixels of photodiode-amplifier-electrode units that convert light into electrical pulses, delivered locally to overlying retinal neurons. A cable exits the sclera and orbit, leading to a periauricular subdermal coil that is coupled by transdermal magnetic induction with an external primary coil. A portable signal processor has knobs for adjusting contrast sensitivity and brightness.

The American Optobionics ASR device, like the Alpha-IMS device, uses incident light instead of video camera data as the input source for the prosthesis.^22^ The self-contained ASR is a disc-shaped microchip containing about 5,000 microphotodiodes, each with its own stimulating electrode. Fully powered by light, this is the only device used in humans so far that has no external power source.

An article on the Australian Bionic Eye has described the device in prototype form. This report detailed a suprachoroidal array with 33 stimulating electrodes.^18^ The prototype had a helical lead wire extended from the implant to a periauricular percutaneous connector. A head-mounted video camera provided data input to the implant. The manufacturer's Web site states that other prototypes have used 25 and 44 electrodes. Next-generation models will use an eyeglass-mounted video camera, an external vision processing unit that will connect to the camera, and arrays with 98 and 256 electrodes.

The Japanese STS Artificial Vision System (Nidek) is a suprachoroidal device connected to periauricular components fixed to the skull.^23^ An eyeglass-mounted video camera sends data to a controller, which relays it to a periauricular external coil coupled by induction with a secondary coil/decoder. A micro-cable extends to the array containing 49 electrodes.

Besides the seven devices for which our preliminary searches found published reports of human recipients, we identified five additional devices subjected to preclinical tests. The Boston Retinal Implant Prosthesis (Visus Technology, Inc., Boston, MA) uses a subretinal array of 16 electrodes that receives energy and data from an eyeglass-mounted video camera and radiofrequency coil, with assistance from a controller that performs image signal processing.^24^ Another American device, the Photovoltaic Retinal Prosthesis (Stanford University Palanker Laboratory) has a subretinal array of thousands of photodiodes that convert light pulses to bi-phasic pulses of electric current.^25^ The device's light source comes from an eyeglass-mounted LCD (liquid crystal display) microdisplay that receives images from a video camera. From Japan, the Okayama University-Type Retinal Prosthesis (OUReP) uses a unique approach of photoelectric dye molecules coupled to polyethylene film.^26^ The dye absorbs light and converts it into electric potentials. Thus the film, implanted in a subretinal space, acts as both the image receiver from incident light and neuron stimulator, with no external power source.

We identified a press release describing the Bio-Retina for use in patients with AMD. The device was created by an Israeli company, Nano-Retina, which was expected to start clinical trials in 2013, but our searches did not identify any completed human trials.^27^ Finally, our searches identified a patent for Iridium Medical Technology Co., Ltd., for a flexible artificial retina device. The company describes the technology as an implant comprised of photosensors, microelectrodes, and circuitry. The photosensors receive incoming light, and microelectrodes stimulate retinal neurons. The flexible nature of the apparatus allows it to conform to the shape of the eye so that the microelectrodes align with the retinal neurons.^28^ See Table 1 for more information.

Table 1 Retinal prosthesis system devices with published human studies

Device | Input Source | Signal Processor | Implant Placement | Electrode/Stimulation Array | Power Source
Alpha-IMS (Retina Implant AG, Germany) | Light projected through recipient's native lens | Part of external power supply; 2 knobs allow recipient to adjust contrast sensitivity and brightness | Subretinal | Microchip containing 1,500 pixels of photodiode-amplifier-electrode units that convert light into electrical pulses, delivered locally to overlying retinal neurons via microelectrodes; power supplied through subretinal polyimide foil that exits the eye through choroid and sclera through equator | Cable exits the orbit, leads to subdermal coil fixed onto skull behind the ear; external power supply and controller attaches by transdermal magnetic induction at external primary coil
Argus II (Second Sight Medical Products, Inc., United States) | Eyeglass-mounted video camera | Video processing unit (computer), mounted on belt or shoulder strap, attached by cable to camera and to eyeglass-mounted radiofrequency transmitter coil | Epiretinal | Electronics case fixed to sclera, secured by encircling scleral buckle containing an antenna/receiver; sclera-penetrating ribbon cable leads to the 60-electrode array | Part of video processing unit
Artificial Silicon Retina (Optobionics, United States) | Light projected through recipient's native lens | None | Subretinal | Microchip containing about 5,000 microscopic solar cells called microphotodiodes, each with its own stimulating electrode; self-contained, no cable | Microchip is powered by incident light
Bionic Eye (BionicVision, Australia) | Next-generation model will use eyeglass-mounted video camera | External vision processing unit will connect to camera | Suprachoroidal | 33 stimulating electrodes | Prototype helical lead wire extends to percutaneous connector
EPIRET3 (Fraunhofer IMS Biohybrid Systems, Germany) | Eyeglass-mounted camera in extraocular component with radiofrequency transmitter; sends data and energy telemetrically | Digital signal processor, in extraocular eyeglass component, calculates a stimulation pattern | Epiretinal | After lens removal, intraocular receiver unit placed in posterior chamber receives energy and data, sends pulses along micro-cable to 25 stimulation electrodes | Part of extraocular component, energy sent with radiofrequency telemetry, no cables connecting extraocular and intraocular components
IRIS (Pixium Vision, France) | Eyeglass-mounted camera in extraocular component with induction transmitter that sends data telemetrically | Eyeglass-mounted signal processer connected to pocket computer with tunable software, sends signals to induction transmitter | Epiretinal | Electronics case fixed to sclera sends ribbon cable through sclera to 150-electrode array | Unclear
Suprachoroidal Transretinal Stimulation (STS)/Nidek Artificial Vision System (Nidek Co., Ltd., Japan) | Eyeglass-mounted video camera and processor send data to controller | Controller sends data to external coil, coupled by induction to implanted secondary coil, which sends data to implanted decoder, which generates biphasic pulses across internal micro-cable to individual electrodes | Suprachoroidal | Electrode array has 49 electrodes, associated intravitreal return electrode | Battery attached to controller

#### Regulatory Aspects of RPS

The Argus II (Second Sight Medical), a second-generation unit, has been through multiple completed clinical trials.^29,30^ The FDA approval for the Argus II specifies that only patients with RP and the most severe loss of vision (light perception only or worse) in both eyes are eligible for device implantation. New quality-of-vision scales designed to better assess the changes and improvements in eyesight for patients with such severe vision loss are an active area of study.^31^

Second Sight Medical provides resources for implanting and operating the Argus II device. Surgeons receive instructions in screening patients for eligibility, along with a recommended clinical followup schedule. A video surgeon manual describes the surgical procedure for implanting the device. Additionally, a previously trained Argus II surgeon must be present during the first surgical implantation at any new institution. Because of these requirements, as well as the high cost and limited patient pool outlined by FDA, only 17 sites across the United States and Canada are certified for implanting the Argus II (http://www.secondsight.com/stutus-us-launch-en.html). Second Sight Medical gives clinical centers a device fitting manual with instructions on how to use all device components and requires training and qualification of personnel involved in fitting the Argus II RPS. A visual rehabilitation guide is available for low vision therapists, along with hands-on training.

The hands on-training includes a “face-to-face continuing education program.^32^ “An experienced therapist must attend the first rehabilitation session.”^32^

Device recipients receive a patient manual describing use of extraocular components. After initial therapy in the clinic, patients are referred for local blind rehabilitation integration training with the Argus II. “The challenge for these patients is to learn to integrate the newly restored vision in the context of their blindness skills.”^32^

### Alternative Treatments for Retinitis Pigmentosa and Age-Related Macular Degeneration

#### Retinitis Pigmentosa

No FDA-approved medications exist to reverse or slow the progression of RP. The current state of care is generally supportive in nature, focusing on maximizing the visual acuity of a patient (i.e., performing cataract surgery) and offering training with low-vision aids and services helping patients to function within their limited visual capacity.

The absence of a therapy is not for lack of effort, with most of the past focus being on nutritional supplements. Randomized clinical trials have been performed on potential treatments, including docosahexaenoic acid (DHA),^33,34^ lutein,^35^ vitamins A and E,^36^ and various combinations of these agents.^37,38^ Unfortunately, none of these studies showed a definitive benefit to patients with RP, with a possible small exception being vitamin A supplementation.^36^ These findings however, are not without controversy, because the benefit of vitamin A was seen only in electrophysiological testing and not in any psychophysical visual parameters perceivable by patients, despite 4 years of treatment. This is particularly important in light of the expansive literature of the potential harmful effects of excessive vitamin A supplementation.^39-43^ Transcorneal electrical simulation is being studied for treating RP.^44^

#### Pharmacologic Therapies

In RP, pharmacologic attempts have been made at neuroprotection through neurotrophic factors, with trials ongoing, but those that have reported have yet to show any efficacy.^45,46^ Although successful pharmacologic interventions have been developed for exudative AMD (e.g., intravitreal injection of a vascular endothelial growth factor [VEGF] inhibitor, such as aflibercept, bevacizumab, or ranibizumab, or photodynamic therapy with verteporfin), nonexudative AMD is still managed supportively.

#### Gene-based Therapies

Recent landmark clinical trials of RPE65 gene therapy for RPE65-related early onset retinal dystrophy, a form of RP, successfully rescued visual function and improved full-field sensitivity and pupillary light reflex in a small group of pediatric patients.^47-50^ Additionally, more recent gene therapy trials in patients with choroideremia^51^ and RPE65-mediated inherited retinal dystrophy.^52,53^ similarly found improved visual outcomes and retinal sensitivity. However, excitement for this modality has been tempered because a followup study conducted in patients with a recessive early-onset form (Leber congenital amaurosis) showed continued disease progression despite stable visual improvements over 3 years.^54^

Some cases of RP are due to mutations in the genes RPE65 and/or LRAT, and a 2014 study by Koenekoop^55^ administered a 7-day course of oral QLT091001, a synthetic retinoid replacement, to 14 enrolled patients with either mutation. After 2 years, three of 14 had sustained improvements in visual fields, and two of 14 had sustained improvements in visual acuity.

Although gene therapy is promising, two hurdles make its application to RP difficult. The first is the large number of genes that converge into the phenotype of RP. For each of the 100 genes that have been associated with RP, a new therapy would need to be developed, and even then it might not resolve all RP cases because the currently known genes do not represent 100 percent of the RP cases.^56^ Second, gene therapy appears to work best at rescuing failing tissue and does not appear be as effective once all function is lost. This would leave those who are currently blind without help and make early diagnosis and treatment imperative, a goal not always easily accomplished.

#### Stem Cell Therapy

Because dysfunction of the retinal pigment epithelium (RPE) occurs in both RP and AMD, RPE replacement strategies are being investigated. Some researchers are using pluripotent stem cells, which have been shown to preserve vision in animal studies. In 2011, an FDA multicenter trial of patients with dry AMD or Stargardt's disease was undertaken. Patients received subretinal injections of RPE cells produced from human stem cells. Some patients demonstrated improved visual acuity, improved color vision, and improved contrast/dark adaptation.^57^

Other investigators are testing whether transplanting an entire layer of RPE, as opposed to a cell suspension, is a viable approach, with animal trials underway. Other approaches include using patient-matched cell transplantation, which may eliminate or reduce the need for immunosuppression, brain tissue from fetuses, or umbilical cord stem cells. Clinical trials of each of these methods were initiated in 2013, 2012, and 2010, respectively.^57^

Finally, multiple studies are testing the use of bone marrow stem cells. Siqueira and colleagues have reported results for 20 patients with RP who received intravitreal injections of bone-marrow-derived stem cells. Vision-related quality of life improved at 3 months following the procedure, but was not significantly different from baseline at 12 months.^58^

#### Low-Vision Aids and Rehabilitation

Low-vision rehabilitation is a multidisciplinary effort to maximize a patient's quality of life despite limited vision.^59^ Ophthalmologists and optometrists make assessments and write prescriptions for any of a variety of low-vision aids that use magnification, enhanced lighting, and/or voice-recognition technologies. Optometrists or low-vision therapists dispense the devices, and occupational therapists and other health care professionals provide training. Some Veterans Health Administration hospitals offer specific programs for low-vision rehabilitation.

#### Blind Rehabilitation

For patients with ultra-low vision, such as light perception, blind rehabilitation skills are taught, with the aim of maintaining the patient's independence. Training includes instruction in using a long cane or a guide dog for walking, Braille or computer software that reads documents aloud, tactile markings on appliances, techniques for folding money to identify its value, and many smart phone apps.^60^

## Scope and Key Questions

### Scope of the Review

#### Key Questions

The first of two key objectives to be pursued in this report is to examine the psychometric properties (validity, reliability, and responsiveness) of outcome measures that have been reported in RPS device studies or may be used in the future. The second key objective is review of the evidence reported on the effects of RPS devices on patient-centered outcomes among patients with retinal degenerative disorders or macular disorders.

The scope of this review is defined below according to the population, intervention, comparators, outcomes, timing, and setting (PICOTS) framework (Table 2). Key questions (KQs) appear below.

Table 2 PICOTS framework

PICOTS component | Description
Patients | Individuals in the Medicare population with low vision and retinal degenerative disorders or macular disorders
Intervention | Retinal prosthesis system devices
Comparators | Best supportive care (both retinal degenerative disorders and macular disorders); pharmacologic therapy, photodynamic therapy, laser therapy (macular disorders)
Outcomes | Health-related quality of life, activities of daily living, instrumental activities of daily living, visual function, visual acuity, changes in concurrent treatments/supportive care
Timing | Any
Setting | Any

Key Question 1A: What outcome measures have been used in studies of RPSs?

Key Question 1B: What are the psychometric properties of the health-related quality of life (HRQoL), ability to perform activities of daily living (ADLs) and instrumental activities of daily living (IADLs), visual function, and other measures used in the studies?

Key Question 1C: What other reliable and valid measures could be used in future studies of RPSs to demonstrate improvement in HRQoL, ability to perform ADLs and IADLs, visual function, and other functions?

Key Question 2: What is the evidence that HRQoL, ability to perform ADLs and IADLs, visual function, and other outcomes are improved in patients who use an RPS compared with baseline (or device off or untreated eye) and compared with alternative treatments?

Key Question 3: What is the evidence that the use of an RPS arrests the progression of RP?

Key Question 4: What is the evidence on adverse events associated with the use of RPSs?

Key Question 5A: What is the evidence on off-label use of RPSs?

Key Question 5B: From a narrative review of the literature, are other uses suggested for RPSs?

Figure 1 presents an analytic framework that depicts KQs, populations, treatments, patient-centered outcome measures, and associated psychometric properties.

Figure 1 Analytic framework

Note: msr=measure. Circled numbers, e.g., [image] denote Key Questions addressed by the systematic review.

Figure 1 is an analytic framework diagram that depicts Key Questions, populations, treatments, patient-centered outcomes, and associated psychometric properties. The diagram begins with a left hand column describing patient populations. Two populations of patients with low vision consist of those with retinal degenerative disorders and those with macular disorders. Patients from each population proceed to the right in the diagram to receive treatments. The diagram shows that patients with retinal degenerative disorders receive a retinal prosthesis or best supportive care. Patients with macular disorders receive a retinal prosthesis, best supportive care, pharmacologic therapy, photodynamic therapy, or laser therapy. From the intersection of patient populations and treatment with retinal prostheses, the diagram moves rightward to depict Key Question 1A: What outcome measures have been used in studies of retinal prosthesis systems? Possible outcome measure categories include visual function, visual acuity, visual field, color vision, laboratory-based performance measures, day-to-day function, and quality of life. The diagram shows possible outcome measures used in identified retinal prosthesis studies and associated established or uncertain psychometric properties, depicting Key Question 1B: What are the psychometric properties of the health-related quality of life (HRQoL), ability to perform activities of daily living (ADLs), and instrumental activities of daily living (IADLs), visual function, and other measures used in the studies? The diagram shows possible outcome measures to be used in future retinal prosthesis studies and associated established psychometric properties, depicting Key Question 1C: What other reliable and valid measures could be used in future studies of RPSs to demonstrate improvement in HRQoL, ability to perform ADLs and IADLs, visual function, and other functions? The diagram shows that patients may receive retinal prostheses or other treatments and proceed to experience various outcomes, depicting Key Question 2: What is the evidence that HRQoL, ability to perform ADLs and IADLs, visual function, and other outcomes are improved in patients who use RPS compared to baseline (or device off or untreated eye) and compared to alternative treatments? The diagram shows that patients may receive retinal prostheses and proceed to various long-term outcomes, depicting Key Question 3: What is the evidence that the use of RPS arrests the progression of RP? The diagram shows that patients receiving retinal prostheses may experience adverse events, depicting Key Question 4: What is the evidence on adverse events associated with the use of RPS? The diagram shows that potential recipients of retinal prostheses include individuals with low vision and retinal degenerative disorders not limited to retinitis pigmentosa, along with those with macular disorders. Key Question 5 asks: What is the evidence on off-label use of RPS? Key Question 5B asks: From a narrative review of the literature, are there other uses that have been suggested for RPS?

## Organization of This Report

The remainder of this report is structured as follows:

- Methods, in which we detail our processes in performing the review
- Results, in which we summarize the evidence, separately for each KQ
- Discussion, in which we highlight our key findings, provide context, discuss limitations, and summarize evidence gaps
- References
- List of abbreviations and acronyms
- Appendix A of search strategies
- Appendix B of excluded studies
- Appendix C containing all evidence tables
- References for evidence tables