# Executive Summary

## Background

### Retinitis Pigmentosa

Retinitis pigmentosa (RP) is a collection of genotypically and phenotypically diverse eye disorders, all of which attack the rods and cones within the retina. This inherited disease is often identified by its main clinical features, which typically include symptoms of poor night vision, visual field loss, and flickering lights. As the disease progresses and more photoreceptors are lost, patients experience an indolent, progressive constriction of their visual field until legal and functional blindness occurs, typically by age 40.^1^ Loss of central vision occurs in very advanced RP or in atypical RP. Upon ophthalmic examination, a triad of clinical findings is typically noted: attenuation of retinal blood vessels, “bone spicule” clumping and mottling of the retinal pigment epithelium (a single layer of pigmented cells that nourishes the retina photoreceptors), and optic nerve head pallor. All of these findings are a direct result of the main pathophysiologic action of RP, atrophy of the photoreceptor layer.

### Age-related Macular Degeneration

The RP population, particularly those with vision poor enough to qualify for a retinal prosthesis system (RPS), is rather small. A paper by Grover and colleagues (1999) examined the visual abilities of 982 patients with RP, of whom 25 percent had visual acuity of 20/200 or worse in both eyes.^2^ Many of these patients had more vision than light perception, so they would not meet the U.S. Food and Drug Administration (FDA) indication for the approved Argus II RPS device (which requires light perception only, or worse). Thus, the broader goal for most of the companies developing retinal prostheses would be for implementation in more common disease states.

The most logical of these is late-stage age-related macular degeneration (AMD), because many of the pathologic aspects of RP for RPS can also be found in AMD, namely physiologic damage limited to the outer retina. AMD is the leading cause of irreversible visual loss in industrialized countries,^3^ and in the United States, it accounts for about half of severe sight loss. However, the number of patients with advanced AMD who could possibly benefit from an RPS is much smaller. Although the etiology is incompletely understood, AMD develops as a result of deposition of cellular debris—including lipids, amyloid, complement factors, and other components—in Bruch's membrane.^4,5^

### Retinal Prosthesis Systems

Multiple types of ocular prosthetic devices are under development.^6-10^ The devices have focused on stimulating different parts of the visual pathway, including the visual cortex,^8^ the optic nerve,^9^ and the retina when placed in the suprachoroidal,^10^ epiretinal,^7^ and subretinal^6^ spaces. Of the seven RPS devices for which there was at least one published article describing a study in humans, the only one to date to receive FDA approval is the Argus II epiretinal RPS (Second Sight Medical Products, Inc., Sylmar, CA). Another device originating in the United States is the subretinal Artificial Silicon Retina (ASR), developed by Optobionics (Glen Ellyn, IL). The subretinal Alpha-IMS was created by Retina Implant AG (Reutlingen, Germany). Another German manufacturer is Fraunhofer IMS Biohybrid Systems (Duisburg, Germany), which developed the epiretinal EPIRET3 device. The IRIS device (also epiretinal) began development in Germany but is now produced by the French manufacturer Pixium Vision (Paris, France). The suprachoroidal Bionic Eye RPS comes from BionicVision in Parkville, Victoria, Australia. Nidek Co., Ltd. (Gamagori, Japan), produces the Suprachoroidal Transretinal Stimulation (STS) Artificial Vision System. These devices are discussed in detail in the body of this report.

We also identified three additional devices subjected to preclinical tests. The Boston Retinal Implant Prosthesis (Visus Technology, Inc., Boston, MA) uses a subretinal array of 16 electrodes that receives energy and data from an eyeglass-mounted video camera and radiofrequency coil, with assistance from a controller that performs image signal processing.^11^ Another American device, the Photovoltaic Retinal Prosthesis (Stanford University Palanker Laboratory) has a subretinal array of thousands of photodiodes that convert light pulses to bi-phasic pulses of electric current.^12^ From Japan, the Okayama University-Type Retinal Prosthesis uses a unique approach with photoelectric dye molecules coupled to polyethylene film.^13^

### Alternative Treatments for Retinitis Pigmentosa and Age-Related Macular Degeneration

For RP, the current state of care is generally supportive in nature, focusing on maximizing the visual acuity of a patient (i.e., performing cataract surgery) and offering training with low-vision aids and services helping patients to function within their limited visual capacity. Some pharmacologic agents approved for other conditions may potentially maximize visual acuity in RP patients. (For example, the topical carbonic anhydrase inhibitor dorzolamide, used in open-angle glaucoma or ocular hypertension, may have an ancillary benefit of reducing cystoid macular edema in RP patients who have this feature of the disease).^14^ The absence of RP-specific FDA-approved medications is not for lack of effort, with most of the past focus being on nutritional supplements. Supportive care is offered to patients with nonexudative AMD. For those patients who smoke, they are advised to quit. Those with intermediate or advanced disease may be advised to take antioxidant vitamins and minerals to reduce the risk of progression. For the nonexudative patients who have progressed to exudative AMD, the main treatment is vascular endothelial growth factor (VEGF) inhibitor therapy.

### Scope and Key Questions

The scope of this review is defined in Table A according to the PICOTS framework (population, intervention, comparators, outcomes, timing, and setting; see Table A). Key questions (KQs) appear below. Figure A presents an analytic framework that depicts KQs, populations, treatments, patient-centered outcome measures, and associated psychometric properties.

Table A PICOTS framework

PICOTS component | Description
Patients | Individuals in the Medicare population with low vision and retinal degenerative disorders or macular disorders
Intervention | Retinal prosthesis system devices
Comparators | Best supportive care (both retinal degenerative disorders and macular disorders); pharmacologic therapy, photodynamic therapy, laser therapy (macular disorders)
Outcomes | Health-related quality of life, activities of daily living, instrumental activities of daily living, visual function, visual acuity, changes in concurrent treatments/supportive care
Timing | Any
Setting | Any

Figure A Analytic framework

Note: msr=measure. Circled numbers, e.g., [image] denote Key Questions addressed by the systematic review.

Figure 1 is an analytic framework diagram that depicts Key Questions, populations, treatments, patient-centered outcomes, and associated psychometric properties. The diagram begins with a left hand column describing patient populations. Two populations of patients with low vision consist of those with retinal degenerative disorders and those with macular disorders. Patients from each population proceed to the right in the diagram to receive treatments. The diagram shows that patients with retinal degenerative disorders receive a retinal prosthesis or best supportive care. Patients with macular disorders receive a retinal prosthesis, best supportive care, pharmacologic therapy, photodynamic therapy, or laser therapy. From the intersection of patient populations and treatment with retinal prostheses, the diagram moves rightward to depict Key Question 1A: What outcome measures have been used in studies of retinal prosthesis systems? Possible outcome measure categories include visual function, visual acuity, visual field, color vision, laboratory-based performance measures, day-to-day function, and quality of life. The diagram shows possible outcome measures used in identified retinal prosthesis studies and associated established or uncertain psychometric properties, depicting Key Question 1B: What are the psychometric properties of the health-related quality of life (HRQoL), ability to perform activities of daily living (ADLs), and instrumental activities of daily living (IADLs), visual function, and other measures used in the studies? The diagram shows possible outcome measures to be used in future retinal prosthesis studies and associated established psychometric properties, depicting Key Question 1C: What other reliable and valid measures could be used in future studies of RPSs to demonstrate improvement in HRQoL, ability to perform ADLs and IADLs, visual function, and other functions? The diagram shows that patients may receive retinal prostheses or other treatments and proceed to experience various outcomes, depicting Key Question 2: What is the evidence that HRQoL, ability to perform ADLs and IADLs, visual function, and other outcomes are improved in patients who use RPS compared to baseline (or device off or untreated eye) and compared to alternative treatments? The diagram shows that patients may receive retinal prostheses and proceed to various long-term outcomes, depicting Key Question 3: What is the evidence that the use of RPS arrests the progression of RP? The diagram shows that patients receiving retinal prostheses may experience adverse events, depicting Key Question 4: What is the evidence on adverse events associated with the use of RPS? The diagram shows that potential recipients of retinal prostheses include individuals with low vision and retinal degenerative disorders not limited to retinitis pigmentosa, along with those with macular disorders. Key Question 5 asks: What is the evidence on off-label use of RPS? Key Question 5B asks: From a narrative review of the literature, are there other uses that have been suggested for RPS?

KQ1A: What outcome measures have been used in studies of RPSs?

KQ1B: What are the psychometric properties of the health-related quality of life (HRQoL), ability to perform activities of daily living (ADLs) and instrumental activities of daily living (IADLs), visual function, and other measures used in the studies?

KQ1C: What other reliable and valid measures could be used in future studies of RPSs to demonstrate improvement in HRQoL, ability to perform ADLs and IADLs, visual function, and other functions?

KQ2: What is the evidence that HRQoL, ability to perform ADLs and IADLs, visual function, and other outcomes are improved in patients who use an RPS compared with baseline (or device OFF or untreated eye) and compared with alternative treatments?

KQ3: What is the evidence that the use of RPS arrests the progression of RP?

KQ4: What is the evidence on adverse events associated with the use of RPS?

KQ5A: What is the evidence on off-label use of RPS?

KQ5B: From a narrative review of the literature, are other uses suggested for RPS?

## Methods

### Literature Search Strategy

Medical librarians performed systematic literature searches following established systematic review protocols. In seeking references for RPS devices, we searched the following databases using controlled vocabulary and text words: Medline, EMBASE, Cumulative Index to Nursing and Allied Health (CINAHL), the Cochrane Library, and PubMed (unprocessed records only). The search concerning RPS devices covered the literature published from January 1, 2000, through April 25, 2016.

We included RPS device articles that met the following criteria: reported use of an RPS device in development or on the market, reported at least one patient-centered outcome, included any number of human participants with any retinal degeneration disorder or macular disorder diagnosis, described any study design, and was published in any language. We excluded studies of the IRIS system because the current version began studies only in late 2015. For psychometric properties (KQ1B and KQ1C), we required that articles be published in English; be primarily designed to evaluate reliability, validity, and/or responsiveness of relevant outcome measures; and have at least two-thirds of patients with very low vision (as defined by logarithm of the minimum angle of resolution [logMAR]≥1.0 and/or visual field≤20 degrees) due to retinal conditions. Correlations between different outcome categories (e.g., visual acuity and quality of life) were not considered validity studies because they measure fundamentally different traits.

We performed dual independent review of abstract and full articles using the Distiller SR tool (Evidence Partners, Ottawa, Ontario, Canada). Extracted data were stored in Microsoft Word and Microsoft Excel files. Please refer to the review protocol (http://www.ahrq.gov/sites/default/files/wysiwyg/research/findings/ta/topicrefinement/rentinal-prosthesis-protocol.pdf) for more details about the methods.

### Risk-of-Bias Assessment of Individual Studies

Because we did not identify any randomized controlled trials, risk-of-bias assessment of RPS device studies focused on single-group designs (case series: pretest-posttest, posttest only, device ON/OFF, fellow eye). We selected seven pertinent risk-of-bias items from the Agency for Healthcare Research and Quality (AHRQ) Methods Guide^15^ (i.e., control for confounding, concurrent interventions, fidelity to protocol, low attrition, outcome assessor blinding, outcome definition/implementation, and prespecified outcomes). Each study was categorized as Low, Moderate, or High risk of bias. For studies addressing psychometric properties of outcomes, we based risk-of-bias assessments on the COnsensus-based Standards for the selection of health Measurement INstruments (COSMIN) checklist.^16^ This instrument contains recommended items for internal consistency reliability, test-retest reliability, face validity, construct validity, and responsiveness.

### Data Synthesis

Due to the designs of the studies (i.e., single-group designs), this review was limited to qualitative synthesis. To permit a clear synthesis, we placed each reported outcome into one of seven categories: visual function, visual acuity, visual field, color vision, laboratory-based visual performance measures (e.g., functioning during a test such as finding a door), day-to-day function, and quality of life.

### Strength of the Body of Evidence

We used the strength-of-evidence grading approach described in the AHRQ Methods Guide.^15^ Domains addressed included the following: study limitations, directness, consistency, precision, and reporting bias. If relevant, we also considered a dose-response association (e.g., whether more electrodes yielded greater effects) and magnitude of effect. We did not use the domain involving plausible confounders reducing an observed effect, because studies did not have separate control groups. Based on the domains, we assigned a grade of High, Moderate, Low, or Insufficient, according to definitions stated below. See Table B for more information.

Table B Evidence grade definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable (i.e., another study would not change the conclusions).
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

Thus, when the evidence did not permit a conclusion (that RPS either improves or does not improve an outcome), we rated the evidence as Insufficient. A lack of statistical significance was not assumed to imply the lack of an effect, since nonsignificance may simply mean low statistical power. We rated the strength of evidence only for KQ2 and the following outcomes because of their relative importance: visual function and visual acuity, visual field, laboratory-based visual performance measures, day-to-day function, and quality of life. We did not rate the strength of evidence for other outcomes or other KQs.

## Results

### Results of Literature Searches

We recorded our process of reducing our initial list of 6,022 potentially relevant publications to a final included set of 40 publications. We excluded 2,647 publications at the title level (they were not relevant to the topic), and another 2,771 at the abstract level. The most common reasons for exclusion at the abstract level were wrong population (1,112 exclusions) and a lack of psychometric property data in studies being considered for KQ1B or KQ1C (890 exclusions). We examined 603 articles in full, and excluded 565 of these for various reasons, the most common being wrong or unclear population (225 exclusions) and no psychometric data (120 exclusions). A complete list of articles excluded at the full-text level appears in Appendix B. Two included articles had been identified by peer reviewers. The 40 included publications described 21 unique studies.

### Key Question 1A Outcome Measures Used in RPS Studies

- For KQ1A we included 30 publications of 11 RPS studies.
- The 30 publications reported 74 different outcomes. Most outcomes involved either visual function (31 percent), visual acuity (26 percent), or laboratory-based visual performance measures (30 percent). Four studies measured day-to-day visual function, and one study measured vision-specific quality of life 3 weeks after implantation and at 5 months and 2 years after planned explantation.
- Only three outcomes were reported by three or more studies: the percentage of patients who passed the light localization task of the Basic Assessment of Light and Motion (BaLM), the percentage of patients whose square localization results were significantly better with system ON than system OFF, and the percentage of patients whose Grating Visual Acuity test results were significantly better with the system ON versus OFF. Seven other outcomes were reported by two studies each. Little consensus exists among authors of RPS studies about which specific measures are important.

### Key Question 1B Psychometric Properties of Outcome Measures Used in RPS Studies

- The Early Treatment Diabetic Retinopathy Study (ETDRS), a measure of visual acuity, has acceptable test-retest reliability, but no included studies measured its validity or responsiveness.
- The Grating Acuity Test (GAT) and the Chow Color Test (CCT) have acceptable test-retest reliability and construct validity, but no included studies measured their responsiveness.
- The Functional Low-Vision Observer Rated Assessment (FLORA) has acceptable face validity, but no included studies measured its reliability or responsiveness.

### Key Question 1C Psychometric Properties of Other Possible Outcome Measures

- For measuring light sensitivity, the full-field flash test (also known as the full field stimulus test) has better psychometric properties than either dark adaptometry with SST-1 or dark-adapted Humphrey perimetry. For the latter two tests, many patients with RP do not provide measurable or reliable results. The full-field flash test has acceptable test-retest reliability and construct validity.
- For measuring contrast sensitivity, the Grating Contrast Sensitivity (GCS) has better test-retest reliability than the Pelli-Robson test. The Pelli-Robson test may not produce meaningful results in some patients with RP, because of their limited vision.
- The FAST instrument (Functional Assessment of Self-Reliance on Tasks) has acceptable reliability, validity, and responsiveness. Further, its psychometric properties are better than those of the Veterans Health Administration-13 (VA-13). Both clinician-completed and patient-completed versions of the FAST instrument have reliability and responsiveness, but they yield somewhat different answers.
- The Very Low Vision Instrumental Activities of Daily Living (IADL-VLV) and the Modified National Eye Institute Visual Function Questionnaire 25-item (NEI-VFQ-25) plus supplement have acceptable reliability, validity, and responsiveness.
- The Modified Impact of Vision Impairment (IVI) has acceptable reliability and validity, but no included studies measured its responsiveness.

### Key Question 2 Effect of RPS on Health-related Quality of Life, Activities of Daily Living, Visual Function, and Other Outcomes

- Some patients clearly benefit from RPS, but evidence is insufficient to estimate the proportion of patients who would benefit. Some patients improved on visual function, visual acuity, visual field, color vision, laboratory-based function, and day-to-day function but not quality of life.
- Visual function was improved in 40 percent to 100 percent of patients with an implanted device.
- Visual acuity was improved in 0 percent to 100 percent of patients with an implanted device.
- Visual fields were improved in 17 percent to 100 percent of patients with an implanted device.
- One study assessed color vision and found one of six patients improved.
- Laboratory-based visual performance measures were varied and patients improved on some tasks but not others.
- Day-to-day function measures were varied, and patients improved on some tasks but not on others. Results from FLORA, the only validated measure used to assess day-to-day function, found patients improved on most tasks assessed with these exceptions: travel within the home independently, identify bottom steps, negotiate stairs, chop food, heat/reheat food, and maintain safety from falls.
- Quality of life was assessed in one study using the NEI-VFQ-25-German version, which the authors note has not been validated in an RP population. They found no significant change in six patients 3 weeks after implantation or after planned explantation (at 5-month and at 2-year followup).

### Key Question 3 RPS to Arrest the Progression of Retinitis Pigmentosa

- Limited evidence has been interpreted as possibly indicating that implanted RPS devices may stop the progression of RP. Patients implanted with the Argus II for 12 months experienced improved visual fields even when the system was in OFF mode.
- Evidence from animal studies has suggested a possible neuroprotective effect from electrical stimulation of the retina, mediated through induction of certain growth factors.
  ○ Electroretinographic waveforms in rat eyes with an active implant experienced temporary preservation compared with unoperated rat eyes through 6–7 weeks of followup.
  ○ Electroretinographic b-waves were significantly larger in rat eyes with active implants versus rat eyes without active implants at the 4- to 6-week followup.
  ○ Rat eyes with and without active implants had similar results for electroretinographic a-waves.
  ○ Rat eyes with active implants had four to six rows of photoreceptors, compared with a single sparse layer of photoreceptor cells in unoperated eyes 8 weeks after implantation.
  ○ Photoreceptor preservation occurred in all rat eyes that received an implant, even if it was an inactive implant.
  ○ Expression of fibroblast growth factor 2 (Fgf2) was significantly higher in rat eyes with active implants by postoperative day 9 compared with eyes with minimally active implants, eyes that underwent sham surgery, and unoperated eyes, and a dose-response relationship was evident.
  ○ Rat eyes with active implants and those without an active implant were similar on growth factor expression of fibroblast growth factor 1 (Fgf1), ciliary neurotrophic factor (Cntf), insulin-like growth factor (Igf), glial cell line–derived neurotrophic factor (Gdnf), and brain-derived neurotrophic factor (Bdnf).

### Key Question 4 Adverse Events of RPS

- Intraoperative adverse events occurred in more than half of studies reporting this outcome, with injury to the optic nerve being the most serious.
- Postimplantation adverse events were common and typically mild, including inflammation, temporary intraocular pressure increase, eye scratchiness, and eye-movement restrictions.
- Intraoperative explantation adverse events were reported in two-thirds of the studies reporting this outcome, the most serious being a central retinal defect caused by removal of loose tacks.
- Post-explanation adverse events were reported by two-thirds of the studies reporting this outcome, with the most serious events including a decrease in visual acuity and a retinal detachment.
- Serious adverse events were reported by just under half of the studies reporting this outcome and included intraocular pressure increase, hypotony, and presumed endophthalmitis.
- Device-related adverse events were reported by more than one-third of studies reporting this outcome and included device failure and need for retacking.
- Adverse events at the long-term followup were reported by just over half of studies reporting this outcome and were varied.

### Key Question 5A Off-label Use of RPS

- One clinical trial of Argus II in patients with advanced dry AMD with central geographic atrophy who are legally blind is under way and due to be completed by June 2019.

### Key Question 5B Other Uses of RPS

- We did not identify any studies of RPS devices being used for nonvisual purposes, although this technology is being used to create cortical implants.

## Discussion

### Key Findings and Strength of Evidence

The RPS studies assessed in this review reported 74 different outcomes, mostly dealing with visual function (31 percent), visual acuity (26 percent), or laboratory-based visual performance measures (30 percent). Day-to-day visual function and quality of life were rarely measured. Little consensus exists among authors of RPS studies about which specific measures are important.

There is some evidence for the validity and/or reliability of the ETDRS visual acuity, GAT, CCT, and FLORA. No included evidence on patients with very low vision addressed the validity or reliability of other outcomes reported in the RPS studies.

Future RPS studies should consider measuring the following outcomes because some evidence shows that they are valid and/or reliable measures: full-field flash test (tested in RP patients but most had much better vision than RPS recipients), GCS (tested in legally blind patients), the patient and clinician version of the FAST instrument (tested in populations with better eye mean logMAR 1.3 and 1.09, which is much better vision than RPS recipients' vision), IADL-VLV(tested in patients with mean 2.3 logMAR (CF) which is slightly better than RPS recipients' vision)) NEI-VFQ-25 plus supplement (tested in patients with mean logMAR 1.00, much better than RPS patients), and IVI (tested in a majority of patients with CF to LP vision including 14% with worse than LP, so very applicable to RPS recipents). Until better evidence is available, it appears that these tests hold the most promise.

During our interviews with Key Informants, particularly patient/advocate Key Informants, we learned that patients vary in their expectations of a treatment such as RPS implantation. Some patients hope to have their sight restored to “normal” vision. Others would be satisfied with more modest gains, such as the ability to color coordinate their clothing, use a color-contrast cutting board, or, for those patients with comorbid insulin-dependent diabetes, give themselves insulin injections.

One patient who had a good experience with the Argus II device and who was not a Key Informant but commented on our draft report, described his/her experience (the person's sex was not identified), which may reflect a more realistic expectation of RPS implantation. The patient reported that his/her eye had healed sufficiently after just a few weeks and vision improved instantaneously. This patient reported the following improvements:

- Identified the window where the light was coming from
- Located various items hanging on office walls
- Spotted the left and right sides of a doorway
- In conversation, looked a person squarely in the face (rather than trying to aim his/her eyes toward the voice)
- Saw a fireworks display for the first time in 25 years
- Walked with confidence with a white cane on city streets, avoiding the tables and chairs at sidewalk cafes
- Saw his/her two grandchildren standing before him/her and identified them without needing to hear their voices.^17^

Retinal surgeons performing RPS implantation need to accurately present the full range of likely visual acuity gains—which at this point do not include “normal” vision, color vision, or a level of sight sufficient to allow a diabetic to safely self-administer insulin. Surgeons also need to advise patients of the possibility that they may not benefit from an implant and could lose residual light perception after implantation.

When choosing outcomes to include in future RPS studies, investigators should routinely measure quality of life (QoL) and ADLs in addition to traditional visual acuity measures because these measures are interrelated. QoL and ADLs should be measured with the IVI and IADL-VLV and FLORA, respectively, because these are the measures with the most evidence of being valid in patients with vision similar to that seen in a RPS population. The Modified NEI-VFQ-25 plus supplement and FAST also measure QoL and function, respectively, but were tested in patients with much better vision than is typical of RPS recipients. Small gains in any vision measure (acuity, visual field, contrast sensitivity, color vision) has the potential to bring about clinically meaningful changes in QoL and ADLs from the patient's perspective.

Although some patients clearly experienced improved visual acuity, visual field, and visual function, the percentages varied greatly among studies of Moderate to High risk of bias. Thus, evidence is insufficient to estimate the proportion of patients who will benefit from an RPS.

There is some suggestion, based on both animal and human studies, that RPSs may have a neuroprotective effect that causes at least a temporary increase in vision in areas far away from the implantation site.

See Table C for strength of evidence grades for the evidence on beneficial outcomes.

Table C Strength of evidence for effectiveness

Strength-of-Evidence Domain | Visual function | Visual Acuity | Visual Field | Laboratory-based Visual Performance Measures | Day-to-Day Function | Quality of Life^a^
Study limitations | High | High | Moderate | Moderate | High | Moderate
Directness | Direct | Direct | Direct | Direct | Direct | Direct
Consistency | Inconsistent | Inconsistent | Inconsistent | Inconsistent | Inconsistent | Inconsistent
Precision | Imprecise | Imprecise | Imprecise | Imprecise | Imprecise | Imprecise
Reporting bias | Undetected | Undetected | Undetected | Undetected | Undetected | Undetected
Strength of evidence | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

a Quality of life measurement in the single study measuring it was used to detect adverse consequences following device explantation.

Intraoperative adverse events were reported in more than half of all included studies, the most serious of which included injury to the optic nerve and central retinal defect. Postimplantation adverse events were common and typically mild, including inflammation, temporary intraocular pressure increase, eye scratchiness, and eye-movement restrictions. Serious adverse events were reported by just under half of the studies reporting this outcome and included intraocular pressure increase, hypotony, and presumed endophthalmitis. Device explantation occurred in 3 out of 47 patients implanted with the Argus II device. Devices were explanted at 14 months, 3.5 years and 4.3 years, respectively. Reasons for explantation included recurrent conjunctival erosion (2 patients) and chronic hypotony and ptosis (1 patient).

### Applicability

The patients enrolled in the 11 included RPS publications had RP, choroideremia, rod-cone dystrophy, or Bardet-Biedl syndrome and very low vision (counting fingers to no light perception) and are representative of patients who will receive RPS devices in the future. Because there are no other treatments for patients with late-stage disease, the comparators used in these studies (pre- vs. post-implantation, system ON vs. OFF) were appropriate.

The maximum duration of study followup was 10 years for one patient with the ASR device. In the Argus II study, 24 of 30 patients still had functioning devices at a mean of 6.2 years followup. Because patients as young as 25 years of age may receive this device, longer-term followup is needed. One single-patient cadaver study suggested that the Artificial Silicon Retina device had a functional life expectancy of about 20 years.

Outcomes reported in these studies were varied, making study-to-study comparisons difficult. They were often not measured with tools that have been shown to be valid and/or reliable in very low-vision populations.

Only a limited number of sites are permitted to perform Argus II surgery, but that number will increase over time. As the procedure diffuses more widely, outcomes may vary from those at the clinical trial sites, which have received significant training and other resources for surgeons and other personnel involved in caring for the participating patients.

### Evidence Gaps/Future Research Recommendations

The first identified gap is the paucity of direct information about how RPS affects quality of life. Only one of the 11 included RPS studies reported data on a quality-of-life instrument (NEI-VFQ-25-German Version). Authors reported no statistically significant change in QoL at 3 weeks after implantation or during the 2-year study period after planned explantation of the device. This does not mean there was no change, because the study was too small (only 6 patients enrolled, and only 5 at final follow up) to rule out the possibility of a difference, and the instrument, albeit tested in a low-vision population, may not have been sensitive enough to measure change in this ultra-low vision population. We recognize that the other reported outcomes (visual acuity, laboratory-based measures of function, day-to-day function) may be surrogates for QoL (on the premise that improved acuity will translate into improved quality of life). However, these outcomes are less patient-oriented than QoL itself.

The second identified gap is the inability to estimate the proportion of patients who would improve after RPS implantation. Because studies used different devices, different comparators, and different outcomes (see previous section), there can be no single estimate of the proportion, because all of these aspects will likely affect improvement rates. Even controlling for the type of RPS, there was too much outcome heterogeneity to permit an estimate.

A third gap is our inability to predict which patients will benefit from these devices. Arevalo and colleagues^18,19^ and Chow and colleagues^20,21^ report that younger patients have better outcomes following surgery and both sets of authors speculate that this is a result of younger patients having healthier retinas than older patients. However, both studies enrolled fewer than 10 patients each so more studies are needed to replicate this finding.

A fourth gap involved psychometric testing of outcome measures in patients with very low vision (K1A and KQ1B). The studies we found used relatively advanced methods for testing psychometric properties (i.e., Rasch-based analysis, separation of item difficulty from person ability). Several of these studies had devised new instruments specifically for people with very low vision. The 11 included RPS studies, however, generally did not use these tests (an exception was the studies of the Artificial Silicon Retina by Chow et al. and Geruschat et al.,^20-22^ which also provided psychometric properties of certain tests). We encourage greater use of tested instruments in future studies of RPS. With greater consistency of outcome measures, future evidence reviews might be able to estimate the likelihood of improvement after RPS implantation.

Although this is not necessarily a gap, we note that we found limited information on potential other uses or off-label use of RPS devices. RPS technology is being used as the basis for creating cortical implants. One review article described that the Argus II device is being modified for use as a cortical implant, Orion I (Second Sight, Sylmar, CA, USA), with human trials planned to commence in 2017. There is also one ongoing clinical trial examining use of the Argus II in severely sight-impaired patients with advanced dry AMD.

### Conclusion

Some patients clearly benefit from implantation with an RPS, but determining who those patients are is still a challenge. Future studies of retinal prostheses devices should make an effort to report valid and reliable measures of important outcomes, especially day-to-day function and QoL.

## Executive Summary References

1 Heckenlively JR. (1988). Retinitis pigmentosa.
2 Grover S, Fishman GA, Anderson RJ, et al. (1999). Visual acuity impairment in patients with retinitis pigmentosa at age 45 years or older. Ophthalmology.
3 Bowling B. Acquired macular disorders In: Kanski's Clinical Ophthalmology: A Systematic Approach.
4 Nunes RP, Rosenfeld PJ, de Amorim Garcia, Filho CA, et al. Age-related macular degeneration. Ophthalmology.
5 Bressler SB, Bressler NM. (2013). Age-related macular degeneration: non-neovascular early AMD, intermediate AMD, and geographic atrophy. Ryan SJ, editor. Retina.
6 Zrenner E, Bartz-Schmidt KU, Benav H, et al. (2011). Subretinal electronic chips allow blind patients to read letters and combine them to words. Proc Biol Sci.
7 Humayun MS, Dorn JD, da Cruz L, et al. (2012). Interim results from the international trial of Second Sight's visual prosthesis. Ophthalmology.
8 Dobelle WH, Quest DO, Antunes JL, et al. (1979). Artificial vision for the blind by electrical stimulation of the visual cortex. Neurosurgery.
9 Veraart C, Raftopoulos C, Mortimer JT, et al. (1998). Visual sensations produced by optic nerve stimulation using an implanted self-sizing spiral cuff electrode. Brain Res.
10 Ayton LN, Blamey PJ, Guymer RH, et al. (2014). First-in-human trial of a novel suprachoroidal retinal prosthesis. PLoS ONE.
11 Rizzo JF, Shire DB, Kelly SK, et al. (2011). Overview of the Boston retinal prosthesis: challenges and opportunities to restore useful vision to the blind. Conf Proc IEEE Eng Med Biol Soc.
12 Mandel Y, Goetz G, Lavinsky D, et al. (2013). Cortical responses elicited by photovoltaic subretinal prostheses exhibit similarities to visually evoked potentials. Nat Commun.
13 Alamusi, Matsuo T, Hosoya O, et al. (2015). Vision maintenance and retinal apoptosis reduction in RCS rats with Okayama University-type retinal prosthesis (OUReP^TM^) implantation. J Artif Organs.
14 Liew G, Moore AT, Webster AR, et al. (2015). Efficacy and prognostic factors of response to carbonic anhydrase inhibitors in management of cystoid macular edema in retinitis pigmentosa. Invest Ophthalmol Vis Sci.
15 (2014). Methods guide for effectiveness and comparative effectiveness reviews.
16 Mokkink LB, Terwee CB, Patrick DL, et al. (2010). The COSMIN checklist for assessing the methodological quality of studies on measurement properties of health status measurement instruments: an international Delphi study. Quality of life research: an international journal of quality of life aspects of treatment, care and rehabilitation.
17 (2016). Personal Communication: patient comment.
18 Arevalo JF, Al Rashaed S, Kahtani ES, et al. (2015). The Argus II retinal prosthesis in RP patients: surgical and functional outcomes from the KKESH Collaborative Retina Study Group [slide presentation].
19 Arevalo JF, Mura M, Al Rashaed S. (2015). The Argus II retinal prosthesis: surgical and functional outcomes in younger retinitis pigmentosa (RP) patients [poster PO267; slide set].
20 Chow AY, Bittner AK, Pardue MT. (2010). The artificial silicon retina in retinitis pigmentosa patients (an american ophthalmological association thesis). Trans Am Ophthalmol Soc.
21 Geruschat DR, Bittner AK, Dagnelie G. (2012). Orientation and mobility assessment in retinal prosthetic clinical trials. Optom Vis Sci.
22 Chow AY, Chow VY, Packo KH, et al. (2004). The artificial silicon retina microchip for the treatment of vision loss from retinitis pigmentosa. Arch Ophthalmol.