# Peer Reviewers

Before publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers appears below:

- Cagri G. Besirli, M.D., Ph.D.
  Assistant Professor, Ophthalmology and Visual Sciences
  Kellogg Eye Center
  University of Michigan
  Ann Arbor, MI
- Emily Y. Chew, M.D.
  Deputy Director, Division of Epidemiology and Clinical Applications
  Deputy Clinical Director
  National Eye Institute
  Bethesda, MD
- Ninel Z. Gregori, M.D.
  Associate Professor of Clinical Ophthalmology
  Bascom Palmer Eye Institute
  Chief, Ophthalmology Section
  Miami Veterans Affairs Medical Center
  Miami, FL
- Flora Lum, M.D.
  Vice President, Quality and Data Science
  American Academy of Ophthalmology
  San Francisco, CA