# Acknowledgments

The authors acknowledge Dr. Craig A. Umscheid, M.D., M.S.C.E., Senior Associate Director of ECRI–Penn Medicine AHRQ Evidence-based Practice Center for recruiting clinical investigator Brian L. VanderBeek, M.D., M.P.H., M.S.C.E. We also gratefully acknowledge the skilled facilitation of our Key Informant calls by Meg Tucker, M.S.P.H., Senior Research Associate at Insight Policy Research, Inc. We would like to thank the following individuals at ECRI Institute for their contributions to this project: Janice Kaczmarek, M.S., Eloise DeHaan, E.L.S., Lydia Dharia, Helen Dunn, Gina Giradi, M.S., and Kristina McShea, M.S.L.I.S. We also thank our AHRQ Task Order Officer Elise Berliner, Ph.D.