# Appendix C Evidence Tables

Table C-1 General information about studies included for Key Question 1B

Table C-2 Patient characteristics in studies included for Key Question 1B

Table C-3 Measures tested in studies included for Key Question 1B

Table C-4 Psychometric data reported in studies included for Key Question 1B

Table C-5 Risk-of-bias of data reported in studies included for Key Question 1B

Table C-6 General information about studies included for Key Question 1C

Table C-7 Patient characteristics in studies included for Key Question 1C

Table C-8 Measures tested in studies included for Key Question 1C

Table C-9 Psychometric data reported in studies included for Key Question 1C

Table C-10 Risk of bias of data reported in studies included for Key Question 1C

Table C-11 Description of RPS study design, selection criteria, and treatment

Table C-12 Baseline demographics in RPS studies

Table C-13 Visual function and visual acuity outcomes in RPS studies

Table C-14 Visual field results in RPS studies

Table C-15 Color vision results in RPS studies

Table C-16 Laboratory-based visual performance measure results in RPS studies

Table C-17 Day-to-day function assessment in RPS studies

Table C-18 Quality of life assessment in RPS studies

Table C-19 Risk-of-bias assessment for visual function outcomes in RPS studies

Table C-20 Risk-of-bias assessment for visual acuity outcomes in RPS studies

Table C-21 Risk-of-bias assessment for visual field outcomes in RPS studies

Table C-22 Risk-of-bias assessment for color vision outcomes in RPS studies

Table C-23 Risk-of-bias assessment for laboratory-based visual performance measures in RPS studies

Table C-24 Risk-of-bias assessment for day-to-day function outcomes in RPS studies

Table C-25 Risk-of-bias assessment for quality of life outcomes in RPS studies

Table C-26 Adverse events in RPS studies

Table C-27 Ongoing clinical trials of Argus II device (6 studies)

Table C-28 Ongoing clinical trials of retina implant model Alpha/Bionic Eye (2 studies)

Table C-29 Ongoing clinical trials of IRIS (2 studies)

Table C-30 Ongoing clinical trial of implantable miniature telescope

Table C-31 Ongoing clinical trial of encapsulated human NTC-201 cells releasing ciliary neurotrophic factor (CNTF) implant

Table C-32 Ongoing clinical trial of brimonidine intravitreal implant

Table C-33 Ongoing clinical trials of other treatments on the horizon (10 studies)

Table C-34 Ongoing clinical trials examining genetic aspects of retinal degenerative disorders (2 studies)

## Reference List for Evidence Tables

1 Geruschat DR, Flax M, Tanna N, et al. (2015). FLORA: Phase I development of a functional vision assessment for prosthetic vision users. Clin Exp Optom.
2 Bittner AK, Jeter P, Dagnelie G. (2011). Grating acuity and contrast tests for clinical trials of severe vision loss. Optom Vis Sci.
3 Chow AY, Bittner AK, Pardue MT. (2010). The artificial silicon retina in retinitis pigmentosa patients (an american ophthalmological association thesis). Trans Am Ophthalmol Soc.
4 Kiser AK, Mladenovich D, Eshraghi F, et al. (2005). Reliability and consistency of visual acuity and contrast sensitivity measures in advanced eye disease. Optom Vis Sci.
5 Mokkink LB, Terwee CB, Patrick DL, et al. (2010). The COSMIN checklist for assessing the methodological quality of studies on measurement properties of health status measurement instruments: an international Delphi study. Quality of life research: an international journal of quality of life aspects of treatment, care and rehabilitation.
6 Finger RP, Tellis B, Crewe J, et al. (2014). Developing the impact of vision impairment-very low vision (IVI-VLV) questionnaire as part of the LoVADA protocol. Invest Ophthalmol Vis Sci.
7 Finger RP, McSweeney SC, Deverell L, et al. (2014). Developing an instrumental activities of daily living tool as part of the low vision assessment of daily activities protocol. Invest Ophthalmol Vis Sci.
8 McKnight PE, BabcockParziale J. (2007). Respondent impact on functional ability outcome measures in vision rehabilitation. Optom Vis Sci.
9 Roman AJ, Cideciyan AV, Aleman TS, et al. (2007). Full-field stimulus testing (FST) to quantify visual perception in severely blind candidates for treatment trials. Physiol Meas.
10 Kiser AK, Mladenovich D, Eshraghi F, et al. (2006). Reliability and consistency of dark-adapted psychophysical measures in advanced eye disease. Invest Ophthalmol Vis Sci.
11 Babcock-Parziale J, McKnight PE, Head DN. (2005). Evaluating psychometric properties of a clinical and a self-report blind rehabilitation outcome measure. J Rehabil Res Dev.
12 Stelmack JA, Stelmack TR, Massof RW. (2002). Measuring low-vision rehabilitation outcomes with the NEI VFQ-25. Invest Ophthalmol Vis Sci.
13 Arevalo JF, Al Rashaed S, Kahtani ES, et al. (2015). The Argus II retinal prosthesis in RP patients: surgical and functional outcomes from the KKESH Collaborative Retina Study Group [slide presentation].
14 Arevalo JF, Mura M, Al Rashaed S. (2015). The Argus II retinal prosthesis: surgical and functional outcomes in younger retinitis pigmentosa (RP) patients [poster PO267; slide set].
15 Ho AC, Humayun MS, Dorn JD, et al. (2015). Long-term results from an epiretinal prosthesis to restore sight to the blind. Ophthalmology.
16 Luo YH, Zhong JJ, da Cruz L. (2015). The use of Argus® II retinal prosthesis by blind subjects to achieve localisation and prehension of objects in 3-dimensional space. Graefes Arch Clin Exp Ophthalmol.
17 De Juan E, Spencer R, Barale PO, et al. (2013). Extraction of retinal tacks from subjects implanted with an epiretinal visual prosthesis. Graefes Arch Clin Exp Ophthalmol.
18 Humayun MS, Dorn JD, da Cruz L, et al. (2012). Interim results from the international trial of Second Sight's visual prosthesis. Ophthalmology.
19 Greenberg RJ, Humayun MS, da Cruz L, et al. (2015). Five-year data from the Argus II retinal prosthesis system clinical trial. Invest Ophthalmol Vis Sci.
20 Luo YH, Davagnanam I, Dacruz L. (2013). MRI brain scans in two patients with the Argus II retinal prosthesis. Ophthalmology.
21 Lauritzen TZ, Harris J, Mohand-Said S, et al. (2012). Reading visual braille with a retinal prosthesis. Front Neurosci.
22 Da Cruz L, Coley BF, Dorn J, et al. (2013). The Argus II epiretinal prosthesis system allows letter and word reading and long-term function in patients with profound vision loss. Br J Ophthalmol.
23 Barry MP, Dagnelie G. (2012). Use of the Argus II retinal prosthesis to improve visual guidance of fine hand movements. Invest Ophthalmol Vis Sci.
24 Geruschat DR, Richards TP, Arditi A, et al. (2016). An analysis of observer-rated functional vision in patients implanted with the Argus II Retinal Prosthesis System at three years. Clin Exp Optom.
25 Garcia S, Petrini K, Rubin GS, et al. (2015). Visual and non-visual navigation in blind patients with a retinal prosthesis. PLoS ONE.
26 da Cruz L, Dorn JD, Humayun MS, et al. (2016). Five-year safety and performance results from the Argus II Retinal Prosthesis System clinical trial. Ophthalmology.
27 Seider MI, Hahn P. (2015). Argus II retinal prosthesis malrotation and repositioning with intraoperative optical coherence tomography in a posterior staphyloma. Clin Ophthalmol.
28 Stingl K, BartzSchmidt KU, Besch D, et al. (2015). Subretinal visual implant alpha IMS - clinical trial interim report. Vision Res.
29 Stingl K, Bach M, Bartz-Schmidt KU, et al. (2013). Safety and efficacy of subretinal visual implants in humans: methodological aspects. Clin Exp Optom.
30 Ayton LN, Blamey PJ, Guymer RH, et al. (2014). First-in-human trial of a novel suprachoroidal retinal prosthesis. PLoS ONE.
31 Rizzo S, Belting C, Cinelli L, et al. (2014). The Argus II retinal prosthesis: 12-month outcomes from a single-study center. Am J Ophthalmol.
32 Fujikado T, Kamei M, Sakaguchi H, et al. (2011). Testing of semichronically implanted retinal prosthesis by suprachoroidal-transretinal stimulation in patients with retinitis pigmentosa. Invest Ophthalmol Vis Sci.
33 Klauke S, Goertz M, Rein S, et al. (2011). Stimulation with a wireless intraocular epiretinal implant elicits visual percepts in blind humans. Invest Ophthalmol Vis Sci.
34 MenzelSevering J, Laube T, Brockmann C, et al. (2012). Implantation and explantation of an active epiretinal visual prosthesis: 2-year follow-up data from the EPIRET3 prospective clinical trial. Eye (Lond).
35 Roessler G, Laube T, Brockmann C, et al. (2009). Implantation and explantation of a wireless epiretinal retina implant device: observations during the EPIRET3 prospective clinical trial. Invest Ophthalmol Vis Sci.
36 Roessler G, Laube T, Brockmann C, et al. (2011). Angiographic findings following tack fixation of a wireless epiretinal retina implant device in blind RP patients. Graefes Arch Clin Exp Ophthalmol.
37 Mokwa W, Goertz M, Koch C, et al. (2008). Intraocular epiretinal prosthesis to restore vision in blind humans. Conf Proc IEEE Eng Med Biol Soc.
38 Zrenner E, Bartz-Schmidt KU, Benav H, et al. (2011). Subretinal electronic chips allow blind patients to read letters and combine them to words. Proc Biol Sci.
39 Geruschat DR, Bittner AK, Dagnelie G. (2012). Orientation and mobility assessment in retinal prosthetic clinical trials. Optom Vis Sci.
40 Chow AY, Chow VY, Packo KH, et al. (2004). The artificial silicon retina microchip for the treatment of vision loss from retinitis pigmentosa. Arch Ophthalmol.
41 Khan MA, Ho AC, Haller JA. (2015). Ten-year follow-up of a subretinal silicon prosthesis for retinitis pigmentosa. Ophthalmology.