# Appendix B Excluded Studies

Abateneh A, Tesfaye M, Bekele S, et al. (2013). Vision loss and psychological distress among Ethiopians adults: a comparative cross-sectional study. PLoS ONE.
Ahmadian L, Massof R. (2008). Does functional vision behave differently in low-vision patients with diabetic retinopathy? A case-matched study. Invest Ophthalmol Vis Sci.
Ahmadian L, Massof R. (2008). Impact of general health status on validity of visual impairment measurement. Ophthalmic Epidemiol.
Ahmed I. (2006). October Consultation # 9. J Cataract Refract Surg.
Ahn SJ, Legge GE, Luebker A. (1995). Printed cards for measuring low-vision reading speed. Vision Res.
Ahuja AK, Behrend MR. (2013). The Argus II retinal prosthesis: Factors affecting patient selection for implantation. Prog Retin Eye Res.
Ahuja AK, Dorn JD, Caspi A, et al. (2011). Blind subjects implanted with the Argus II retinal prosthesis are able to improve performance in a spatial-motor task. Br J Ophthalmol.
Ahuja AK, Yeoh J, Dorn JD, et al. (2013). Factors affecting perceptual threshold in Argus II retinal prosthesis subjects. Transl Vis Sci Technol.
Akeo K, Hiida Y, Saga M, et al. (2002). Correlation between contrast sensitivity and visual acuity in retinitis pigmentosa patients. Ophthalmologica.
Al Yaman M, Al Atabany W, Bystrov A, et al. (2014). FPGA design for dual-spectrum Visual Scene Preparation in retinal prosthesis. Conf Proc IEEE Eng Med Biol Soc.
Alcubierre N, Rubinat E, Traveset A, et al. (2014). A prospective cross-sectional study on quality of life and treatment satisfaction in type 2 diabetic patients with retinopathy without other major late diabetic complications. Health Qual Life Outcomes.
Allen P, Ayton L, Yeoh J, et al. (2014). First-in-human clinical trial of a suprachoroidal retinal prosthesis. Neuromodulation.
Allen P, Yeoh J, Briggs R, et al. (2014). Suprachoroidal retinal prostheses: A preliminary clinical trial of three patients. Clin Experiment Ophthalmol.
Alteheld N, Roessler G, Vobig M, et al. (2004). The retina implant new approach to a visual prosthesis. Biomed Tech.
Alteheld N, Roessler G, Walter P. (2007). Towards the bionic eye--the retina implant: surgical, opthalmological and histopathological perspectives. Acta Neurochir Suppl.
Althin R, Lundstrom M, Roos P. (2002). A new index approach to measure lost benefits from progression to blindness. Int J Technol Assess Health Care.
Al-Zboon E, Smadi J. (2015). Self-determination of women with disabilities. Europ J Spec Needs Educ.
Anderson AJ, Johnson CA, Werner JS. (2011). Measuring visual function in age-related macular degeneration with frequency-doubling (matrix) perimetry. Opt Vis Sci.
Andrade LC, Souza GS, Lacerda EM, et al. (2014). Influence of retinopathy on the achromatic and chromatic vision of patients with type 2 diabetes. BMC Ophthalmol.
Arimura E, Matsumoto C, Nomoto H, et al. (2011). Correlations between M-CHARTS and PHP findings and subjective perception of metamorphopsia in patients with macular diseases. Invest Ophthalmol Vis Sci.
Aslam T, Mahmood S, Balaskas K, et al. (2014). Repeatability of visual function measures in age-related macular degeneration. Graefes Arch Clin Exp Ophthalmol.
Ayton LN, Apollo NV, Varsamidis M, et al. (2014). Assessing residual visual function in severe vision loss. Invest Ophthalmol Vis Sci.
Ayton LN, Blamey PJ, Guymer RH, et al. (2014). First-in-human trial of a novel suprachoroidal retinal prosthesis. PLoS ONE.
Ayton LN, Luu CD, Allen PJ, et al. (2013). The importance of multidisciplinary collaborations in the future of bionic vision. Expert Rev Ophthalmol.
Azoulay L, Chaumet-Riffaud P, Jaron S, et al. (2015). Threshold levels of visual field and acuity loss related to significant decreases in the quality of life and emotional states of patients with retinitis pigmentosa. Ophthalmic Res.
Babizhayev MA. (2003). Glare disability and driving safety. Ophthalmic Res.
Bach M, Wilke M, Wilhelm B, et al. (2010). Basic quantitative assessment of visual performance in patients with very low vision. Invest Ophthalmol Vis Sci.
Barnes N, Walker J, Lieby P, et al. (2011). The impact of environment complexity on mobility performance for prosthetic vision using the visual representation of depth. Clin Experiment Ophthalmol.
Barry JA, Folkard A, Denniston AK, et al. (2014). Development and validation of quality-of-life questionnaires for birdshot chorioretinopathy. Ophthalmology.
Barteselli G, Gomez ML, Doede AL, et al. (2014). Visual function assessment in simulated real-life situations in patients with age-related macular degeneration compared to normal subjects. Eye (Lond).
Beausencourt E, Elsner AE, Hartnett ME, et al. (1997). Quantitative analysis of macular holes with scanning laser tomography. Ophthalmology.
Bechtel B. (2011). Small firm development offers big promise to retinal medicine. Ocular Surg News.
Berdeaux G, Mesbah M, Bradley C. (2011). Metric properties of the MacDQoL, individualized macular-disease-specific quality of life instrument, and newly identified subscales in French, German, Italian, and American populations. Value Health.
Besch D, Sachs H, Szurman P, et al. (2008). Extraocular surgery for implantation of an active subretinal visual prosthesis with external connections: Feasibility and outcome in seven patients. Br J Ophthalmol.
Bhagat N, Zarbin M. (2013). Recent Innovations in Medical and Surgical Retina. Asia Pac J Ophthalmol (Phila).
Bhagat N, Zarbin M. (2015). Recent Innovations in Medical and Surgical Retina. Asia Pac J Ophthalmol (Phila).
Bibby SA, Maslin ER, McIlraith R, et al. (2007). Vision and self-reported mobility performance in patients with low vision. Clin Exp Optom.
(2001). Bionic eye?. Home Healthc Nurse.
Biro A. (2012). Gene therapy, retinal implants may help restore sight in blind patients. Ocular Surg News.
Biro A. (2012). Subretinal implant provides some vision in patients with hereditary retinal degenerative disease. Ocular Surg News.
Bittner AK, Gould JM, Rosenfarb A, et al. (2014). A pilot study of an acupuncture protocol to improve visual function in retinitis pigmentosa patients. Clin Exp Optom.
Bittner AK, Haythornthwaite JA, Diener West M, et al. (2013). Worse-than-usual visual fields measured in retinitis pigmentosa related to episodically decreased general health. Br J Ophthalmol.
Bittner AK, Ibrahim MA, Haythornthwaite JA, et al. (2011). Vision test variability in retinitis pigmentosa and psychosocial factors. Opt Vis Sci.
Bokinni Y, Shah N, Maguire O, et al. (2015). Performance of a computerised visual acuity measurement device in subjects with age-related macular degeneration: Comparison with gold standard ETDRS chart measurements. Eye (Lond).
Bologna G, Deville B, Diego Gomez J, et al. (2011). Toward local and global perception modules for vision substitution. Neurocomputing.
Bonotto LB, Moreira AT, Chuffi S, et al. (2014). Comparative study of visual functions in premature pre-school children with and without retinopathy of prematurity. Arq Bras Oftalmol.
Bourbakis N. (2008). Sensing surrounding 3-D space for navigation of the blind. A prototype system featuring vibration arrays and data fusion provides a near real-time feedback. IEEE Eng Med Biol Mag.
Boyle EL, Harcharek A, Hasson M, et al. (2011). Retinal implant holds potential for end-stage AMD patients. Ocular Surg News.
Brabyn JA, Schneck ME, Lott LA, et al. (2005). Night driving self-restriction: vision function and gender differences. Optom Vis Sci.
Brendler C, Pour Aryan N, Rieger V, et al. (2013). A Substrate Isolated LDO for an Inductively Powered Retinal Implant. Biomed Tech (Berl).
Brennan Ing M, Boerner K, Horowitz A, et al. (2013). The vision-specific optimization in primary and secondary control (OPS) scale. Eur J Ageing.
Briesen S, Roberts H, Finger RP. (2014). The impact of visual impairment on health-related quality of life in rural Africa. Ophthalmic Epidemiol.
Brody BL, Roch-Levecq AC, Gamst AC, et al. (2002). Self-management of age-related macular degeneration and quality of life: a randomized controlled trial. Arch Ophthalmol.
Brose LS, Bradley C. (2010). Psychometric development of the individualized Retinopathy-Dependent Quality of Life Questionnaire (RetDQoL). Value Health.
Brose LS, Bradley C. (2009). Psychometric development of the retinopathy treatment satisfaction questionnaire (RetTSQ). Psychol Health Med.
Brown B. (1990). Visual psychophysics and clinical assessment of abnormal vision. Curr Opin Ophthalmol.
Brown CM, Wong EY, O'Connor PM, et al. (2009). Measurement of quality of life for people with diabetic retinopathy impairment. Expert Rev Ophthalmol.
Brown GC, Brown MM, Kertes PJ, et al. (2011). Comparative effectiveness and cost-effective analyses: 17.3% and counting!. Evid Based Ophthalmol.
Bruijning J, van Nispen R, Knol D, et al. (2012). Low vision rehabilitation plans comparing two intake methods. Optom Vis Sci.
Bruijning J, van Nispen R, Verstraten P, et al. (2010). A Dutch ICF version of the Activity Inventory: results from focus groups with visually impaired persons and experts. Ophthalmic Epidemiol.
Bruijning JE, van Rens G, Fick M, et al. (2014). Longitudinal observation, evaluation and interpretation of coping with mental (emotional) health in low vision rehabilitation using the Dutch ICF Activity Inventory. Health Qual Life Outcomes.
Bruijning JE, van Rens G, Knol D, et al. (2013). Psychometric analyses to improve the Dutch ICF Activity Inventory. Opt Vis Sci.
Bruijning JE, van Rens GH, Fick M, et al. (2014). Longitudinal observation, evaluation and interpretation of coping with mental (emotional) health in low vision rehabilitation using the Dutch ICF Activity Inventory. Health Qual Life Outcomes.
Cacho I, Dickinson CM, Smith HJ, et al. (2010). Clinical impairment measures and reading performance in a large age-related macular degeneration group. Opt Vis Sci.
Cacho-Martinez P, Garcia-Munoz A, Ruiz-Cantero MT. (2014). Is there any evidence for the validity of diagnostic criteria used for accommodative and nonstrabismic binocular dysfunctions?. J Optom.
Camparini M, Cassinari P, Ferrigno L, et al. (2001). ETDRS-fast: implementing psychophysical adaptive methods to standardized visual acuity measurement with ETDRS charts. Invest Ophthalmol Vis Sci.
Cao KY, Markowitz SN. (2014). Residual stereopsis in age-related macular degeneration patients and its impact on vision-related abilities: a pilot study. J Optom.
Cappello E, Virgili G, Tollot L, et al. (2009). Reading ability and retinal sensitivity after surgery for macular hole and macular pucker. Retina.
Carignan M, Rousseau J, Gresset J, et al. (2008). Content validity of a home-based person-environment interaction assessment tool for visually impaired adults. J Rehabil Res Dev.
Carta A, Braccio L, Belpoliti M, et al. (1998). Self-assessment of the quality of vision: association of questionnaire score with objective clinical tests. Curr Eye Res.
Caspi A, Dorn JD, McClure KH, et al. (2009). Feasibility study of a retinal prosthesis: Spatial vision with a 16-electrode implant. Arch Ophthalmol.
Caspi A, Zivotofsky AZ. (2015). Assessing the utility of visual acuity measures in visual prostheses. Vision Res.
Caspi A, Zivotofsky AZ. (2015). Assessing the utility of visual acuity measures in visual prostheses. Vision Res.
Chader GJ, Weiland J, Humayun MS. (2009). Artificial vision: needs, functioning, and testing of a retinal electronic prosthesis. Prog Brain Res.
Chader GJ. (2005). Beyond basic research for inherited and orphan retinal diseases: Successes and challenges. Retina.
Chan TL, Perlmutter MS, Andrews M, et al. (2015). Equating visual function scales to facilitate reporting of Medicare functional G-code severity/complexity modifiers for low-vision patients. Arch Phys Med Rehabil.
Chang MH, Kim HS, Shin JH, et al. (2012). Facial identification in very low-resolution images simulating prosthetic vision. J Neural Eng.
Chen SJ, Mahadevappa M, Roizenblatt R, et al. (2006). Neural responses elicited by electrical stimulation of the retina. Trans Am Ophthalmol Soc.
Cheong AC, Lovie-Kitchin JE, Bowers AR. (2002). Determining magnification for reading with low vision. Clin Exp Optom.
Chia EM, Chia EM, Rochtchina E, et al. (2006). Utility and validity of the self-administered SF-36: findings from an older population. Ann Acad Med Singapore.
Chia EM, Wang JJ, Rochtchina E, et al. (2004). Impact of bilateral visual impairment on health-related quality of life: the Blue Mountains Eye Study. Invest Ophthalmol Vis Sci.
Chiang PP, Fenwick E, Marella M, et al. (2011). Validation and reliability of the VF-14 questionnaire in a German population. Invest Ophthalmol Vis Sci.
Chiang PP, Zheng Y, Wong TY, et al. (2013). Vision impairment and major causes of vision loss impacts on vision-specific functioning independent of socioeconomic factors. Ophthalmology.
Childs AL. (2004). Responsiveness of the SF-36 health survey to changes in visual acuity among patients with subfoveal choroidal neovascularization. Am J Ophthalmol.
Chow AY. (2013). Retinal Prostheses Development in Retinitis Pigmentosa Patients-Progress and Comparison. Asia Pac J Ophthalmol (Phila).
Christiaan Stronks H, Barry MP, Dagnelie G. (2013). Electrically elicited visual evoked potentials in argus II retinal implant wearers. Invest Ophthalmol Vis Sci.
Chuang AT, Margo CE, Greenberg PB. (2014). Retinal implants: A systematic review. Br J Ophthalmol.
Cimberle M. (2003). Research on retinal implants progresses. Ocular Surg News.
Cimberle M. (2011). Subretinal electronic chip shows encouraging results, further improvements. Ocular Surg News.
Cimberle M. (2007). Subretinal implant shows promise to restore vision in some patients. Ocular Surg News.
Claesson L, Blomstrand J, Eklund K, et al. (2013). Comparison of visual acuity charts identifying visual impairment among older people outside the eye clinic. Disabil Rehabil.
Clemons TE, Chew EY, Bressler SB, et al. (2003). National Eye Institute Visual Function Questionnaire in the Age-Related Eye Disease Study (AREDS): AREDS Report No. 10. Arch Ophthalmol.
Clemson L, Bundy A, Unsworth C, et al. (2009). Validation of the modified assessment of living skills and resources, an IADL measure for older people. Disabil Rehabil.
Conrad R, Geiser F, Kleiman A, et al. (2014). Temperament and character personality profile and illness-related stress in central serous chorioretinopathy. Sci World J.
Correa M, Fox C, Hasson M. (2013). Useful vision restored in retinitis pigmentosa patients who received subretinal implant. Ocular Surg News.
Cunningham SI, Shi Y, Weiland JD, et al. (2015). Feasibility of structural and functional MRI acquisition with unpowered implants in Argus II retinal prosthesis patients: a case study. Transl Vis Sci Technol.
Cunningham S, Tjan B, Bao P, et al. (2015). Tactile-Evoked V1 responses in Argus II Retinal Prosthesis Patients assessed with fMRI: A Case Study. J Vis.
Dagnelie G, Keane P, Narla V, et al. (2007). Real and virtual mobility performance in simulated prosthetic vision. J Neural Eng.
Dagnelie G. (2002). Visual perfromance under simulated conditions of prosthetic vision. J Vis.
Dahlin Ivanoff S, Sonn U, Svensson E. (2001). Development of an ADL instrument targeting elderly persons with age-related macular degeneration. Disabil Rehabil.
Davison JA. (2008). October consultation # 6. J Cataract Refract Surg.
Day H, Jutai J. (1996). Measuring the psychosocial impact of assistive devices: The PIADS. Can J Rehabil.
De Balthasar C, Patel S, Roy A, et al. (2008). Factors affecting perceptual thresholds in epiretinal prostheses. Invest Ophthalmol Vis Sci.
de Boer MR, de Vet HC, Terwee CB, et al. (2005). Changes to the subscales of two vision-related quality of life questionnaires are proposed. J Clin Epidemiol.
de Boer MR, Moll AC, de Vet HC, et al. (2004). Psychometric properties of vision-related quality of life questionnaires: a systematic review. Ophthalmic Physiol Opt.
de Boer MR, Terwee CB, de Vet HC, et al. (2006). Evaluation of cross-sectional and longitudinal construct validity of two vision-related quality of life questionnaires: the LVQoL and VCM1. Qual Life Res.
DeCcarlo DK, Scilley K, Wells J, et al. (2003). Driving habits and health-related quality of life in patients with age-related maculopathy. Optom Vis Sci.
Dell SJ. (2010). February consultation #2. J Cataract Refract Surg.
Demers L, Monette M, Descent M, et al. (2002). The Psychosocial Impact of Assistive Devices Scale (PIADS): translation and preliminary psychometric evaluation of a Canadian-French version. Qual Life Res.
Denny F, Marshall AH, Stevenson MR, et al. (2007). Rasch analysis of the daily living tasks dependent on vision (DLTV). Invest Ophthalmol Vis Sci.
Dev MK, Paudel N, Joshi ND, et al. (2014). Impact of visual impairment on vision-specific quality of life among older adults living in nursing home. Curr Eye Res.
Dev MK, Paudel N, Joshi ND, et al. (2014). Psycho-social impact of visual impairment on health-related quality of life among nursing home residents. BMC Health Serv Res.
Dickson G, Chesser A, Woods NK, et al. (2012). Time required for screening for visual impairment in primary care: a randomized comparison of 3 common visual tests. J Prim Care Community Health.
Dixon P, Dakin H, Wordsworth S. (2015). Generic and disease-specific estimates of quality of life in macular degeneration: mapping the MacDQoL onto the EQ-5D-3L. Quality of life research : an international journal of quality of life aspects of treatment, care and rehabilitation.
Djafari F, Gresset JA, Boisjoly HM, et al. (2003). Estimation of the misclassification rate of self-reported visual disability. Can J Public Health.
Dobson V, Quinn GE, Biglan AW, et al. (1990). Acuity card assessment of visual function in the cryotherapy for retinopathy of prematurity trial. Invest Ophthalmol Vis Sci.
Dorn JD, Ahuja AK, Caspi A, et al. (2013). The detection of motion by blind subjects with the epiretinal 60-electrode (Argus II) retinal prosthesis. JAMA Ophthalmol.
Dougherty BE, Bullimore MA. (2010). Comparison of scoring approaches for the NEI VFQ-25 in low vision. Optom Vis Sci.
Dougherty BE, Martin SR, Kelly CB, et al. (2009). Development of a battery of functional tests for low vision. Opt Vis Sci.
Dowling JE. (2014). Restoring vision to the blind: Introduction. Transl Vis Sci Technol.
Dreer LE, McGwin G, Scilley K, et al. (2007). Development of a nursing home vision-targeted health-related quality of life questionnaire for older adults. Aging Ment Health.
Dubuc S, Wittich W, Gomolin JE, et al. (2009). Beyond visual acuity: functional outcome and patient satisfaction following treatment for age-related macular degeneration. Can J Ophthalmol.
Dunbar HM, Crossland MD, Rubin GS. (2010). Fixation stability: a comparison between the Nidek MP-1 and the Rodenstock scanning laser ophthalmoscope in persons with and without diabetic maculopathy. Invest Ophthalmol Vis Sci.
El Miedany Y, El Gaafary M, Toth M, et al. (2011). Falls risk assessment score (FRAS): Time to rethink. J Clin Gerontol Geriatr.
Elliott AF, Dreer LE, McGwin G, et al. (2010). The personal burden of decreased vision-targeted health-related quality of life in nursing home residents. J Aging Health.
Eng JG, Agrawal RN, Tozer KR, et al. (2011). Morphometric analysis of optic nerves and retina from an end-stage retinitis pigmentosa patient with an implanted active epiretinal array. Invest Ophthalmol Vis Sci.
Falahaty K, Cheong LS, Mohd Isa MBH. (2015). Disability among elderly people with visual impairment in two welfare homes in Malaysia. Biomed Pharmacol J.
Faria BM, Duman F, Zheng CX, et al. (2015). Evaluating contrast sensitivity in age-related macular degeneration using a novel computer-based test, the SPAETH/RICHMAN Contrast sensitivity test. Retina.
Fellman RL. (2007). June Consultation # 2. J Cataract Refract Surg.
Fenwick EK, Ong PG, Sabanayagam C, et al. (2015). Assessment of the psychometric properties of the Chinese Impact of Vision Impairment questionnaire in a population-based study: findings from the Singapore Chinese Eye Study. Int J Qual Life.
Fenwick EK, Pesudovs K, Khadka J, et al. (2013). Evaluation of item candidates for a diabetic retinopathy quality of life item bank. Quality of life research: an international journal of quality of life aspects of treatment, care and rehabilitation.
Fenwick EK, Pesudovs K, Khadka J, et al. (2012). The impact of diabetic retinopathy on quality of life: qualitative findings from an item bank development project. Qual Life Res.
Fenwick EK, Pesudovs K, Rees G, et al. (2012). Republished article: The impact of diabetic retinopathy: understanding the patient's perspective. Postgrad Med J.
Fenwick EK, Pesudovs K, Rees G, et al. (2012). Republished article: The impact of diabetic retinopathy: Understanding the patient's perspective. Postgrad Med J.
Fenwick EK, Pesudovs K, Rees G, et al. (2011). The impact of diabetic retinopathy: understanding the patient's perspective. Br J Ophthalmol.
Fenwick EK, Xie J, Pesudovs K, et al. (2012). Assessing disutility associated with diabetic retinopathy, diabetic macular oedema and associated visual impairment using the Vision and Quality of Life Index. Clin Exp Optom.
Fernandes RA, Diniz B, Ribeiro R, et al. (2012). Artificial vision through neuronal stimulation. Neurosci Lett.
Feucht M, Laube T, Bornfeld N, et al. (2005). Development of an epiretinal prosthesis for stimulation of the human retina. Ophthalmologe.
Fevzi A, Aysegul Y. (2008). Psychometric performance of the National Eye Institute 25-Item Visual Function Questionnaire: In Turkish diabetic retinopathy patients. Patient.
Finger RP, Fenwick E, Chiang PP, et al. (2011). The impact of the severity of vision loss on vision-specific functioning in a German outpatient population - an observational study. Graefes Arch Clin Exp Ophthalmol.
Finger RP, Fenwick E, Marella M, et al. (2011). The impact of vision impairment on vision-specific quality of life in Germany. Invest Ophthalmol Vis Sci.
Finger RP, Fenwick E, Owsley C, et al. (2011). Visual functioning and quality of life under low luminance: evaluation of the German Low Luminance Questionnaire. Invest Ophthalmol Vis Sci.
Finger RP, Fenwick E, Pesudovs K, et al. (2012). Rasch analysis reveals problems with multiplicative scoring in the macular disease quality of life questionnaire. Ophthalmology.
Finger RP, Fleckenstein M, Holz FG, et al. (2008). Quality of life in age-related macular degeneration: a review of available vision-specific psychometric tools. Int J Qual Life.
Finger RP, Guymer RH, Gillies MC, et al. (2014). The impact of anti-vascular endothelial growth factor treatment on quality of life in neovascular age-related macular degeneration. Ophthalmology.
Finger RP, Kortuem K, Fenwick E, et al. (2013). Evaluation of a vision-related utility instrument: the German vision and quality of life index. Invest Ophthalmol Vis Sci.
Fitzke FW, Crabb DP, McNaught AI, et al. (1995). Image processing of computerised visual field data. Br J Ophthalmol.
Fornos AP, Sommerhalder J, da Cruz L, et al. (2012). Temporal properties of visual perception on electrical stimulation of the retina. Invest Ophthalmol Vis Sci.
Fornos AP, Sommerhalder J, Pelizzone M. (2011). Reading with a simulated 60-channel implant. Front Neurosci.
Friedman DS, Munoz B, Massof RW, et al. (2002). Grating visual acuity using the preferential-looking method in elderly nursing home residents. Invest Ophthalmol Vis Sci.
(2008). From the field. Retinal prosthesis study recruitment partially completed. J Vis Impair Blind.
Frost NA, Sparrow JM, Durant JS, et al. (1998). Development of a questionnaire for measurement of vision-related quality of life. Ophthalmic Epidemiol.
Frost NA, Sparrow JM, Hopper CD, et al. (2001). Reliability of the VCM1 Questionnaire when administered by post and by telephone. Ophthalmic Epidemiol.
Fujikado T, Morimoto T, Kanda H, et al. (2007). Evaluation of phosphenes elicited by extraocular stimulation in normals and by suprachoroidal-transretinal stimulation in patients with retinitis pigmentosa. Graefes Arch Clin Exp Ophthalmol.
Gabrielian A, Hariprasad SM, Jager RD, et al. (2010). The utility of visual function questionnaire in the assessment of the impact of diabetic retinopathy on vision-related quality of life. Eye (Lond).
Gall R, Wick B, Bedell H. (1998). Vergence facility: establishing clinical utility. Optom Vis Sci.
Gallagher P, Mulvany F. (2004). Levels of ability and functioning: Using the WHODAS II in an Irish context. Disabil Rehabil.
Garcia S, Petrini K, Rubin GS, et al. (2015). Visual and non-visual navigation in blind patients with a retinal prosthesis. PLoS ONE.
Garcia-Munoz A, Carbonell-Bonete S, Cacho-Martinez P. (2014). Symptomatology associated with accommodative and binocular vision anomalies. J Optom.
Gekeler F, Kopp A, Sachs H, et al. (2010). Visualisation of active subretinal implants with external connections by high-resolution CT. Br J Ophthalmol.
Gekeler F, Messias A, Ottinger M, et al. (2006). Phosphenes electrically evoked with DTL electrodes: A study in patients with retinitis pigmentosa, glaucoma, and homonymous visual field loss and normal subjects. Invest Ophthalmol Vis Sci.
Gerding H. (2008). Development of a minimally invasive retinal implant system. Ophthalmologe.
Geruschat Duane R, Dagnelie Gislin. Restoration of vision following long-term blindness: considerations for providing rehabilitation. J Vis Impair Blind.
Giacomelli G, Volpe R, Virgili G, et al. (2010). Contrast reduction and reading: assessment and reliability with the Reading Explorer test. Eur J Ophthalmol.
Globe DR, Levin S, Chang TS, et al. (2002). Validity of the SF-12 quality of life instrument in patients with retinal diseases. Ophthalmology.
Goldstein JE, Chun MW, Fletcher DC, et al. (2014). Visual ability of patients seeking outpatient low vision services in the United States. JAMA Ophthalmol.
Goodrich GL, Kirby J. (2001). A comparison of patient reading performance and preference: optical devices, handheld CCTV (Innoventions Magni-Cam), or stand-mounted CCTV (Optelec Clearview or TSI Genie). Optometry.
Gopal L. (2010). Update on vitreo retinal surgery. J Int Med Sci Acad.
Gothwal VK, Bagga DK, Sumalini R. (2012). Rasch analysis of the Indian vision function questionnaire. Br J Ophthalmol.
Gothwal VK, Bagga DK. (2012). Andhra Pradesh Eye Disease Study - Visual Function Questionnaire: further improvements in psychometric properties using Rasch analysis. Ophthalmic Epidemiol.
Gothwal VK, Bagga DK. (2013). Utility values in the visually impaired: comparing time-trade off and VisQoL. Opt Vis Sci.
Gothwal VK, Bagga DK. (2013). Vision and Quality of Life Index: validation of the Indian version using Rasch analysis. Invest Ophthalmol Vis Sci.
Gothwal VK, Lovie-Kitchin JE, Nutheti R. (2003). The development of the LV Prasad-Functional Vision Questionnaire: a measure of functional vision performance of visually impaired children. Invest Ophthalmol Vis Sci.
Gothwal VK, Reddy SP, Sumalini R, et al. (2012). National Eye Institute Visual Function Questionnaire or Indian Vision Function Questionnaire for visually impaired: a conundrum. Invest Ophthalmol Vis Sci.
Gothwal VK, Srinivas M, Rao GN. (2013). A new look at the WHOQoL as health-related quality of life instrument among visually impaired people using Rasch analysis. Qual Life Res.
Gothwal VK, Sumalini R, Bharani S, et al. (2012). The second version of the L. V. Prasad-functional vision questionnaire. Opt Vis Sci.
Gothwal VK, Sumalini R, Irfan SM, et al. (2013). Rasch analysis of Impact of Vision Impairment for Children questionnaire. Opt Vis Sci.
Grabow HB. (2006). October Consultation # 3. J Cataract Refract Surg.
Greenberg R. (2005). Cooperation between private and public sectors leads to an intraocular retinal implant. Retina.
Greenberg RJ, Humayun MS, da Cruz L, et al. (2015). Five-year data from the Argus II retinal prosthesis system clinical trial. Invest Ophthalmol Vis Sci.
Greenwald SH, Horsager A, Humayun MS, et al. (2009). Brightness as a function of current amplitude in human retinal electrical stimulation. Invest Ophthalmol Vis Sci.
Gregori NZ, Davis JL, Rizzo S. (2016). Bimanual technique for retinal tacking of epiretinal prosthesis. Retina.
Gusseck H. (2005). Retinal implants. Patients' expectations. Ophthalmologe.
Guthrie DM, Pitman R, Stolee P, et al. (2011). Reliability of standardized assessment for adults who are deafblind. J Rehabil Res Dev.
Guttman KC. (2015). Subretinal implant benefits retinitis pigmentosa cases. Ophthalmol Times.
Guttman Krader C, Rizzo S. (2014). Epiretinal prosthesis outcomes remain encouraging for retinitis pigmentosa. Ophthalmol Times.
Haegerstrom-Portnoy G, Schneck ME, Verdon WA, et al. (1996). Clinical vision characteristics of the congenital achromatopsias. II. Color vision. Optom Vis Sci.
Hafed ZM, Stingl K, Bartz-Schmidt KU, et al. (2014). Oculomotor behavior of blind patients seeing with a subretinal visual implant. Vision Res.
Hafed ZM, Stingl K, Bartz-Schmidt KU, et al. (2014). Oculomotor behavior of blind patients seeing with a subretinal visual implant. Vision Res.
Hahm BJ, Shin YW, Shim EJ, et al. (2008). Depression and the vision-related quality of life in patients with retinitis pigmentosa. Br J Ophthalmol.
Hallum LE, Dagnelie G, Suaning GJ, et al. (2007). Simulating auditory and visual sensorineural prostheses: A comparative review. J Neural Eng.
Hanout M, Horan N, Do DV. (2015). Introduction to microperimetry and its use in analysis of geographic atrophy in age-related macular degeneration. Curr Opin Ophthalmol.
Harper R, Doorduyn K, Reeves B, et al. (1999). Evaluating the outcomes of low vision rehabilitation. Ophthal Physiol Opt.
Hart PM, Stevenson MR, Montgomery AM, et al. (2005). Further validation of the Daily Living Tasks Dependent on Vision: identification of domains. Br J Ophthalmol.
Hartnett ME, Rodier DW, McColm JR, et al. (2003). Long-term vision results measured with Teller Acuity Cards and a new Light Perception/Projection Scale after management of late stages of retinopathy of prematurity. Arch Ophthalmol.
Hassan SE, Massof RW. (2012). Measurements of street-crossing decision-making in pedestrians with low vision. Accid Anal Prev.
Hassell JB, Weih LM, Keeffe JE. (2000). A measure of handicap for low vision rehabilitation: the impact of vision impairment profile. Clin Experiment Ophthalmol.
Hasson M, Mullin DW. (2010). Subretinal implant allows stable images with eye movement in pilot study of blind patients. Ocular Surg News.
Hasson M. (2010). Subretinal implant provides stable percepts synchronized with eye movement. Ocular Surg News.
Hayes JS, Yin VT, Piyathaisere D, et al. (2003). Visually guided performance of simple tasks using simulated prosthetic vision. Artif Organs.
Haymes S, Guest D, Heyes A, et al. (1996). Mobility of people with retinitis pigmentosa as a function of vision and psychological variables. Optom Vis Sci.
Haymes SA, Chen J. (2004). Reliability and validity of the Melbourne Edge Test and High/Low Contrast Visual Acuity chart. Optom Vis Sci.
Haymes SA, Johnston AW, Heyes AD. (2001). A weighted version of the Melbourne Low-Vision ADL Index: a measure of disability impact. Optom Vis Sci.
Haymes SA, Johnston AW, Heyes AD. (2002). Relationship between vision impairment and ability to perform activities of daily living. Ophthal Physiol Opt.
Haymes SA, Johnston AW, Heyes AD. (2001). The development of the Melbourne low-vision ADL index: a measure of vision disability. Invest Ophthalmol Vis Sci.
Head DN, Babcock JL, Goodrich GL, et al. (2000). A geriatric assessment of functional status in vision rehabilitation. J Vis Impair Blind.
Heintz E, Wirehn AB, Peebo BB, et al. (2012). QALY weights for diabetic retinopathy--a comparison of health state valuations with HUI-3, EQ-5D, EQ-VAS, and TTO. Value Health.
Hensil J, Whittaker SG. (2000). Visual reading versus auditory reading by sighted persons and persons with low vision. J Vis Impairm Blindn.
Hernandez Trillo A, Dickinson CM. (2012). The impact of visual and nonvisual factors on quality of life and adaptation in adults with visual impairment. Invest Ophthalmol Vis Sci.
Hewitt AW, Jeganathan VS, Kidd JE, et al. (2006). Influence of photodynamic therapy for age related macular degeneration upon subjective vision related quality of life. Graefes Arch Clin Exp Ophthalmol.
Holbrook EA, Stevens SL, Kang M, et al. (2011). Validation of a talking pedometer for adults with visual impairment. Med Sci Sports Exerc.
Horiguchi M, Suzuki H, Kojima Y, et al. (2001). New visual acuity chart for patients with macular hole. Invest Ophthalmol Vis Sci.
Horowitz A, Reinardt JP. (1998). Development of the Adaptation to age-related Vision Loss Scale. J Vis Impair Blind.
Horsager A, Boynton GM, Greenberg RJ, et al. (2011). Temporal interactions during paired-electrode stimulation in two retinal prosthesis subjects. Invest Ophthalmol Vis Sci.
Horsager A, Greenberg RJ, Fine I. (2010). Spatiotemporal interactions in retinal prosthesis subjects. Invest Ophthalmol Vis Sci.
Horsager A, Greenwald SH, Weiland JD, et al. (2009). Predicting visual sensitivity in retinal prosthesis patients. Invest Ophthalmol Vis Sci.
Hossain P, Seetho IW, Browning AC, et al. (2005). Science, medicine, and the future: Artificial means for restoring vision. Br Med J.
Huang Q, Chowdhury V, Coroneo MT. (2009). Evaluation of patient suitability for a retinal prosthesis using structural and functional tests of inner retinal integrity. J Neural Eng.
Hudson C, Flanagan JG, Turner GS, et al. (1998). Short-wavelength sensitive visual field loss in patients with clinically significant diabetic macular oedema. Diabetologia.
Humayun MS. (2013). Prosthesis team leader outlines components, procedure, follow-up. Ophthalmol Times.
Humayun MS, Dorn JD, Ahuja AK, et al. (2009). Preliminary 6 month results from the Argus II epiretinal prosthesis feasibility study. Conf Proc IEEE Eng Med Biol Soc.
Humayun MS, Weiland JD, Fujii GY, et al. (2003). Visual perception in a blind subject with a chronic microelectronic retinal prosthesis. Vision Res.
Humayun MS. (2001). Intraocular retinal prosthesis. Trans Am Ophthalmol Soc.
Idil A, Ozen M, Atak N, et al. (2011). Validity and reliability study of Turkish version on low vision with quality of life questionnaire. Int J Ophthalmol.
Idil SA, Caliskan D, Idil NB. (2011). Development and validation of the Turkish version of the MNREAD visual acuity charts. Turk J Med Sci.
(2011). In the journals. Ocular Surg News.
Israelsen PE, Sadda SR, Dorn JD, et al. (2015). Optomap widefield imaging of the Argus II retinal prosthesis in patients with retinitis pigmentosa. Retin Cases Brief Rep.
Ivastinovic D, Koch M, Langmann A, et al. (2006). Evaluation of a new mobility test and a visual acuity test for assessment of visual function. Spektr Augenheilkunde.
Iyigun E, Bayer A, Tastan S, et al. (2010). Validity and reliability study for the NEI-VFO-39 scale in chronic ophthalmic diseases--Turkish version. Acta Ophthalmol.
Jabr F. (2012). Bionic eye. Sci Am.
Javaheri M, Hahn DS, Lakhanpal RR, et al. (2006). Retinal prostheses for the blind. Ann Acad Med Singapore.
Jayasundera T. (2014). Use of retinal prosthesis system helps shape vision for retinitis pigmentosa. Ophthalmol Times.
Kamel HK, Guro-Razuman S, Shareeff M. (2000). The activities of daily vision scale: a useful tool to assess fall risk in older adults with vision impairment. J Am Geriatr Soc.
Kay S, Ferreira A. (2014). Mapping the 25-item National Eye Institute Visual Functioning Questionnaire (NEI VFQ-25) to EQ-5D utility scores. Ophthalmic Epidemiol.
Keane PA, Patel PJ, Ouyang Y, et al. (2010). Effects of retinal morphology on contrast sensitivity and reading ability in neovascular age-related macular degeneration. Invest Ophthalmol Vis Sci.
Keeffe JE, McCarty CA, Hassell JB, et al. (1999). Description and measurement of handicap caused by vision impairment. Aust N Z J Ophthalmol.
Keseru M, Feucht M, Bornfeld N, et al. (2012). Acute electrical stimulation of the human retina with an epiretinal electrode array. Acta Ophthalmol.
Khadka J, McAlinden C, Pesudovs K. (2013). Quality assessment of ophthalmic questionnaires: review and recommendations. Optom Vis Sci.
Kim CY. (2010). August consultation #4. J Cataract Refract Surg.
Kinoshita T, Imaizumi H, Miyamoto H, et al. (2015). Changes in metamorphopsia in daily life after successful epiretinal membrane surgery and correlation with M-CHARTS score. Clin Ophthalmol.
Kiral-Kornek FI, Savage CO, O'Sullivan-Greene E, et al. (2013). Embracing the irregular: a patient-specific image processing strategy for visual prostheses. Conf Proc IEEE Eng Med Biol Soc.
Kitiratschky VB, Stingl K, Wilhelm B, et al. (2015). Safety evaluation of “retina implant alpha IMS” a prospective clinical trial. Graefes Arch Clin Exp Ophthalmol.
Klein BE, Moss SE, Klein R, et al. (2003). Associations of visual function with physical outcomes and limitations 5 years later in an older population: the Beaver Dam eye study. Ophthalmology.
Klein M, Birch DG. (2009). Psychophysical assessment of low visual function in patients with retinal degenerative diseases (RDDs) with the Diagnosys full-field stimulus threshold (D-FST). Doc Ophthalmol.
Koenraads Y, Braun KP, van der Linden DC, et al. (2015). Perimetry in young and neurologically impaired children: the Behavioral Visual Field (BEFIE) Screening Test revisited. JAMA Ophthalmol.
Koitschev A, Stingl K, Bartz-Schmidt KU, et al. (2015). Extraocular surgical approach for placement of subretinal implants in blind patients: lessons from Cochlear-implants. J Ophthalmol.
Kontodimopoulos N, Pappa E, Tadros C, et al. (2014). Dimensional sensitivity of the 15D multiattribute utility instrument in diabetic retinopathy. Appl Res Qual Life.
Kotecha A, Zhong J, Stewart D, et al. (2014). The Argus II prosthesis facilitates reaching and grasping tasks: a case series. BMC Ophthalmol.
Kovac B, Vukosavljevic M, Djokic Kovac J, et al. (2015). Validation and cross-cultural adaptation of the National Eye Institute Visual Function Questionnaire (NEI VFQ-25) in Serbian patients. Health Qual Life Outcomes.
Kowalski JW, Rentz AM, Walt JG, et al. (2012). Rasch analysis in the development of a simplified version of the National Eye Institute Visual-Function Questionnaire-25 for utility estimation. Qual Life Res.
Krader CG, Humayun MS. (2013). FDA approval of retinal prosthesis brings limited sight to individuals with retinitis pigmentosa. Ophthalmol Times.
Krezel AK, Hogg RE, Azuara-Blanco A. (2015). Patient-reported outcomes in randomised controlled trials on age-related macular degeneration. Br J Ophthalmol.
Kriechbaum K, Prager F, Geitzenauer W, et al. (2009). Association of retinal sensitivity and morphology during antiangiogenic treatment of retinal vein occlusion over one year. Ophthalmology.
Krisch I, Hosticka BJ. (2007). Restoring visual perception using microsystem technologies: engineering and manufacturing perspectives. Acta Neurochir Suppl.
Kronemyer B. (2013). Retinal prosthesis system allows patients to identify letters, words. Ocular Surg News.
Kuo HK, Kuo MT, Tiong IS, et al. (2011). Visual acuity as measured with Landolt C chart and Early Treatment of Diabetic Retinopathy Study (ETDRS) chart. Graefes Arch Clin Exp Ophthalmol.
Kusnyerik A, Greppmaier U, Wilke R, et al. (2012). Positioning of electronic subretinal implants in blind retinitis pigmentosa patients through multimodal assessment of retinal structures. Invest Ophthalmol Vis Sci.
Labiris G, Katsanos A, Fanariotis M, et al. (2008). Psychometric properties of the Greek version of the NEI-VFQ 25. BMC Ophthalmol.
Lamoureux EL, Chong EW, Thumboo J, et al. (2008). Vision impairment, ocular conditions, and vision-specific function: the Singapore Malay Eye Study. Ophthalmology.
Lamoureux EL, Hassell JB, Keeffe JE. (2004). The determinants of participation in activities of daily living in people with impaired vision. Am J Ophthalmol.
Lamoureux EL, Hassell JB, Keeffe JE. (2004). The impact of diabetic retinopathy on participation in daily living. Arch Ophthalmol.
Lamoureux EL, Pallant JF, Pesudovs K, et al. (2008). Assessing participation in daily living and the effectiveness of rehabiliation in age related macular degeneration patients using the impact of vision impairment scale. Ophthalmic Epidemiol.
Lamoureux EL, Pallant JF, Pesudovs K, et al. (2007). The effectiveness of low-vision rehabilitation on participation in daily living and quality of life. Invest Ophthalmol Vis Sci.
Lamoureux EL, Pallant JF, Pesudovs K, et al. (2007). The impact of vision impairment questionnaire: an assessment of its domain structure using confirmatory factor analysis and rasch analysis. Invest Ophthalmol Vis Sci.
Lamoureux EL, Pallant JF, Pesudovs K, et al. (2006). The impact of vision impairment questionnaire: an evaluation of its measurement properties using Rasch analysis. Invest Ophthalmol Vis Sci.
Lamoureux EL, Pesudovs K, Pallant JF, et al. (2008). An evaluation of the 10-item vision core measure 1 (VCM1) scale (the Core Module of the Vision-Related Quality of Life scale) using Rasch analysis. Ophthalmic Epidemiol.
Lamoureux EL, Pesudovs K, Thumboo J, et al. (2009). An evaluation of the reliability and validity of the visual functioning questionnaire (VF-11) using Rasch analysis in an Asian population. Invest Ophthalmol Vis Sci.
Lamoureux EL, Tai ES, Thumboo J, et al. (2010). Impact of diabetic retinopathy on vision-specific function. Ophthalmology.
Lamoureux EL, Tee HW, Pesudovs K, et al. (2009). Can clinicians use the PHQ-9 to assess depression in people with vision loss?. Opt Vis Sci.
Lange C, Feltgen N, Junker B, et al. (2009). Resolving the clinical acuity categories “hand motion” and “counting fingers” using the Freiburg Visual Acuity Test (FrACT). Graefes Arch Clin Exp Ophthalmol.
Langelaan M, van Nispen RM, Knol DL, et al. (2007). Visual Functioning Questionnaire: reevaluation of psychometric properties for a group of working-age adults. Optom Vis Sci.
Langelaan M, Wouters B, Moll AC, et al. (2005). Intra- and interrater agreement and reliability of the Functional Field Score. Ophthalmic Physiol Opt.
Latham K, Baranian M, Timmis MA, et al. (2015). Difficulties with goals of the Dutch ICF Activity Inventory: Perceptions of those with retinitis pigmentosa and of those who support them. Invest Ophthalmol Vis Sci.
Latham K, Baranian M, Timmis M, et al. (2015). Emotional health of people with visual impairment caused by retinitis pigmentosa. PLoS ONE.
Latham K, Baranian M, Timmis M, et al. (2015). Emotional health of people with visual impairment caused by retinitis pigmentosa. PLoS ONE.
Lauritzen TZ, Harris J, Mohand-Said S, et al. (2012). Reading visual braille with a retinal prosthesis. Front Neurosci.
Le Gargasson JF, Rigaudiere F, Guez JE, et al. (1994). Contribution of scanning laser ophthalmoscopy to the functional investigation of subjects with macular holes. Doc Ophthalmol.
Legge GE, Beckmann PJ, Tjan BS, et al. (2013). Indoor navigation by people with visual impairment using a digital sign system. PLoS ONE.
Leissner J, Coenen M, Froehlich S, et al. (2014). What explains health in persons with visual impairment?. Health Qual Life Outcomes.
Leplege A, Schemann JF, Diakite B, et al. (2006). A new condition specific quality of life measure for the blind and the partially sighted in Sub-Saharan Africa, the IOTAQoL: methodological aspects of the development procedure. Qual Life Res.
Lepri BP. (2009). Is acuity enough? Other considerations in clinical investigations of visual prostheses. J Neural Eng.
Lesmes LA, Lu ZL, Baek J, et al. (2010). Bayesian adaptive estimation of the contrast sensitivity function: The quick CSF method. J Vis.
Lewis PM, Ackland HM, Lowery AJ, et al. (2015). Restoration of vision in blind individuals using bionic devices: A review with a focus on cortical visual prostheses. Brain Res.
Li X, Chen J, Xu G, et al. (2015). Development of an elderly low vision quality of life questionnaire for less-developed areas of China. Int J Qual Life.
Lim HH, Shannon RV. (2015). Two laskers and counting: learning from the past enables future innovations with central neural prostheses. Brain Stim.
Lin JC, Chie WC. (2010). Psychometric validation of the Taiwan Chinese version of the 25-Item National Eye Institute Visual Functioning Questionnaire. J Eval Clin Pract.
Lin JC, Chie WC. (2010). Psychometric validation of the Taiwan Chinese version of the 25-Item National Eye Institute Visual Functioning Questionnaire: Corrigenda. J Eval Clin Pract.
Lin JC, Yu JH. (2012). Assessment of quality of life among Taiwanese patients with visual impairment. J Formos Med Assoc.
Lin TC, Chang HM, Hsu CC, et al. (2015). Retinal prostheses in degenerative retinal diseases. J Chin Med Assoc.
Lindblad AS, Clemons TE. (2005). Responsiveness of the National Eye Institute Visual Function Questionnaire to progression to advanced age-related macular degeneration, vision loss, and lens opacity: AREDS Report no. 14. Arch Ophthalmol.
Linder M, Chang TS, Scott IU, et al. (1999). Validity of the visual function index (VF-14) in patients with retinal disease. Arch Ophthalmol.
Lipshitz I, Jacob S, Lamba M, et al. (2008). Mirror telescopic intraocular lens for age-related macular degeneration. Design and preliminary clinical results of the Lipshitz macular implant. J Cataract Refract Surg.
Little B. (2009). October consultation #2. J Cataract Refract Surg.
Liu X, Makino H, Kobayashi S, et al. (2006). An indoor guidance system for the blind using fluorescent lights--relationship between receiving signal and walking speed. Conf Proc IEEE Eng Med Biol Soc.
Lloyd AJ, Loftus J, Turner M, et al. (2013). Psychometric validation of the Visual Function Questionnaire-25 in patients with diabetic macular edema. Health Qual Life Outcomes.
Lodha N, Westall CA, Brent M, et al. (2003). A modified protocol for the assessment of visual function in patients with retinitis pigmentosa. Adv Exp Med Biol.
Loewenstein A, Malach R, Goldstein M, et al. (2003). Replacing the Amsler grid: a new method for monitoring patients with age-related macular degeneration. Ophthalmology.
Loizos K, Lazzi G, Lauritzen JS, et al. (2014). A multi-scale computational model for the study of retinal prosthetic stimulation. Conf Proc IEEE Eng Med Biol Soc.
Longworth L, Yang Y, Young T, et al. (2014). Use of generic and condition-specific measures of health-related quality of life in NICE decision-making: a systematic review, statistical modelling and survey. Health Technol Assess.
Lopez-Miguel A, Coco-Martin MB, Martinez-Fernandez R, et al. (2013). Patient-reported outcomes in Spanish patients diagnosed with bilateral age-related macular degeneration. Ophthalmologica.
Lovie-Kitchin JE, Bevan JD, Hein B. (2001). Reading performance in children with low vision. Clin Exp Optom.
Lu Y, Wang J, Wu H, et al. (2014). Recognition of objects in simulated irregular phosphene maps for an epiretinal prosthesis. Artif Organs.
Luna B, Dobson V, Biglan AW. (1990). Development of grating acuity in infants with regressed stage 3 retinopathy of prematurity. Invest Ophthalmol Vis Sci.
Lundstrom M, Wendel E. (2006). Assessment of vision-related quality of life measures in ophthalmic conditions. Expert Rev Pharmacoecon Outcomes Res.
Luo N, Wang X, Ang M, et al. (2015). A vision “bolt-on” item could increase the discriminatory power of the EQ-5D Index Score. Value Health.
Luo YH, Da Cruz L. (2014). A review and update on the current status of retinal prostheses (bionic eye). Br Med Bull.
Luo YH, Zhong JJ, da Cruz L. (2015). The use of Argus® II retinal prosthesis by blind subjects to achieve localisation and prehension of objects in 3-dimensional space. Graefes Arch Clin Exp Ophthalmol.
MacKenzie D. (2010). Electronic device restores sight in the blind. N Sci.
Mackenzie PJ, Chang TS, Scott IU, et al. (2002). Assessment of vision-related function in patients with age-related macular degeneration. Ophthalmology.
Mahadevappa M, Weiland JD, Yanai D, et al. (2005). Perceptual thresholds and electrode impedance in three retinal prosthesis subjects. IEEE Trans Neural Syst Rehabil Eng.
Malkin AG, Goldstein JE, Perlmutter MS, et al. (2013). Responsiveness of the EQ-5D to the effects of low vision rehabilitation. Opt Vis Sci.
Mallinson T. (2007). Why measurement matters for measuring patient vision outcomes. Optom Vis Sci.
Mangione CM, Berry S, Spritzer K, et al. (1998). Identifying the content area for the 51-item National Eye Institute Visual Function Questionnaire: results from focus groups with visually impaired persons. Arch Ophthalmol.
Mangione CM, Lee PP, Gutierrez PR, et al. (2001). Development of the 25-item National Eye Institute Visual Function Questionnaire. Arch Ophthalmol.
Mangione CM, Lee PP, Pitts J, et al. (1998). Psychometric properties of the National Eye Institute Visual Function Questionnaire (NEI-VFQ). NEI-VFQ Field Test Investigators. Arch Ophthalmol.
Mansfield JS, Legge GE, Bane MC. (1996). Psychophysics of reading. XV: Font effects in normal and low vision. Invest Ophthalmol Vis Sci.
Maples WC. (2002). Test-retest reliability of the College of Optometrists in Vision Development Quality of Life Assessment short form. J Optom Vision Dev.
Marella M, Gothwal VK, Pesudovs K, et al. (2009). Validation of the visual disability questionnaire (VDQ) in India. Opt Vis Sci.
Marella M, Pesudovs K, Keeffe JE, et al. (2010). The psychometric validity of the NEI VFQ-25 for use in a low-vision population. Invest Ophthalmol Vis Sci.
Markowitz SN, Reyes SV. (2013). Microperimetry and clinical practice: an evidence-based review. Can J Ophthalmol.
Marmeleira J, Laranjo L, Marques O, et al. (2013). Criterion-related validity of the short form of the International Physical Activity Questionnaire in adults who are blind. J Vis Impair Blind.
Marton K, Kovi Z, Farkas L, et al. (2014). Everyday functions and needs of individuals with disability: a reliability and validity study based on the principles of the ICF. Psychiatr Hung.
Marx MS, Werner P, Cohen-Mansfield J, et al. (1990). Visual acuity estimates in noncommunicative elderly persons. Invest Ophthalmol Vis Sci.
Massof RW, Ahmadian L, Grover LL, et al. (2007). The Activity Inventory: an adaptive visual function questionnaire. Optom Vis Sci.
Massof RW, Ahmadian L. (2007). What do different visual function questionnaires measure?. Ophthalmic Epidemiol.
Massof RW, Fletcher DC. (2001). Evaluation of the NEI visual functioning questionnaire as an interval measure of visual ability in low vision. Vision Res.
Massof RW, Hsu CT, Baker FH, et al. (2005). Visual disability variables. I: the importance and difficulty of activity goals for a sample of low-vision patients. Arch Phys Med Rehabil.
Massof RW, Hsu CT, Baker FH, et al. (2005). Visual disability variables. II: The difficulty of tasks for a sample of low-vision patients. Arch Phys Med Rehabil.
Massof RW. (1998). A systems model for low vision rehabilitation. II. Measurement of vision disabilities. Optom Vis Sci.
Massof RW. (2007). An interval-scaled scoring algorithm for visual function questionnaires. Optom Vis Sci.
Massof RW. (2005). Application of stochastic measurement models to visual function rating scale questionnaires. Ophthalmic Epidemiol.
Massof RW. (2004). Likert and Guttman scaling of visual function rating scale questionnaires. Ophthalmic Epidemiol.
Massof RW. (2002). The measurement of vision disability. Optom Vis Sci.
Mathew R, Sivaprasad S. (2012). Environmental Amsler test as a monitoring tool for retreatment with ranibizumab for neovascular age-related macular degeneration. Eye (Lond).
Mazella A, Albaret JM, Picard D. (2016). Haptic-2D: A new haptic test battery assessing the tactual abilities of sighted and visually impaired children and adolescents with two-dimensional raised materials. Res Dev Disabil.
McCabe P, Nason F, Demers Turco P, et al. (2000). Evaluating the effectiveness of a vision rehabilitation intervention using an objective and subjective measure of functional performance. Ophthalmic Epidemiol.
McCarthy C, Barnes N. (2012). Time-to-contact maps for navigation with a low resolution visual prosthesis. Conf Proc IEEE Eng Med Biol Soc.
McCarthy C, Walker JG, Lieby P, et al. (2015). Mobility and low contrast trip hazard avoidance using augmented depth. J Neural Eng.
McClure ME, Hart PM, Jackson AJ, et al. (2000). Macular degeneration: do conventional measurements of impaired visual function equate with visual disability?. Br J Ophthalmol.
McGregor LN, Chaparro A. (2005). Visual difficulties reported by low-vision and nonimpaired older adult drivers. Hum Factors.
McKean-Cowdin R, Varma R, Wu J, et al. (2007). Severity of visual field loss and health-related quality of life. Am J Ophthalmol.
Melillo P, Orrico A, Attanasio M, et al. (2015). A pilot study for development of a novel tool for clinical decision making to identify fallers among ophthalmic patients. BMC Med Inform Decis Mak.
Messias K, Jagle H, Saran R, et al. (2013). Psychophysically determined full-field stimulus thresholds (FST) in retinitis pigmentosa: relationships with electroretinography and visual field outcomes. Doc Ophthalmol.
Miller KM. (2008). August consultation #5. J Cataract Refract Surg.
Misajon R, Hawthorne G, Richardson J, et al. (2005). Vision and quality of life: the development of a utility measure. Invest Ophthalmol Vis Sci.
Miskala PH, Bressler NM, Meinert CL. (2004). Relative contributions of reduced vision and general health to NEI-VFQ scores in patients with neovascular age-related macular degeneration. Arch Ophthalmol.
Miskala PH, Hawkins BS, Mangione CM, et al. (2003). Responsiveness of the National Eye Institute Visual Function Questionnaire to changes in visual acuity: findings in patients with subfoveal choroidal neovascularization--SST Report No. 1. Arch Ophthalmol.
Mitchell J, Bradley C. (2004). Design of an individualised measure of the impact of macular disease on quality of life (the MacDQoL). Qual Life Res.
Mitchell J, Bradley C. (2001). Psychometric evaluation of the 12-item Well-being Questionnaire for use with people with macular disease. Qual Life Res.
Mitchell J, Bradley C. (2006). Quality of life in age-related macular degeneration: a review of the literature.
Mitchell J, Wolffsohn J, Woodcock A, et al. (2008). The MacDQoL individualized measure of the impact of macular degeneration on quality of life: reliability and responsiveness. Am J Ophthalmol.
Mitchell J, Wolffsohn JS, Woodcock A, Anderson SJ, McMillan CV, Ffytche T, Rubinstein M, Amoaku W, Bradley C. (2005). +Psychometric evaluation of the MacDQoL individualised measure of the impact of macular degeneration on quality of life. Health Qual Life Outcomes.
Mitchell P, Bressler N, Tolley K, et al. (2013). Patient-reported visual function outcomes improve after ranibizumab treatment in patients with vision impairment due to diabetic macular edema: randomized clinical trial. JAMA Ophthalmol.
Miwa M, Iwanami M, Oba MS, et al. (2013). Comparison of LogMAR Eye charts with angular vision for visually impaired: the Berkeley rudimentary vision test vs LogMAR One target Landolt ring Eye chart. Graefes Arch Clin Exp Ophthalmol.
Moganeswari D, Thomas J, Srinivasan K, et al. (2015). Test re-test reliability and validity of different visual acuity and stereoacuity charts used in preschool children. J Clin Diagn Res.
Monge M, Raj M, Nazari MH, et al. (2013). A fully intraocular high-density self-calibrating epiretinal prosthesis. IEEE Trans Biomed Circuits Syst.
Morrow T. (2013). Retinal implant brings some sight to profound retinitis pigmentosa patients. Manag Care.
Nanduri D, Fine I, Horsager A, et al. (2012). Frequency and amplitude modulation have different effects on the percepts elicited by retinal stimulation. Invest Ophthalmol Vis Sci.
Nanduri D, Humayun MS, Greenberg RJ, et al. (2008). Retinal prosthesis phosphene shape analysis. Conf Proc IEEE Eng Med Biol Soc.
Nau A, Bach M, Fisher C. (2013). Clinical tests of ultra-low vision used to evaluate rudimentary visual perceptions enabled by the brainport vision device. Transl Vis Sci Technol.
Nau AC, Pintar C, Fisher C, et al. (2014). A standardized obstacle course for assessment of visual function in ultra low vision and artificial vision. J Vis Exp.
Nayagam DA, Durmo I, McGowan C, et al. (2015). Techniques for processing eyes implanted with a retinal prosthesis for localized histopathological analysis: Part 2 Epiretinal implants with retinal tacks. J Vis Exp.
Nelson PA, Dial JG, Joyce A. (2002). Validation of the cognitive test for the blind as an assessment of intellectual functioning. Rehabil Psychol.
Nevyas-Wallace A. (2010). February consultation #3. J Cataract Refract Surg.
Niederlander C, Wahlster P, Kriza C, et al. (2013). Registries of implantable medical devices in Europe. Health Policy.
Novack GD. (2013). Fill size for ophthalmic products. Ocul Surf.
Novak CB, Mackinnon SE, Williams JI, et al. (1993). Development of a new measure of fine sensory function. Plast Reconstr Surg.
Nutheti R, Shamanna BR, Nirmalan PK, et al. (2006). Impact of impaired vision and eye disease on quality of life in Andhra Pradesh. Invest Ophthalmol Vis Sci.
OConnor PM, Lamoureux EL, Keeffe JE. (2008). Predicting the need for low vision rehabilitation services. Br J Ophthalmol.
OConnor PM, Scarr BC, Lamoureux EL, et al. (2010). Validation of a quality of life questionnaire in the Pacific Island. Ophthalmic Epidemiol.
Ohta J, Tokuda T, Kagawa K, et al. (2006). Silicon LSI-based smart stimulators for retinal prosthesis: A flexible and extendable microchip-based stimulator. IEEE Eng Med Biol Mag.
Opie NL, Ayton LN, Apollo NV, et al. (2014). Optical coherence tomography-guided retinal prosthesis design: model of degenerated retinal curvature and thickness for patient-specific devices. Artif Organs.
Orr P, Rentz AM, Margolis MK, et al. (2011). Validation of the National Eye Institute Visual Function Questionnaire-25 (NEI VFQ-25) in age-related macular degeneration. Invest Ophthalmol Vis Sci.
Orticio LP. (2007). Measuring health-related quality of life among older visually impaired adults: a preview to instrument construction. Insight.
Owsley C, Huisingh C, Clark ME, et al. (2015). Comparison of visual function in older eyes in the earliest stages of age-related macular degeneration to those in normal macular health. Curr Eye Res.
Owsley C, McGwin G, Scilley K, et al. (2006). Development of a questionnaire to assess vision problems under low luminance in age-related maculopathy. Invest Ophthalmol Vis Sci.
Pach J, Gekeler F. (2013). Therapeutic approaches for retinitis pigmentosa. Klin Monbl Augenheilkd.
Parikh N, Itti L, Humayun M, et al. (2013). Performance of visually guided tasks using simulated prosthetic vision and saliency-based cues. J Neural Eng.
Parikh NJ, McIntosh BP, Tanguay AR, et al. (2009). Biomimetic image processing for retinal prostheses: peripheral saliency cues. Conf Proc IEEE Eng Med Biol Soc.
Park RI. (2004). The bionic eye: Retinal prostheses. Int Ophthalmol Clin.
Park Y, Shin JA, Yang SW, et al. (2015). The relationship between visual impairment and health-related quality of life in Korean adults: The Korea national health and nutrition examination survey (2008-2012). PLoS ONE.
Patel PJ, Chen FK, Da Cruz L, et al. (2011). Test-retest variability of reading performance metrics using MNREAD in patients with age-related macular degeneration. Invest Ophthalmol Vis Sci.
Paudel P, Khadka J, Burnett A, et al. (2015). Papua New Guinea vision-specific quality of life questionnaire: A new patient-reported outcome instrument to assess the impact of impaired vision. Clin Experiment Ophthalmol.
Payakachat N, Summers KH, Pleil AM, et al. (2009). Predicting EQ-5D utility scores from the 25-item National Eye Institute Vision Function Questionnaire (NEI-VFQ 25) in patients with age-related macular degeneration. Qual Res Life.
Paz SH, Globe DR, Wu J, et al. (2003). Relationship between self-reported depression and self-reported visual function in Latinos. Arch Ophthalmol.
Paz SH, Slotkin J, McKean-Cowdin R, et al. (2013). Development of a vision-targeted health-related quality of life item measure. Qual Res Life.
Penrod WM, Petrosko J. (2003). Spatial organization skills of the blind in large outdoor places. RE:view.
Peters AY, Locke KG, Birch DG. (2000). Comparison of the Goldmann-Weekers dark adaptometer and LKC Technologies Scotopic Sensitivity tester-1. Doc Ophthalmol.
Peters T, Klingberg S, Zrenner E, et al. (2013). Emotional wellbeing of blind patients in a pilot trial with subretinal implants. Graefes Arch Clin Exp Ophthalmol.
Petrillo J, Cano SJ, McLeod LD, et al. (2015). Using classical test theory, item response theory, and Rasch measurement theory to evaluate patient-reported outcome measures: a comparison of worked examples. Value Health.
Pezaris J. (2011). A novel approach to visual prosthetics. Neurosci Lett.
Picaud S, Sahel JA. (2014). Retinal prostheses: Clinical results and future challenges. C R Biol.
Piermarocchi S, Varano M, Parravano M, et al. (2011). Quality of Vision Index: a new method to appraise visual function changes in age-related macular degeneration. Eur J Ophthalmol.
Posey VK, Henderson BW. (2012). Comprehensive adult student assessment systems braille reading assessment: an exploratory study. J Vis Impair Blind.
Rahimy E, Reddy S, Decroos FC, et al. (2015). Prospective evaluation of visual acuity agreement between standard early treatment diabetic retinopathy study chart and a handheld equivalent in eyes with retinal pathology. Retina.
Rees G, Ponczek E, Hassell J, et al. (2010). Psychological outcomes following interventions for people with low vision: A systematic review. Expert Rev Ophthalmol.
Rees G, Xie J, Holloway EE, et al. (2013). Identifying distinct risk factors for vision-specific distress and depressive symptoms in people with vision impairment. Invest Ophthalmol Vis Sci.
Reeves BC, Langham J, Walker J, et al. (2009). Verteporfin photodynamic therapy cohort study: report 2: clinical measures of vision and health-related quality of life. Ophthalmology.
Regillo CD. (2009). Retinal implant shows promising early results in clinical trial. Ocular Surg News.
Reischies FM, Geiselmann B. (1997). Age-related cognitive and vision impairment affecting the detection of dementia syndrome in old age. Br J Psychiatry.
(2014). Restoring vision to the blind: Evaluating visual function, endpoints. Transl Vis Sci Technol.
(2014). Restoring vision to the blind: The new age of implanted visual prostheses. Transl Vis Sci Technol.
(2009). Retinal implant offers the potential for sight to blind patients. Ocular Surg News.
Revicki DA, Rentz AM, Harnam N, et al. (2010). Reliability and validity of the National Eye Institute Visual Function Questionnaire-25 in patients with age-related macular degeneration. Invest Ophthalmol Vis Sci.
Rieger V, Aryan NP, Brendler C, et al. (2014). Benefit of spatial filtering for visual perception with a subretinal implant. Conf Proc IEEE Eng Med Biol Soc.
Rizzo JF, Wyatt J, Loewenstein J, et al. (2003). Methods and perceptual thresholds for short-term electrical stimulation of human retina with microelectrode arrays. Invest Ophthalmol Vis Sci.
Rizzo JF, Wyatt J, Loewenstein J, et al. (2003). Perceptual efficacy of electrical stimulation of human retina with a microelectrode array during short-term surgical trials. Invest Ophthalmol Vis Sci.
Rock T, Bartz-Schmidt KU, Bramkamp M, et al. (2014). Influence of axial length on thickness measurements using spectral-domain optical coherence tomography. Invest Ophthalmol Vis Sci.
Roentgen UR, Gelderblom GJ, de Witte LP. (2012). The development of an indoor mobility course for the evaluation of electronic mobility aids for persons who are visually impaired. Assist Technol.
Roets Merken LM, Zuidema SU, Vernooij Dassen MJ, et al. (2014). Screening for hearing, visual and dual sensory impairment in older adults using behavioural cues: A validation study. Int J Nurs Stud.
Rohrschneider K, Bultmann S, Gluck R, et al. (2000). Scanning laser ophthalmoscope fundus perimetry before and after laser photocoagulation for clinically significant diabetic macular edema. Am J Ophthalmol.
Rohrschneider K, Springer C, Bultmann S, et al. (2005). Microperimetry--comparison between the micro perimeter 1 and scanning laser ophthalmoscope--fundus perimetry. Am J Ophthalmol.
Rosenberg R. (1992). Low vision. Curr Opin Ophthalmol.
Rosenfeld JV. (2015). The development of a wireless multi-electrode cortical prosthesis for restoration of vision in blind individuals. J Neurosurg.
Rosenfeld JV, Lewis P. (2013). Progress in bionic vision devices. Stereotact Funct Neurosurg.
Rossi GC, Milano G, Tinelli C. (2003). The Italian version of the 25-item National Eye Institute Visual Function Questionnaire: translation, validity, and reliability. J Glaucoma.
Rovner BW, Casten RJ, Tasman WS. (2002). Effect of depression on vision function in age-related macular degeneration. Arch Ophthalmol.
Rozanski C, Haythornthwaite JA, Dagnelie G, et al. (2014). Applying theories and interventions from behavioral medicine to understand and reduce visual field variability in patients with vision loss. Med Hypotheses.
Rubin GS, Bandeen-Roche K, Huang GH, et al. (2001). The association of multiple visual impairments with self-reported visual disability: SEE project. Invest Ophthalmol Vis Sci.
Rubin GS, West SK, Munoz B, et al. (1997). A comprehensive assessment of visual impairment in a population of older Americans. The SEE Study. Salisbury Eye Evaluation Project. Invest Ophthalmol Vis Sci.
Rubin GS. (2013). Measuring reading performance. Vision Res.
Ryan B, Court H, Margrain TH. (2008). Measuring low vision service outcomes: Rasch analysis of the seven-item National Eye Institute Visual Function Questionnaire. Optom Vis Sci.
Sabariego C, Oberhauser C, Posarac A, et al. (2015). Measuring disability: Comparing the impact of two data collection approaches on disability rates. Int J Environ Res Public Health.
Sabbah N, Authie CN, Sanda N, et al. (2014). Importance of eye position on spatial localization in blind subjects wearing an argus II retinal prosthesis. Invest Ophthalmol Vis Sci.
Sakaguchi H, Kamei M, Fujikado T, et al. (2009). Artificial vision by direct optic nerve electrode (AV-DONE) implantation in a blind patient with retinitis pigmentosa. J Artif Organs.
Saunders AL, Williams CE, Heriot W, et al. (2014). Development of a surgical procedure for implantation of a prototype suprachoroidal retinal prosthesis. Clin Experiment Ophthalmol.
Sawa M, et al. (2003). Question and answer sessions with Dr. George O. Waring, III. Ophthalmologica.
Sawa Y, Tatsumi E, Funakubo A, et al. (2010). Journal of artificial organs 2009: The year in review. J Artif Organs.
Schemann JF, Leplege A, Keita T, Resnikoff S. (2002). From visual function deficiency to handicap: measuring visual handicap in Mali. Ophthalmic Epidemiol.
Schmier JK, Halpern MT, Covert D. (2006). Validation of the Daily Living Tasks Dependent on Vision (DLTV) questionnaire in a U.S. population with age-related macular degeneration. Ophthalmic Epidemiol.
Schulze-Bonsel K, Feltgen N, Burau H, et al. (2006). Visual acuities “hand motion” and “counting fingers” can be quantified with the freiburg visual acuity test. Invest Ophthalmol Vis Sci.
Schweitzer KD, Eneh AA, Hurst J, et al. (2011). Validation of patient symptom diary in acute posterior vitreous detachment. Saudi J Ophthalmol.
Scilley K, Owsley C. (2002). Vision-specific health-related quality of life: content areas for nursing home residents. Qual Life Res.
Scott IU, Schein OD, West S, et al. (1994). Functional status and quality of life measurement among ophthalmic patients. Arch Ophthalmol.
Scott IU, Smiddy WE, Schiffman J, et al. (1999). Quality of life of low-vision patients and the impact of low-vision services. Am J Ophthalmol.
(2012). Second human trial under way with retina implants for retinitis pigmentosa. Ocular Surg News.
Sengupta S, Nguyen AM, van Landingham SW, et al. (2015). Evaluation of real-world mobility in age-related macular degeneration. BMC Ophthalmol.
Serafano D. (2007). August Consultation # 9. J Cataract Refract Surg.
Shah N, Dakin SC, Dobinson S, et al. (2016). Visual acuity loss in patients with age-related macular degeneration measured using a novel high-pass letter chart. Br J Ophthalmol.
Sharma S, Oliver-Fernandez A. (2004). Age-related macular degeneration and quality of life: how to interpret a research paper in health-related quality of life. Curr Opin Ophthalmol.
Shaw A, Gold D. (2011). Development of a tool for the assessment of employment preparedness specifically for persons who are blind or partially sighted. Work.
Shivdasani MN, Sinclair NC, Dimitrov PN, et al. (2014). Factors affecting perceptual thresholds in a suprachoroidal retinal prosthesis. Invest Ophthalmol Vis Sci.
Shrestha GS, Kaiti R. (2014). Visual functions and disability in diabetic retinopathy patients. J Optom.
Siepser SB. (2008). August consultation #8. J Cataract Refract Surg.
(2010). Sight restored. N Sci.
Simunovic MP. (2015). Metamorphopsia and its quantification. Retina.
Sin M, Rehak M, Chrapek O, et al. (2011). Cesk Slov Oftalmol.
Singer MA, Amir N, Herro A, et al. (2011). Improving quality of life in patients with end-stage age-related macular degeneration: Focus on miniature ocular implants. Clin Ophthalmol.
Skalicky SE, Fenwick E, Martin KR, et al. (2016). Impact of age-related macular degeneration in patients with glaucoma: understanding the patients' perspective. Clin Experiment Ophthalmol.
Slakter JS, Schneebaum JW, Shah SA. (2015). Digital algorithmic diabetic retinopathy severity scoring system (an American Ophthalmological Society thesis). Trans Am Ophthalmol Soc.
Slater KD, Sinclair NC, Nelson TS, et al. (2015). NeuroBi: a highly configurable neurostimulator for a retinal rrosthesis and other applications. IEEE J Transl Eng Health Med.
Smith J, Ward D, Michaelides M, et al. (2015). New and emerging technologies for the treatment of inherited retinal diseases: A horizon scanning review. Eye (Lond).
Smith SC. (2002). Eye on research: retinal microchip implants. Insight.
Smith TM. (2013). Refinement of the Low Vision Independence Measure: A qualitative study. Phys Occup Ther Geriatr.
Smretschnig E, Falkner-Radler CI, Binder S, et al. (2015). Vision-related quality of life and visual function after retinal detachment surgery. Retina.
Snyder ME. (2008). August consultation #2. J Cataract Refract Surg.
Sommerhalder J, Rappaz B, De Haller R, et al. (2004). Simulation of artificial vision: II. Eccentric reading of full-page text and the learning of this task. Vision Res.
Sonn U. (1996). Longitudinal studies of dependence in daily life activities among elderly persons. Scand J Rehabil Med Suppl.
Sorensen MS, Andersen S, Henningsen GO, et al. (2011). Danish version of Visual Function Questionnaire-25 and its use in age-related macular degeneration. Dan Med Bull.
Srinivasan K, Ramesh SV, Babu N, et al. (2012). Efficacy of a remote based computerised visual acuity measurement. Br J Ophthalmol.
Stacey A, Li Y, Barnes N. (2011). A salient information processing system for bionic eye with application to obstacle avoidance. Conf Proc IEEE Eng Med Biol Soc.
Stelmack J, Szlyk JP, Stelmack T, et al. (2004). Use of Rasch person-item map in exploratory data analysis: a clinical perspective. J Rehabil Res Dev.
Stelmack J. (2001). Quality of life of low-vision patients and outcomes of low-vision rehabilitation. Optom Vis Sci.
Stelmack JA, Massof RW. (2007). Using the VA LV VFQ-48 and LV VFQ-20 in low vision rehabilitation. Optom Vis Sci.
Stelmack JA, Szlyk JP, Stelmack TR, et al. (2006). Measuring outcomes of vision rehabilitation with the Veterans Affairs Low Vision Visual Functioning Questionnaire. Invest Ophthalmol Vis Sci.
Stelmack JA, Szlyk JP, Stelmack TR, et al. (2004). Psychometric properties of the Veterans Affairs Low-Vision Visual Functioning Questionnaire. Invest Ophthalmol Vis Sci.
Stelmack JA, Tang XC, Reda DJ, et al. (2008). Outcomes of the Veterans Affairs Low Vision Intervention Trial (LOVIT). Arch Ophthalmol.
Stelmack JA, Tang XC, Reda DJ, et al. (2007). The Veterans Affairs Low Vision Intervention Trial (LOVIT): design and methodology. Clin Trials.
Stingl K, Bartz KU, Gekeler F, et al. (2013). Functional outcome in subretinal electronic implants depends on foveal eccentricity. Invest Ophthalmol Vis Sci.
Stingl K, Bartz-Schmidt KU, Besch D, et al. (2013). Artificial vision with wirelessly powered subretinal electronic implant alpha-IMS. Proc Biol Sci.
Stingl K, Bartz-Schmidt KU, Besch D, et al. (2012). What can blind patients see in daily life with the subretinal Alpha IMS implant?: Current overview from the clinical trial in Tubingen. Ophthalmologe.
Stingl K, Gekeler F, Bartz-Schmidt KU, et al. (2013). Fluorescein angiographic findings in eyes of patients with a subretinal electronic implant. Curr Eye Res.
Stronks HC, Barry MP, Dagnelie G. (2016). Electrically evoked electroretinograms and pupil responses in Argus II retinal implant wearers. Doc Ophthalmol.
Submacular Surgery Trials Research Group. (2007). Evaluation of minimum clinically meaningful changes in scores on the National Eye Institute Visual Function Questionnaire (NEI-VFQ) SST Report Number 19. Ophthalmic Epidemiol.
Subramanian A, Dickinson C. (2006). Spatial localization in visual impairment. Invest Ophthalmol Vis Sci.
Sugawara T, Sato E, Baba T, et al. (2011). Relationship between vision-related quality of life and microperimetry-determined macular sensitivity in patients with retinitis pigmentosa. Jpn J Ophthalmol.
Suner IJ, Kokame GT, Yu E, et al. (2009). Responsiveness of NEI VFQ-25 to changes in visual acuity in neovascular AMD: validation studies from two phase 3 clinical trials. Invest Ophthalmol Vis Sci.
Suzukamo Y, Oshika T, Yuzawa M, et al. (2005). Psychometric properties of the 25-item National Eye Institute Visual Function Questionnaire (NEI VFQ-25), Japanese version. Health Qual Life Outcomes.
Szlyk JP, Arditi A, Bucci PC, et al. (1990). Self-report in functional assessment of low vision. J Vis Impair Blind.
Szlyk JP, Coffey B, Arditi A, et al. (1990). Self-report in functional assessment of low vision. J Vis Impairm Blindn.
Szlyk JP, Fishman GA, Alexander KR, et al. (1997). Relationship between difficulty in performing daily activities and clinical measures of visual function in patients with retinitis pigmentosa. Arch Ophthalmol.
Szlyk JP, Seiple W, Fishman GA, et al. (2001). Perceived and actual performance of daily tasks: relationship to visual function tests in individuals with retinitis pigmentosa. Ophthalmology.
Szlyk JP, Stelmack J, Massof RW, et al. (2004). Performance of the Veterans Affairs low vision visual functioning questionnaire. J Vis Impair Blind.
Szlyk JP, Stelmack J, Massof RW, et al. (2004). Performance of the Veterans Affairs Low Vision Visual Functioning Questionnaire. J Vis Impairm Blindn.
Tabrett DR, Latham K. (2011). Factors influencing self-reported vision-related activity limitation in the visually impaired. Invest Ophthalmol Vis Sci.
Tadic V, Cooper A, Cumberland P, et al. (2013). Development of the functional vision questionnaire for children and young people with visual impairment: the FVQ_CYP. Ophthalmology.
Tamaki M, Matsuo T. (2011). Optical coherence tomographic parameters as objective signs for visual acuity in patients with retinitis pigmentosa, future candidates for retinal prostheses. J Artif Organs.
Tejeria L, Harper RA, Artes PH, et al. (2002). Face recognition in age related macular degeneration: perceived disability, measured disability, and performance with a bioptic device. Br J Ophthalmol.
Tosh J, Brazier J, Evans P, et al. (2012). A review of generic preference-based measures of health-related quality of life in visual disorders. Value Health.
Tranos PG, Topouzis F, Stangos NT, et al. (2004). Effect of laser photocoagulation treatment for diabetic macular oedema on patient's vision-related quality of life. Curr Eye Res.
Trauzettel-Klosinski S, Biermann P, Hahn G, et al. (2003). Assessment of parafoveal function in maculopathy: a comparison between the Macular Mapping Test and kinetic Manual Perimetry. Graefes Arch Clin Exp Ophthalmol.
Tregear SJ, Ripley LG, Knowles PJ, et al. (1994). Automated tritan discrimination sensitivity: A new clinical technique for the effective screening of severe diabetic retinopathy. Int J Psychophysiol.
Trento M, Passera P, Trevisan M, et al. (2013). Quality of life, impaired vision and social role in people with diabetes: a multicenter observational study. Acta Diabetol.
Tunay ZO, Caliskan D, Oztuna D, et al. (2015). Validation and reliability of the CardiffVisual Ability Questionnaire for children using Rasch analysis in a Turkish population. Br J Ophthalmol.
Turano KA, Geruschat DR, Stahl JW, et al. (1999). Perceived visual ability for independent mobility in persons with retinitis pigmentosa. Invest Ophthalmol Vis Sci.
Turco PD, Connolly J, McCabe P, et al. (1994). Assessment of functional vision performance: a new test for low vision patients. Ophthalmic Epidemiol.
Unver YB, Yavuz GA, Sinclair SH. (2009). Interactive, computer-based, self-reported, visual function questionnaire: the PalmPilot-VFQ. Eye (Lond).
Uppal G, Milliken A, Lee J, et al. (2007). New algorithm for assessing patient suitability for macular translocation surgery. Clin Experiment Ophthalmol.
(2014). Users of retinal prosthesis system accumulate implant time since FDA approval. Ocular Surg News.
Van De Put MA, Vehof J, Hooymans JM, et al. (2015). Postoperative metamorphopsia in macula-off rhegmatogenous retinal detachment: Associations with visual function, vision related quality of life, and optical coherence tomography findings. PLoS ONE.
Van Der Aa HPA, Van Rens GHMB, Comijs HC, et al. (2015). Stepped care for depression and anxiety in visually impaired older adults: multicentre randomised controlled trial. BMJ.
van Nispen RM, de Boer MR, van Rens GH. (2009). Additional psychometric information and vision-specific questionnaires are available for age-related macular degeneration. Qual Life Res.
van Nispen RM, Knol DL, Langelaan M, et al. (2007). Applying multilevel item response theory to vision-related quality of life in Dutch visually impaired elderly. Optom Vis Sci.
van Nispen RM, Knol DL, Langelaan M, et al. (2011). Re-evaluating a vision-related quality of life questionnaire with item response theory (IRT) and differential item functioning (DIF) analyses. BMC Med Res Methodol.
van Nispen RM, Knol DL, Mokkink LB, et al. (2010). Vision-related quality of life Core Measure (VCM1) showed low-impact differential item functioning between groups with different administration modes. J Clin Epidemiol.
Velikay-Parel M, Ivastinovic D, Georgi T, et al. (2013). A test method for quantification of stimulus-induced depression effects on perceptual threshold in epiretinal prosthesis. Acta Ophthalmol.
Velikay-Parel M, Ivastinovic D, Hornig R, et al. (2006). Retina implant: Up date on artificial vision. Spektr Augenheilkunde.
Velozo CA, Warren M, Hicks E, et al. (2013). Generating clinical outputs for self-reports of visual functioning. Opt Vis Sci.
Verdugo MA, Prieto G, Caballo C, et al. (2005). Factorial structure of the quality of life questionnaire in a Spanish sample of visually disabled adults. Eur J Psychol Assess.
Viola MV, Patrinos AA. (2007). A neuroprosthesis for restoring sight. Acta Neurochir Suppl.
Virgili G, Rubin G. (2003). Orientation and mobility training for adults with low vision. Cochrane Database Syst Rev.
Vurro M, Baselli G, Orabona F, et al. (2006). Simulation and assessment of bioinspired visual processing system for epi-retinal prostheses. Conf Proc IEEE Eng Med Biol Soc.
Wang J, Wu X, Lu Y, et al. (2014). Face recognition in simulated prosthetic vision: Face detection-based image processing strategies. J Neural Eng.
Wang LL, Liu WJ, Liu HY, et al. (2015). Single-site baseline and short-term outcomes of clinical characteristics and life quality evaluation of Chinese wet age-related macular degeneration patients in routine clinical practice. Chin Med J.
Waninge A, van Wijck R, Steenbergen B, et al. (2011). Feasibility and reliability of the modified Berg Balance Scale in persons with severe intellectual and visual disabilities. J Intellect Disabil Res.
Warrian KJ, Katz LJ, Myers JS, et al. (2015). A comparison of methods used to evaluate mobility performance in the visually impaired. Br J Ophthalmol.
Warrian KJ, Lorenzana LL, Lankaranian D, et al. (2009). Assessing age-related macular degeneration with the ADREV performance-based measure. Retina.
Warrian KJ, Lorenzana LL, Lankaranian D, et al. (2010). The assessment of disability related to vision performance-based measure in diabetic retinopathy. Am J Ophthalmol.
Watson GR, De lAune W, Long S, et al. (1997). Veterans' use of low vision devices for reading. Optom Vis Sci.
Watson GR, Wright V, Long S, et al. (1996). A low vision reading comprehension test. J Vis Impair Blind.
Weger M, Pichler T, Franke GH, et al. (2014). Assessment of vision-related quality of life in patients with central retinal artery occlusion. Retina.
Weih LM, Hassell JB, Keeffe J. (2002). Assessment of the impact of vision impairment. Invest Ophthalmol Vis Sci.
Weiland JD, Humayun MS. (2005). A biomimetic retinal stimulating array. IEEE Eng Med Biol Mag.
Weiland JD, Parikh N, Pradeep V, et al. (2012). Smart image processing system for retinal prosthesis. Conf Proc IEEE Eng Med Biol Soc.
Weiland JD, Yanai D, Mahadevappa M, et al. (2004). Visual task performance in blind humans with retinal prosthetic implants. Conf Proc IEEE Eng Med Biol Soc.
Weitz AC, Behrend MR, Ahuja AK, et al. (2014). Interphase gap as a means to reduce electrical stimulation thresholds for epiretinal prostheses. J Neural Eng.
Weitz AC, Nanduri D, Behrend MR, et al. (2015). Improving the spatial resolution of epiretinal implants by increasing stimulus pulse duration. Sci Transl Med.
Weleber RG, Smith TB, Peters D, et al. (2015). VFMA: Topographic Analysis of Sensitivity Data From Full-Field Static Perimetry. Transl Vis Sci Technol.
West CG, Gildengorin G, Haegerstrom-Portnoy G, et al. (2003). Vision and driving self-restriction in older adults. J Am Geriatr Soc.
West SK, Rubin GS, Broman AT, et al. (2002). How does visual impairment affect performance on tasks of everyday life? The SEE Project. Salisbury Eye Evaluation. Arch Ophthalmol.
Wilke R, Gabel VP, Sachs H, et al. (2011). Spatial resolution and perception of patterns mediated by a subretinal 16-electrode array in patients blinded by hereditary retinal dystrophies. Invest Ophthalmol Vis Sci.
Williams RA, Brody BL, Thomas RG, et al. (1998). The psychosocial impact of macular degeneration. Arch Ophthalmol.
Wittich W, Overbury O, Kapusta MA, et al. (2005). Visual function assessment and metamorphopsia after macular hole surgery. Ophthal Physiol Opt.
Wolffe KE, Ajuwon PM, Kelly SM. (2013). Working with visual impairment in Nigeria: A qualitative look at employment status. J Vis Impair Blind.
Wolffsohn JS, Cochrane AL, Watt NA. (2000). Implementation methods for vision related quality of life questionnaires. Br J Ophthalmol.
Wolffsohn JS, Cochrane AL. (2000). Design of the low vision quality-of-life questionnaire (LVQoL) and measuring the outcome of low-vision rehabilitation. Am J Ophthalmol.
Wolffsohn JS, Jackson J, Hunt OA, et al. (2014). An enhanced functional ability questionnaire (faVIQ) to measure the impact of rehabilitation services on the visually impaired. Int J Ophthalmol.
Woodcock A, Bradley C, Plowright R, et al. (2004). The influence of diabetic retinopathy on quality of life: interviews to guide the design of a condition-specific, individualised questionnaire: the RetDQoL. Patient Educ Couns.
Wooten BR, Renzi LM, Moore R, et al. (2010). A practical method of measuring the human temporal contrast sensitivity function. Biomed Opt Express.
Wrobel WG, Banzhaf A, Blaess G, et al. (2011). A new system for the treatment of retinal degeneration. Biomed Tech.
Wu AW, Coleson LC, Holbrook J, et al. (1996). Measuring visual function and quality of life in patients with cytomegalovirus retinitis. Development of a questionnaire. Studies of Ocular Complication of AIDS Research Group. Arch Ophthalmol.
Wu Z, Guymer RH, Finger RP. (2015). Low luminance deficit and night vision symptoms in intermediate age-related macular degeneration. Br J Ophthalmol.
Wu Z, Guymer RH, Jung CJ, et al. (2015). Measurement of Retinal Sensitivity on Tablet Devices in Age-Related Macular Degeneration. Transl Vis Sci Technol.
Wulsin LR, Jacobson AM, Rand LI. (1993). Psychosocial adjustment to advanced proliferative diabetic retinopathy. Diabetes Care.
Xia P, Hu J, Qi J, et al. (2015). MEMS-based system and image processing strategy for epiretinal prosthesis. Biomed Mater Eng.
Xia Y, Peng X, Ren Q. (2012). Retinitis pigmentosa patients' attitudes toward participation in retinal prosthesis trials. Contemp Clin Trials.
Yamamoto S, Sugawara T, Murakami A, et al. (2012). Topical isopropyl unoprostone for retinitis pigmentosa: microperimetric results of the phase 2 clinical study. Ophthalmol Ther.
Yanai D, Lakhanpal RR, Weiland JD, et al. (2003). The value of preoperative tests in the selection of blind patients for a permanent microelectronic implant. Trans Am Ophthalmol Soc.
Yanai D, Weiland JD, Mahadevappa M, et al. (2007). Visual performance using a retinal prosthesis in three subjects with retinitis pigmentosa. Am J Ophthalmol.
Yingyong P. (2007). Evaluation of the Thai, Low Vision Quality-of-Life Questionnaire (LVQoL). J Med Assoc Thai.
Yochim BP, Beaudreau SA, Fairchild JK, et al. (2015). Verbal Naming Test for use with older adults: Development and initial validation. J Int Neuropsychol Soc.
Yue L, Falabella P, Christopher P, et al. (2015). Ten-year follow-up of a blind patient chronically implanted with epiretinal prosthesis Argus I. Ophthalmology.
Yuzawa M, Fujita K, Tanaka E, et al. (2013). Assessing quality of life in the treatment of patients with age-related macular degeneration: Clinical research findings and recommendations for clinical practice. Clin Ophthalmol.
Zapf MP, Boon MY, Matteucci PB, et al. (2015). Towards an assistive peripheral visual prosthesis for long-term treatment of retinitis pigmentosa: Evaluating mobility performance in immersive simulations. J Neural Eng.
Zebehazy KT, Zigmond N, Zimmerman GJ. (2012). Ability or access-ability: Differential item functioning of items on alternate performance-based assessment tests for students with visual impairments. J Vis Impair Blind.
Zhang XJ, Wang AP, Yin AC. (2014). The impact of psychosocial adaptation status on quality of life for Chinese patients with visual impairments. J Clin Nurs.
Zhang XJ, Wang AP. (2011). Development of a psychosocial adaptation questionnaire for Chinese patients with visual impairments. J Clin Nurs.
Zou H, Zhang X, Xu X, et al. (2005). Development and psychometric tests of the Chinese-version Low Vision Quality of Life Questionnaire. Qual Life Res.
Zrenner E, Bartz Schmidt KU, Gekeler F, et al. (2012). What retinitis pigmentosa patients can see with the new subretinal wireless implant alpha-IMS. Doc Ophthalmol.
Zrenner E, Bartz-Schmidt KU, Chee C, et al. (2014). (16:45) Visual outcome in 26 blind retinitis pigmentosa patients after receiving electronic subretinal implant Alpha-IMS. Doc Ophthalmol.
Zrenner E, Bartz-Schmidt KU, Gekeler F, et al. (2013). The subretinal implant alpha IMS to deliver useful vision in photoreceptor disease. Doc Ophthalmol.
Zrenner E, Benav H, Bruckmann A, et al. (2010). Electronic implants provide continuous stable percepts in blind volunteers only if the image receiver is directly linked to eye movement. Doc Ophthalmol.
Zrenner E. (2002). The subretinal implant: can microphotodiode arrays replace degenerated retinal photoreceptors to restore vision?. Ophthalmologica.