# Results

## Results of the Literature Searches

We retrieved 1,233 unique citations from our literature search (Figure 1). After reviewing titles and abstracts, we included 243 articles in our full-text review. After reviewing full text, we included 83 studies (published in 98 articles) and excluded 145 articles. The reasons for excluding the 145 articles are presented in Appendix C. There were 16 articles that we would have otherwise included, but the study populations overlap with other trials. Since we were unable to determine unique study participants, we excluded these studies from the analysis. These articles are listed in Appendix D.

Figure 1 Search flow diagram

RCT = randomized controlled trial

Figure 1 summarizes the search flow, starting with the electronic database search, and ending with 83 included studies.

## GQ 1 Describe the Technology/Intervention

### KQ 1 What is the theoretical renal denervation mechanism of action?

The renal sympathetic nervous system is thought to play a key role in hypertension and mediates the complex interactions between the brain and the kidney. Efferent sympathetic nerve fibers travelling from the brain to the kidney begin at the sympathetic ganglion at the lower thoracic and upper lumbar vertebrae, and course through the renal artery adventitia to provide sympathetic innervation of the renal vasculature, renal tubules, and juxta-glomerular apparatus. Effects mediated by alpha 1 receptors lead to vasoconstriction, decreased renal blood flow, volume retention and sodium resorption, while beta 1 receptor activation contributes to renin release and subsequent renin–angiotensin–aldosterone system activation. Afferent sympathetic nerve fibers travelling from the kidney to the brain act through the hypothalamus to regulate central sympathetic outflow to control systemic hemodynamics and reflexive sympathetic efferent activity as part of an important feedback loop.^16, 17^

Studies of surgical sympathectomy demonstrated its efficacy in uncontrolled hypertension, but orthostatic hypotension often resulted, 10-year mortality was high (approximately 40%), and advancements in pharmacotherapy for hypertension eventually rendered the procedure obsolete.^18, 19^ Catheter-based renal denervation involves placement of a catheter into the lumen of the renal arteries through which radiofrequency (or ultrasound) energy is applied to the vessel wall causing thermal (or sonic) injury to the sympathetic nerves coursing through the adventitia. This action reduces efferent renal sympathetic activity as evidenced by a reduction in renal noradrenaline spillover levels^20^ and is accompanied by a commensurate increase in renal blood flow and reduction in plasma renin activity. Reductions in whole-body noradrenaline spillover levels and skeletal muscle sympathetic nerve activity have also been measured following renal denervation and are thought to reflect the effects of reduced afferent renal sympathetic activity.^21, 22^ Thus, ablation of both the afferent and efferent renal nerves is thought to be the primary mechanism of blood pressure reduction with renal denervation.^23^

Despite the theoretical benefits of renal denervation for resistant hypertension, a number of issues remain. First, most of the published studies that we reviewed for this report used the Medtronic Symplicity® catheter for renal denervation. The Medtronic Symplicity catheter uses about 8 watts of radiofrequency energy for ablation.^24^ Other catheter designs include ultrasound energy (The ReCor Medical PARADISE® catheter), peri-vascular chemical injury (Ablative Solutions Peregrine System™ catheter), and a multi-electrode design (St. Jude Medical's EnligHTN™, Boston Scientific Vessix™, Medtronic SPYRAL) to allow simultaneous delivery of radio-frequency energy to multiple ablation points within a renal artery.^24^ There are no studies with head-to-head comparison of these devices. Second, while the effectiveness of renal denervation may be assessed after the procedure by whole-body noradrenaline spillover levels and skeletal muscle sympathetic nerve activity, these tests are not available for use at point-of-care. Therefore, the completeness of renal denervation cannot be confirmed at the time of the procedure. Third, most of the studies did not report the training, certification of the interventionalist, or the quality control used when performing renal denervation. As a result, procedural variability may diminish the effectiveness of the procedure. Finally, although renal sympathetic hyperactivity is one of the many mechanisms for resistant hypertension, it remains difficult to determine the contribution of sympathetic hyperactivity to resistant hypertension at an individual level and thereby identify patients most likely to benefit from reducing sympathetic overactivity by renal denervation. We further discuss the predictors of response to renal denervation in the KQ 5 section of this report.

The renal denervation procedure is invasive and inherently involves risks. These include those associated with arterial access (e.g., hematoma or pseudoaneurysm), renal cannulation (e.g., renal artery stenosis and dissection) and systemic effects (e.g., embolization). Most studies selectively included individuals with favorable renal anatomy which reduces the risk of complications. We discuss the complications in detail in the KQ 8 section of this report.

## GQ 2 Describe the Context in which the Technology/Intervention Is Used

### KQ 2 What is the evidence for blood pressure measurement and use as a surrogate outcome?

Hypertension is a progressive cardiovascular syndrome arising from complex and interrelated etiologies. Blood pressure is a biomarker of this syndrome.^25^ Data from observational studies involving over 1 million individuals indicate a linear association between increasing blood pressure and the risk of ischemic heart disease or death.^26^

Overwhelming evidence supports the use of antihypertensive therapy to lower blood pressure.^27^ Numerous clinical trials demonstrate the benefits of lowering blood pressure on reducing the risk of stroke, coronary heart disease, heart failure, and death.^12, 28-32^ In patients with both blood pressure of 140-159/90-99 mm Hg and cardiovascular disease, a sustained reduction in systolic blood pressure of 12 mm Hg over 10 years will prevent one death for every 11 patients treated.^33^

A systematic review of 62,605 hypertensive patients demonstrated a linear association between reduction of systolic blood pressure with drug treatment and the risk of death.^34^ Most recently, the Systolic Blood Pressure Intervention Trial (SPRINT) randomized 9361 hypertensive non-diabetic patients with a systolic blood pressure of greater than 130 mm Hg and an increased cardiovascular risk to a systolic blood pressure target of less than 120 mm Hg (intensive treatment) or less than 140 mm Hg (standard treatment).^32^ The trial was terminated early due to a significantly lower risk of death in the intensive treatment group (hazard ratio, 0.73; 95% confidence interval [CI], 0.60 to 0.90). If this lower blood pressure becomes a new target for clinicians, novel methods for controlling blood pressure may need to be developed to achieve this target.

The Food and Drug Administration considers blood pressure to be a surrogate endpoint for cardiovascular risk. The rationale for using blood pressure as a surrogate endpoint is based on the numerous studies of blood pressure reduction and improved cardiovascular outcomes, and the concern that a requirement for clinical endpoints may restrict the availability of newer drugs to control blood pressure.^35^

Use of blood pressure as a surrogate endpoint and the choice of antihypertensive medications to reach blood pressure goals was assessed in a large meta-analysis by Law, et al.^36^ The meta-analysis included 147 RCTs conducted from 1996 to 2007 including 464,000 people. Blood pressure reduction with drug treatments was associated with significantly lower risk of coronary heart disease events or strokes, regardless of age or baseline blood pressure (as low as 110/70 mm Hg). All antihypertensive drugs (e.g., thiazide-type diuretics, beta-blockers, angiotensin-converting enzyme inhibitors, angiotensin receptor blockers, and calcium channel blockers) had similar effects on prevention of coronary heart disease events, driven by blood pressure reduction rather than by drug-specific effects. While blood pressure was, overall, a surrogate endpoint for strokes, there were antihypertensive class-specific differences in the risk of stroke, with calcium channel blockers demonstrating the lowest risk of stroke.

Blood pressure control has also been associated with decreased risk of kidney disease progression;^37^ however, differences between drugs have been noted in clinical trials. For example, despite similar blood pressure control, losartan was superior to atenolol in the Losartan Intervention for Endpoint Reduction in Hypertension (LIFE) study,^38^ ramipril was superior to amlodipine or metoprolol in slowing progression of kidney function decline in blacks with proteinuria in the African American Study of Kidney Disease and Hypertension (AASK),^39^ and chlorthalidone was superior to lisinopril or amlodipine in the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT).^12, 40, 41^

It is debatable whether or not these differences in antihypertensive medications are the exception versus the rule, and if they are due to differences in central aortic blood pressures (versus peripheral cuff blood pressure). Similar concerns about surrogate endpoints have been raised after the failure of a dual renin-angiotensin system blockade to reduce progression of kidney disease in patients with albuminuria,^42, 43^ despite albuminuria being one of the strongest risk factors for progression of kidney disease and adverse outcomes in patients with chronic kidney disease.

In summary, strong evidence supports the use of blood pressure as a surrogate cardiovascular and mortality endpoint when treating patients using antihypertensive agents. Whether or not these findings apply to device-based approaches is not known at this time.^44^ It is also not known if blood pressure reduction achieved through renal denervation has effects on clinical endpoints that are similar to blood pressure reduction achieved through antihypertensive agents.

### KQ 3 What is the clinical definition of resistant hypertension, and what are the treatment alternatives?

#### Definition and Prevalence

A consensus statement from the American Heart Association Professional Education Committee of the Council for High Blood Pressure Research defines resistant hypertension as blood pressure that remains above goal in spite of the concurrent use of three antihypertensive medications of different classes.^6^ Ideally, one of the three medications should be a diuretic, and all medications should be prescribed in ways that take advantage of synergistic effects of different classes of agents and promote adherence to therapy. This definition includes all patients with blood pressure above their goal who are on three medications and also patients with blood pressure at goal but who require four or more medications.

The prevalence of treatment resistant hypertension is high. Based on the sequential National Health and Nutrition Examination Survey (NHANES) data, prevalence of treatment resistant hypertension, defined as blood pressure of 140/90 mm Hg or more while taking three or more antihypertensive medications, increased from 5.5 percent in the 1988 to 1994 survey to 11.8 percent in the 2005 to 2008 survey.^10^ Older age, African American race, obesity, and chronic kidney disease were associated with treatment resistant hypertension.^10^ Prevalence of treatment resistant hypertension is even higher (17%) in community-based cohorts of patients with a history of stroke or transient ischemic attacks.^45^ It is important to note that the prevalence of treatment resistant hypertension is based on a target blood pressure of less than 140/90 mm Hg.

#### Causes and Treatment

The causes of treatment resistant hypertension are numerous and can include lifestyle factors, secondary causes, and antihypertensive medication effects. Common causes of treatment resistant hypertension include pseudoresistance (i.e., white coat effect), non-adherence to diet (particularly dietary sodium intake) or medications, lifestyle factors (e.g., obesity, lack of exercise), use of non-steroidal anti-inflammatory drugs, secondary causes of hypertension (e.g., primary hyperaldosteronism, renal artery stenosis, chronic kidney disease), and physician inertia in up-titrating antihypertensive medications.^6^ Guidelines for overall blood pressure management have been published,^46, 47^ but choice of antihypertensive agent and titration is still individualized by the treating physician. For this reason, non-adherence to medications can also be a major contributing factor to treatment resistant hypertension. In one study, 48 percent of patients undergoing renal denervation were non-adherent for antihypertensive medications in plasma and urine as assessed by liquid chromatography high resolution tandem mass spectrometry.^48^

Management strategies for treatment resistant hypertension have not been well studied. Overall, the goal is to establish the true resistance by correct measurement of blood pressure and out of office blood pressure readings. After addressing lifestyle factors, dietary salt intake, and medication adherence, and excluding/treating secondary causes of hypertension, the management is drug escalation, and in particular, maximizing diuretic therapy^49^ with addition of mineralocorticoid receptor antagonists.^6^ In a recent, double-blind, placebo-controlled, cross-over, RCT of resistant hypertension in the United Kingdom (The Prevention and Treatment of Hypertension with Algorithm based Therapy [PATHWAY-2]), aldosterone antagonist spironolactone reduced home systolic blood pressure by 8.70 mm Hg (95% CI, 9.72 to 7.69) and allowed blood pressure control in 65 percent of the patients.^50^ In comparative studies, aldosterone antagonists reduced systolic blood pressure by 24.3 mm Hg (95% CI, 8.7 to 39.9).^51^ For patients with resistant hypertension referred for specialty care, 10 percent continue to experience uncontrolled hypertension despite being on a six drug regimen.^52^ Given the continued difficulty in controlling treatment resistant hypertension with medications, other options are needed for clinicians, patients, and other key stakeholders. Renal denervation is one such option.

### KQ 4 For randomized controlled trials and observational studies of renal denervation, what are the inclusion criteria for patients, and how do clinical characteristics match the clinical definition of resistant hypertension?

#### Key Point

- Most studies included patients with uncontrolled hypertension, defined as systolic blood pressure over 140 mm Hg or 160 mm Hg while taking a minimum of three anti-hypertensive medications. Most studies excluded patients with secondary causes of hypertension. Most did not assess medication adherence.

We considered the definition of resistant hypertension according to clinical consensus (see KQ1) as “blood pressure that remains above goal in spite of the concurrent use of three antihypertensive medications of different classes.”^6^ Ideally, one of the three medications should be a diuretic and all medications should be prescribed at optimal amounts. We also evaluated reporting of antihypertensive medication adherence, exclusion of patients with secondary causes of hypertension, and whether or not a run-in observation period was considered prior to renal denervation. Studies were evaluated for both inclusion and exclusion criteria, and the degree to which these studies excluded other treatable causes of resistant hypertension (i.e., potentially treated by change in lifestyle or medications) and reduced biases in measurement are reported below.

#### Number of Antihypertensive Medications

The majority of studies specified three as the minimum number of anti-hypertensive medications (Table 3). Many but not all studies [44/83 (53%)] also required use of a diuretic as an inclusion criterion. However, in most studies, an optimal antihypertensive dose was not specified.

Table 3 Number (percent) of studies using the following inclusion criteria

| Randomized controlled trials (n=9) | Comparative observational studies (n=8) | Non-comparative studies (n=66)
Office SBP > 140 mm Hg while taking ≥ 3 antihypertensive medications and a minimum ambulatory SBP | 3 (33%) | 0 | 5 (7%)
Office SBP > 140 mm Hg while taking ≥ 3 antihypertensive medications but did not specify criteria for ambulatory SBP | 1 (11%) | 1 (13%) | 8 (12%)
Office SBP > 160 mm Hg while taking ≥ 3 antihypertensive medications and a minimum ambulatory SBP | 2 (22%) | 0 | 4 (6%)
Office SBP > 160 mm Hg while taking ≥ 3 antihypertensive medications but did not specify criteria for ambulatory SBP | 2 (22%) | 4 (50%) | 30 (44%)
Elevated ambulatory SBP while taking ≥ 3 antihypertensive medications but did not specify criteria for office SBP | 1 (11%) | 0 | 2 (3%)
Taking ≥ 3 antihypertensive medications but did not specify criteria for office nor ambulatory SBP | 0 | 1 (13%) | 1 (1%)
Elevated office and/or ambulatory SPB while taking ≥ 4 antihypertensive medications | 0 | 0 | 1 (1%)
Taking ≥ 4 antihypertensive medications but did not specify criteria for office and ambulatory SBP | 0 | 0 | 1 (1%)
Office SBP between 140 and 160 mm Hg and ambulatory SBP > 130 mm Hg, but did not specify criteria for the number of medications | 0 | 0 | 1 (1%)
Elevated office SBP, but did not specify criteria for the number of medications or ambulatory SBP | 0 | 0 | 2 (3%)
Ambulatory SBP > 130 mm Hg, but did not specify criteria for the number of medications or office SBP | 0 | 0 | 1 (1%)
Did not specify criteria for the number of medications or office or ambulatory SBP | 0 | 2 (25%) | 10 (15%)
Required a diuretic | 6 (67%) | 4 (50%) | 28 (42%)

mm Hg = millimeters of mercury; SBP = systolic blood pressure

#### Systolic Blood Pressure Inclusion Criterion

Considering systolic blood pressure greater than 140 mm Hg to be uncontrolled hypertension, almost all studies included patients with uncontrolled hypertension; however, the systolic blood pressure criterion varied in this definition, with some studies defining resistant hypertension as 140 mm Hg systolic or greater, and others as 160 mm Hg or greater.

#### Exclusion of Secondary Causes of Hypertension

Fourteen (82%) of the RCTs and comparative studies and 44 (67%) of the non-comparative studies reported considering secondary causes of hypertension as an exclusion criterion.

#### Medication Adherence Prior to Enrollment or Study Entry

Of the RCTs and comparative studies, only five (29%) reported any evaluation of adherence prior to enrollment (Table 4). In two studies, this evaluation was in the form of a medication diary.

Table 4 Summary of included studies evaluating renal denervation devices among patients with resistant hypertension (83 studies reported in 98 articles)

| Number of studies (Number of participants)
Study type
Randomized controlled trial | 9 (1030)
Prospective cohort | 5 (284)
Retrospective cohort | 2 (206)
Before/after study | 66 (6059)
Case-control | 1 (81)
Run-in period
Yes | 10 (976)
No/not reported/not applicable | 73 (6684)
Adherence assessed in randomized controlled trials and comparative studies (n=17)
Assessed adherence during run-in period | 5 (339)
Assessed adherence during study | 6 (937)
Location^*^
United States | 3 (838)
Europe | 57 (4038)
Worldwide | 2 (1104)
Other | 23 (1936)
Not reported | 9 (649)
Funding source^*^
Manufacturer | 28 (3809)
Government/non-profit | 23 (2552)
None | 3 (302)
Not reported | 33 (2285)
Renal denervation devices^*^
Symplicity™ Renal Denervation System | 53 (5547)
Other | 27 (1720)
Unspecified | 7 (492)
Specialty^*^
Interventional cardiologist | 2 (140)
Interventional radiologist | 3 (75)
Other | 4 (379)
Not reported | 81 (8075)
Comparators
Medications | 7 (410)
Sham procedure | 3 (636)
Other | 7 (375)
Outcomes
Blood pressure | 82 (7607)
Stroke | 6 (2329)
Myocardial infarction | 7 (2349)
Hospitalization | 6 (2373)
Mortality | 9 (2703)
Adverse events | 32 (3982)

* Responses add up to more than 83 studies because there could be more than one response for each study.

#### Other Inclusion Criteria and Clinical Characteristics of the Patients

The total number of subjects in the included studies ranged from 18 to 998 (Table 5). In all but thirteen studies, the majority of included subjects were male; in four studies, the gender distribution of the subjects was not reported. Twenty-five trials reported a maximum age exclusion (the most common age exclusion was for people 85 years old or older). Forty-six reported a minimum age exclusion, with most excluding subjects younger than 18 years old. In 77 studies, the race or ethnicity distribution of the subjects was not reported. In studies which reported the mean body mass index of subjects (all but 20 studies), the mean body mass index ranged from 27 to 34. Compared with non-randomized trials, the RCTs were characterized by a larger sample size, a lower prevalence of diabetes, and a mean estimated glomerular filtration rate that was higher than that found in the non-randomized trials.

Table 5 Summary of the descriptive characteristics of the enrolled patient population stratified by study design

Characteristic | RCTs (N=9) | Comparative studies (N=8) | Non-comparative studies (N=66)
Sample size, median (range) | 71 (18 to 535) | 60 (28 to 198) | 54 (27 to 998)
Mean age of participants, median (range) | 58 years (55 to 65) | 62 years (54 to 68) | 62 years (45 to 69)^*^
% male subjects, median (range) | 70% (50 to 100) | 63% (29 to 80) | 60% (13 to 81)^*^
% Caucasian, median (range) | 84% (70 to 98)^†^ | NR | 89% (30 to 100)^‡^
BMI, median (range) | 31 kg/m^2^ (27 to 34) | 31 kg/m^2^ (27 to 34) | 31 kg/m^2^ (27 to 33)^§^
eGFR, median (range) | 80 mL/min/m^2^ (41 to 90)^¶^ | 75 mL/min/m^2^ (67 to 83)^ǁ^ | 75 mL/min/m^2^ (49 to 98)^**^
CKD stages | CKD 3: 13% (5 to 21)^††^ | NR | CKD 2: 64% (63 to 67)^¶^ CKD 3: 20% (1 to 27) CKD 4: 17% (3 to 19)
% with diabetes, median (range) | 32% (8 to 89) | 30% (14 to 50)^‡^ | 37% (10 to 100)^‡‡^
% with LVH, median (range) | 56 to 60^§§^ | 10 to 18^§§^ | 22% (12 to 87)^¶^
Mean number of antihypertensive medications, median (range) | 5.1 (3.6 to 5.4)^¶¶^ | 4.6 (0 to 5.3) | 5 (1.2 to 6.2)^ǁǁ^
% of patients on a diuretic, median (range) | 100% (89 to 100)^***^ | 50 to 84^§§^ | 89% (63 to 100)^†††^

BMI = body mass index; CKD = chronic kidney disease; eGFR = estimated glomerular filtration rate; kg/m^2^ = kilograms per meters squared; LVH = left ventricular hypertrophy; mL/min/1.73 m^2^ = milliliters per min per 1.72 meters squared; NR =not reported; RCT = randomized controlled trial

* N = 60

† N = 9

‡ N = 6

§ N = 48

¶ N = 5

ǁ N = 3

** N = 41

†† N = 2

‡‡ N = 58

§§ N = 1

¶¶ N = 8

ǁǁ N = 56

*** N = 7

††† N = 25

## GQ 3 Describe the Current Evidence of the Technology/Intervention

### KQ 5 What are the predictors of response in Medicare eligible patients who are appropriate candidates for renal denervation?

#### Key Points

- The most common predictors of response to renal denervation were baseline office systolic blood pressure (13 studies) or other measures of baseline systolic blood pressure (11 studies).
- The patients included in the studies were comparable only in part to the Medicare-eligible population.

#### Applicability of the Studies to the Medicare Population

With regard to the applicability of these studies to the Medicare population, the reported subject characteristics are relevant. The mean age of the patients was less than 65 years (the general age of Medicare eligibility) in all types of studies (Table 5), indicating that the majority of patients studied would not meet the age criterion for Medicare. However, the range of ages in the studies did include Medicare-eligible ages.

In addition, chronic kidney disease, which is highly prevalent among the Medicare population, was only partially represented among these studies. Two of the RCTs included some patients with stage 3 chronic kidney disease; comparative studies did not report chronic kidney disease stage; and non-comparative studies included a wider range of kidney disease, including stages 3 and 4. None of the studies included patients on dialysis. Thus, the patients in these studies are comparable only in part to the Medicare-eligible population.

#### Predictors of Response

Twenty-eight studies examined predictors of response to renal denervation (Table 6). Thirteen studies conducted a multivariate analysis (as noted with an asterisk in the last column of Table 6) and 15 conducted a univariate analysis. The most common predictors of response to renal denervation were baseline office systolic blood pressure (13 studies) or other measure of baseline systolic blood pressure (11 studies). Other predictors of response that were found in more than one study included change in heart rate after the renal denervation procedure (2 studies), central pulse pressure (2 studies), and body mass index (2 studies). These studies were heterogeneous in time to followup and definition of renal denervation response. Only two studies assessed these predictors of response comparing renal denervation patients to those undergoing a sham procedure.^53, 54^ Both of these studies found that baseline office systolic blood pressure was a predictor of blood pressure response in those undergoing a sham procedure. None of the studies found that gender or age were predictors of response. Only one study reported race (African American) as a predictor of response, but most of the studies in our review were not performed in the United States and did not report race.

Table 6 Predictors of response to renal denervation

Author, year Study design | Response definition | Predictors evaluated | Significant predictors
Flack, 2015^53^ RCT N = 535 | 6-month change in office SBP | Baseline office SBP, SBP ≥ 180 mm Hg, African American race, age ≥ 65 years, history of diabetes, eGFR ≥ 60 mL/min/1.73 m2, gender, 4-quadrant ablation pattern, ≥ 8 full 120-s ablations, ≥ 4 notches, total number of ablation attempts, baseline dipper status, salt sensitivity, baseline number of medication classes, prescription of a calcium antagonist or angiotensin receptor blocker or diuretic, complex antihypertensive medication regimen, and geography | Baseline office SBP ≥ 180 mm Hg, vasodilator use, interaction between African American and baseline office SBP ≥ 180 mm Hg^*^
Tsioufis, 2015^55^ Prospective cohort N = 46 | 1. ≥ 10 mm Hg decrease in office BP; 2. office SBP reduction of ≥ 10% from baseline | Gender, sleep apnea, history of type 2 diabetes, age, baseline office SBP, baseline office DBP, baseline office HR, BMI, baseline number of medication classes, number of ablations, average diameter of renal arteries, baseline office PP, office HR at 24 months | 1. None^*^; 2. BMI^*^
Kim, 2015^56^ Before-after study N = 1000 | 1. 6- month change in office SBP; 2. 12-month change in office SBP | Korean vs. Caucasian, baseline office SPB, baseline office DBP, age, gender, diabetes mellitus, baseline HR, BMI, renal insufficiency, history of cardiac disease, heart failure, LVH, current smoker, total number of ablation attempts, number of 120-s ablation attempts, total number of antihypertensive medication classes, and types of antihypertensive medications | 1. baseline office SBP, LVH, calcium channel blockers^*^; 2. Korean vs. Caucasian, baseline office SBP, alpha-adrenergic blocker^*^
Id, 2015^57^ Before-after study N = 101 | 6-month change in office SBP | Gender, age, BMI, office and ambulatory BP, renal function, diabetes mellitus, number of ablations, and antihypertensive medications | Baseline office SBP, BMI^*^
Ott, 2015^58^ Before-after study N = 63 | 6-month office SBP reduction | Age, gender, coronary heart disease; diabetes mellitus, HR, central PP, baseline office SBP | Baseline SBP; central PP^*^
Ott, 2015^59^ Before-after study N = 27 | 6-month change in 24-h SBP | NR | Baseline 24-h SBP^†^
Dorr, 2015^60^ Before-after study N = 100 | 6-month change in SBP | NR | Baseline SBP, change in brain-derived neurotrophic factor^‡^
Dorr, 2015^61^ Before-after study N = 100 | 6-month change in SBP | NR | Carboxyl-terminal pro-peptide of type 1 collagen (PICP)^‡^
Azizi, 2015^62^ RCT N = 106 | 6-month change in daytime ambulatory SBP | NR | Gender, baseline ambulatory daytime SBP; change in HR; number of antihypertensive drugs at 6 months; MMAS-8^*^
Sievert, 2015^63^ Before-after study N = 146 | 1. > 10 mm Hg decrease in office SBP at 6 months; 2. > 5 mm Hg reduction in ambulatory SBP at 6 months | Baseline DBP, eGFR, number of electrode activations, baseline ambulatory SBP, number of antihypertensive medications, gender, regimen includes a centrally-acting sympatholytic, HR, age, baseline ambulatory DBP, regimen includes a fixed combination, regimen includes an alpha-1 blocker, baseline SBP, accessory renal artery treated | 1. None^†^; 2. Baseline ambulatory SBP; baseline SBP; baseline ambulatory DBP^†^
Rosa, 2015^64^ RCT N = 106 | ≥ 10 mm Hg decrease in 24-h SBP | NR | Baseline daytime SBP^*^
Kandzari, 2015^54^ RCT N = 535 | 1. 6-month change in office SBP; 2. 6-month change in 24-h ambulatory SBP | Baseline office SBP ≥180 mmHg, African-American race, age < 65 years, history of diabetes, renal insufficiency, gender, 4-quadrant ablation pattern, ≥ 8 full 120-s ablations, ≥ 4 notches, total number of ablation attempts, as well as baseline prescription of aldosterone antagonist, a-1-blocker, a-2 agonist, angiotensin-converting enzyme inhibitor, angiotensin-receptor blocker, beta-blocker, calcium-channel blocker, direct renin inhibitor, and vasodilator | 1. Baseline office SBP; total number of ablation attempts; aldosterone antagonist; vasodilator^*^; 2. baseline eGFR >= 60; aldosterone antagonist^*^
Ewen, 2015^65^ Before-after study N = 126 | ≥ 10 mm Hg decrease in office SBP at 6 months | Gender, age, diabetes mellitus, ≥ 5 antihypertensive drugs, aldosterone antagonist, central sympatholytic, baseline office SBP ≥ 175 mm Hg, baseline ambulatory SBP ≥ 153 mm Hg, baseline PP ≥ 85 mm Hg | Baseline office SBP^*^
Verloop, 2015^66^ Before-after study N = 54 | 12-month change in BP | Changes in eGFR, BMI, or total daily use of antihypertensive drugs | None^*^
Dorr, 2015^67^ Before-after study N = 60 | 6-month change in office SBP | Baseline office SBP | Baseline office SBP^†^
Vink, 2014^68^ Before-after study N = 67 | 6-month change in office SBP | Age, gender, number of antihypertensive drugs, total daily use of antihypertensive drugs, hypercholesterolemia, diabetes mellitus, cardiovascular diseases, BMI, office SBP, office DBP, mean daytime SBP, mean nighttime SBP, mean daytime PP, mean HR during daytime, presence of a non-dipping profile, eGFR, laboratory parameters | Cardiovascular disease; office SBP; office DBP; PP; presence of a non-dipping profile; noradrenaline
Papademetriou, 2014^69^ Before-after study N = 46 | 1. 6-month change in BP; 2. 12-month change in BP | NR | 1. Baseline office SBP, baseline HR; 2. Baseline office SBP
Verloop, 2014^70^ Before-after study N = 126 | 6-month change in office SBP | Renal artery anatomy, age, gender, baseline eGFR, baseline SBP, baseline daytime SBP, change in antihypertensive drugs | None^†^
Poss, 2014^71^ Before-after study N = 101 | 6-month change in SBP | NR | Vitamin D concentration^‡^
Lenski, 2013^72^ Before-after study N = 119 | ≥ 10 mm Hg decrease in SBP at 6 months | Psychological factors | None^‡^
Vogel, 2014^73^ Before-after study N = 63 | Change in office SBP | Baseline office SBP, number of ablation points | Baseline office SBP^†^
Zuern, 2013^74^ Before-after study N = 50 | ≥ 10 mm Hg decrease in ambulatory SBP at 6 months | NR | Cardiac baroreflex sensitivity^*^
Ott, 2013^75^ Before-after study N = 54 | 3-month and 6-month change in office SBP | Change in HR | None^†^
Worthley, 2013^76^ Before-after study N = 46 | 6-month change in office SBP | NR | Baseline SBP; baseline HR; reduction in HR^‡^
Schmid, 2013^77^ Before-after study N = 53 | 6-month change in office SBP | Baseline office SBP, renal artery supply, total number of ablations, eGFR | Baseline office SBP^*^
Prochnau, 2013^78^ Before-after study N = 43 | ≥ 10 mm Hg decrease in ambulatory SBP at 6 months | Age, BMI, creatinine, baseline 24-h ambulatory SBP | Baseline ambulatory SBP^*^
Symplicity, 2011^79^ Before-after study N = 153 | 12-month change in SBP | Age, gender, race, BMI, SBP, DBP, PP, HR, drug class, number of antihypertensive drugs, eGFR, hypercholesterolemia, coronary artery disease | Baseline SBP; use of central sympatholytic agents^*^
De Sousa Almeida, 2016^80^ Before-after study N = 65 | 12-month change in ambulatory SBP | LV mass | None^†^
Burchell, 2016^81^ Before-after study N = 29 | 6-month change in office SBP | NR | Number of ablations per artery, total number of ablations^†^
Sharp, 2016^82^ Before-after study N = 253 | 1. Change in office SBP; 2. Change in ambulatory SBP | Use of aldosterone antagonist, age, gender, diabetes, eGFR, number of drugs taken, baseline BP | 1. Baseline office SBP^*^; 2. Baseline ambulatory SBP^*^
Tiroch, 2015^83^ Before-after study N = 46 | 6-month change in office SBP | Baseline office BP, veno-arterial norepinephrine gradient reduction, BMI, medication status | Baseline office BP, veno-arterial norepinephrine gradient reduction^*^
Rohla, 2016^84^ Before-after study N = 103 | 1. 6-month change in ambulatory SBP; 2. 12-month change in ambulatory SBP | Baseline ambulatory SBP, number of ablation points, age, BMI, gender, diabetes, hyperlipidemia, coronary artery disease, peripheral artery disease, prior stroke or transient ischemic attack, number of antihypertensives, use of renin-inhibitors, aldosterone antagonists, and alpha-blockers | 1. Baseline ambulatory SBP, BMI, number of antihypertensive drugs^*^; 2. Baseline ambulatory SBP, number of antihypertensive drugs^*^

BP = blood pressure; BMI = body mass index; DBP = diastolic blood pressure; eGFR = estimated glomerular filtration rate; h = hours; HR = heart rate; LVH = left ventricular hypertrophy; mm Hg = millimeters of mercury; MMAS-8 = Morisky Medication Adherence Scale; NR = not reported; PP = pulse pressure; RCT = randomized controlled trial; s = seconds; SBP = systolic blood pressure

* Significant in a multivariate analysis

† Significant in a univariate analysis.

‡ Unclear if a univariate or multivariate analysis.

### KQ 6 What is the evidence for renal denervation effectiveness in reducing blood pressure, stroke, myocardial infarction, and hospitalization and/or improving survival in Medicare eligible patients with resistant hypertension?

#### Key Points

- The between-group difference in change in 24-hour ambulatory systolic blood pressure from baseline to 6 months was highly variable in six RCTs and two comparative cohorts, ranging from -20 mm Hg to -1.96 mm Hg.
- The between-group differences in change in office systolic blood pressure from baseline to 6 months ranged from -42 mm Hg to 1.9 mm Hg in ten RCTs and comparative cohorts.
- We did not identify any studies designed to assess the efficacy or effectiveness of renal denervation in reducing stroke, myocardial infarction, hospitalizations, or survival in patients with resistant hypertension.

In KQ3, we described the relative lack of applicability of the studies to the Medicare eligible population. We a priori considered an optimal study design to assess the efficacy of renal denervation on blood pressure reduction in patients with resistant hypertension. This study design would exclude other treatable causes of hypertension (e.g., lifestyle, adherence, and secondary causes), be conducted on a background of a stable and optimized antihypertensive regimen, and minimize investigator bias in blood pressure and treatment measurement. Thus, the study would effectively evaluate the impact of interventional procedures on blood pressure and would have the following explicit characteristics: 1) the study will exclude patients with secondary causes of hypertension; 2) the study will exclude patients with uncontrolled hypertension due to non-adherence to diet (in particular salt intake) and medications; 3) the study will include a sufficiently long run-in period to reduce regression to the mean and ensure compliance; 4) the study will exclude white coat effect by home or ambulatory blood pressure monitoring prior to randomization; 5) the study will include a placebo (sham) group; 6) the study will continue to evaluate dietary and medication adherence during followup; and 7) the study will use ambulatory blood pressure as the primary outcome measure. We abstracted the published studies of renal denervation and assessed whether or not the studies met these characteristics.

#### Systolic Blood Pressure

A number of different measures are used in clinical practice to assess systolic blood pressure. These include office-based blood pressure and readings from ambulatory blood pressure measurement (e.g., overall, daytime, and nighttime).

Studies have supported ambulatory measurements as being more predictive than office measurements for morbidity and mortality in the general population^85^ and in patients with resistant hypertension.^86^ Below, we report all blood pressure outcomes identified in studies of renal denervation that are both least biased (ambulatory) and commonly used by clinicians (office) but are inherently more biased.

##### Change in Ambulatory Blood Pressure

###### Twenty-Four-Hour Ambulatory Systolic Blood Pressure

We identified nine RCTs and controlled studies that reported 24-hour ambulatory blood pressure measurements (Table 7).^23, 62, 64, 87-92^

Table 7 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on 24-hour ambulatory systolic blood pressure

Author, year Study design | Mean followup (months) | RDN, N | Control group, N | Mean baseline 24-hour ABPM (SD) in RDN group, mm Hg | Mean baseline 24-hour ABPM (SD) in control group, mm Hg | Mean change (95% CI) from baseline in 24-hour ABPM in RDN group, mm Hg | Mean change (95% CI) from baseline in 24-hour ABPM in control group, mm Hg | Mean between-group difference^*^ (95% CI), mm Hg^*^
Azizi, 2015^62^ RCT | 6 | RDN (Medtronic Simplicity), 48 | Continuation of anti-hypertensive drugs, 53 | 151.6 (16.3) | 146.8 (15.2) | -15.4 (-19.1 to -11.7) | -9.5 (-13.0 to -6.0) | -5.9 (-11.0 to -0.8)
Bhatt, 2014^87^ RCT | 6 | RDN (Medtronic Symplicity), 360 | Sham procedure, 167 | 159.1 (13.2) | 159.5 (15.3) | -6.75 (-8.4 to -5.1) | -4.79 (-7.4 to -2.1) | -1.96 (-5.1 to 1.2)
Desch, 2015^88^ RCT | 6 | RDN (Medtronic Symplicity), 32 | Sham procedure, 35 | 140.2 (4.6) | 140.4 (5.6) | -7 (-10.8 to -3.2) | -3.5 (-6.7 to -0.2) | -3.5 (-8.5 to 1.5)
Kario, 2015^89^ RCT | 6 | RDN (Medtronic Symplicity), 22 | Continuation of anti-hypertensive drugs, 19 | 164.7 (18.3) | 163.3 (17.2) | -7.5 (-12.5 to -2.5) | -1.4 (-6 to 3.2) | -6.2 (-13 to 0.6)
Rosa, 2015^64^ RCT | 6 | RDN (Medtronic Symplicity), 52 | Intensification of anti-hypertensive drugs, 54 | 149 (12) | 147 (13) | -9 (-11.8 to -5.3) | -8.1 (-12.7 to -3.4) P=0.001 | -0.5 (-6.2 to 5.2)
Schneider, 2015^90^ RCT | 6 | RDN (Medtronic Flex), 9 | Continuation of anti-hypertensive drugs, 9 | 140 (13) | 143 (12) | -2.88 (-10.1 to 4.4) | -5 (-12.3 to 2.3) | 2.1 (-8.2 to 12.4)
Symplicity, 2010^23^ RCT | 6 | RDN (Medtronic Symplicity), 20 | Unspecified, but allowed to crossover to RDN after 6 months, 25 | NR | NR | -11 (-17.6 to -4.4) | -3 (-10.4 to 4.4) | -8 (-17.9 to 1.9)
Tsioufis, 2015^91^ Prospective cohort | 6 | RDN (St. Jude Medical EnligHTN), 18 | No renal denervation, 10 | 153 (16) | 149 (11) | -20 (-22.7 to -17.3) | 0 (-2.8 to 2.8) | -20 (-34.6 to -5.4)
Tsioufis, 2015^92^ Prospective cohort | 6 | RDN (St. Jude Medical EnligHTN), 31 | No renal denervation, 12 | 147.5 (12) | 145.3 (9.2) | -10.2 (-11.5 to -8.9) | -0.6 (-2.2 to 1) | -9.6 (-18.9 to -0.3)
Bhatt, 2014^87^ RCT | 12 | RDN (Medtronic Symplicity), 247 | Sham procedure, 20 | 158 (NR) | 151 (NR) | -7.6 (-7.9 to -7.3) | -6.1 (-12.4 to 0.2) | -1.5 (-7.8 to 4.8)
Rosa, 2015^64^ RCT | 12 | RDN (Medtronic Simplicity), 52 | Continuation of anti-hypertensive drugs, 54 | 149 (12) | 147 (13) | -6.4 (-10.1 to -2.7) | -8.2 (-13.3 to -3.3) | 1.9 (-4.2 to 8.0)

ABPM = ambulatory blood pressure monitoring; CI = confidence interval; mm Hg = millimeters mercury; NR = not reported; RCT = randomized controlled trial; RDN = renal denervation; SD = standard deviation

* The mean between-group difference is calculated as the mean change from baseline in the renal denervation group minus the mean change from baseline in the control group.

In studies using a sham control group, the mean between-group difference in change in 24-hour ambulatory systolic blood pressure from baseline to 6 months was small and not statistically significant in two RCTs (-1.96 and -3.5 mm Hg).^87, 88, 92^ In comparative studies without a sham control group, the largest mean between-group difference in change in 24-hour ambulatory systolic blood pressure from baseline to 6 months was seen in two prospective cohort studies which reported a statistically significant difference (-20 and -9.6 mm Hg), with smaller differences in the seven RCTs that lacked a sham control (-6.2 to +2.1 mm Hg), of which only one trial reported a statistically significant difference.^23, 64, 89-92^

Only two RCTs reported a change in ambulatory systolic blood pressure over 12 months. The between-group differences were not statistical significant at -1.5 and 1.9 mm Hg.^64, 87^

Figure 2 shows the mean between-group difference in the change of ambulatory and office systolic blood pressure between renal denervation and the control arms. The mean between-group differences were smaller for ambulatory systolic blood pressure than for office systolic blood pressure.

Figure 2 Mean between-group difference in the change in ambulatory and office systolic blood pressure* between renal denervation and control in randomized controlled trials of patients with resistant hypertension

* We present further details of the studies reporting ambulatory systolic blood pressure in Table 7 and office systolic blood pressure in Table 11.

BL = baseline; CI = confidence interval; ES = effect size (mean between-group difference); mm Hg = millimeters mercury; NR = not reported; RDN = renal denervation; SBP = systolic blood pressure

Circles indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence interval for each study.

Figure 2 summarizes the mean between-group difference in the change in ambulatory and office systolic blood pressure between renal denervation and control in randomized controlled trials of patients with resistant hypertension.

Table 11 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on office systolic blood pressure

Author, year Study design | Mean followup (months) | RDN, N | Control group, N | Mean baseline OSBP (SD) in RDN group, mmHg | Mean baseline OSBP (SD) in RDN group, mmHg | Mean (95% CI) change from baseline in RDN group, mm Hg | Mean (95% CI) change from baseline in control group, mm Hg | Mean between-group difference^*^ (95% CI), mm Hg
Lambert, 2012^123^ Prospective cohort | 3 | RDN (Medtronic Symplicity), 62 | Unmedicated normotensive subjects, 63 | 166 (3) | 122 (1) | NR | NR | -16 (-16.7 to -15.3)
Azizi, 2015^62^ RCT | 6 | RDN (Medtronic Symplicity) plus intensification of anti-hypertensive drugs, 48 | Intensification of anti-hypertensive drugs, 53 | 159.3 (22.7) | 155.9 (21.9) | -15.1 (-20.6 to -9.5) | -9.5 (-14.7 to -4.2) | -5.6 (-13.2 to 2)
Bhatt, 2014^87^ RCT | 6 | RDN (Medtronic Symplicity), 364 | Sham procedure, 171 | 179.7 (16.1) | 180.2 (16.8) | -14.13 (-16.6 to -11.6) | -11.74 (-15.6 to -7.9) | -2.39 (-7 to 2.2)
Fadl Elmula, 2014^122^ RCT | 6 | RDN (Medtronic Symplicity), 9 | Continuation of anti-hypertensive drugs, 10 | 156 (13) | 160 (14) | -8 (-17.8 to 1.8) | -28 (-36.1 to -19.9) | 20 (7.3 to 32.7)
Kario, 2015^89^ RCT | 6 | RDN (Medtronic Symplicity), 22 | Continuation of anti-hypertensive drugs, 19 | 181 (18) | 178.7 (17.8) | -15.3 (-24.3 to -8.9) | -7.9 (-17.3 to 1.5) | -8.6 (-20.8 to 3.6)
Pokushalov, 2012^124^ RCT | 6 | RDN (Unspecified), 13 | Pulmonary vein isolation, 14 | 181 (7) | 178 (8) | -28 (-30.7 to -25.3) | -5 (-6.3 to -3.7) | -23 (-26 to -20)
Rosa, 2015^64^ RCT | 6 | RDN (Medtronic Symplicity), 52 | Intensification of anti-hypertensive drugs, 54 | 159 (19) | 155 (17) | -12 (-17 to -7.8) | -14.3 (-19.7 to -8.9) | 1.9 (-5.2 to 9)
Schneider, 2015^90^ RCT | 6 | RDN (Medtronic Flex), 9 | Continuation of anti-hypertensive drugs, 9 | 155 (14) | 146 (6) | -23 (-32.5 to -13.5) | 1 (-7.5 to 9.5) | -24 (-36.7 to -11.3)
Symplicity, 2010^23^ RCT | 6 | RDN (Medtronic Symplicity), 49 | Unspecified, but allowed to crossover to RDN after 6 months, 51 | 178 (18) | 178 (17) | -32 (-38.4 to -25.6) | 1 (-4.8 to 6.8) | -33 (-41.6 to -24.4)
Ewen, 2014^125^ Prospective cohort | 6 | RDN (Medtronic Symplicity), 50 | Unspecified, 10 | 164 (3) | 155 (4) | -26 (-27.4 to -24.6) | -2 (-6.8 to 2.8) | -24 (-42.2 to -5.8)
Tsioufis, 2015^91^ Prospective cohort | 6 | RDN (St. Jude Medical EnligHTN), 18 | Sham procedure, 10 | 182 (19) | 182 (12) | -42 (-45.1 to -38.9) | 0 (-3 to 3) | -42 (-58.4 to -25.6)
Bhatt, 2014^87^ RCT | 12 | RDN (Medtronic Symplicity), 319 | Sham procedure, 48 | 179 (NR) | 176 (NR) | -18.9 (-21.7 to -16.1) | -21.4 (-27 to -15.8) | 2.5 (-3.8 to 8.8)
Rosa, 2015^64^ RCT | 12 | RDN (Medtronic Simplicity), 51 | Continuation of anti-hypertensive drugs, 50 | 159 (19) | 155 (17) | NR (-18.9 to -7.9) | -11.3 (-17.1 to -5.5) | -2.1 (-10.1 to 5.9)
Pokushalov, 2012^124^ RCT | 12 | RDN (Unspecified), 13 | Pulmonary vein isolation, 14 | 181 (7) | 178 (8) | -25 (-27.7 to -22.3) | -5 (-7.6 to -2.4) | -20 (-23.8 to -16.2)
Symplicity, 2010^23^ RCT | 12 | RDN (Medtronic Symplicity), 49 | Unspecified, but allowed to crossover to RDN after 6 months | 178.3 (18.2) | NR | -28.1 (-35.4 to -20.7) | NR | NR
Symplicity, 2010^23^ RCT | 36 | RDN (Medtronic Symplicity), 52 | Unspecified, but allowed to crossover to RDN after 6 months | 178 (18) | NR | -33 (-40 to -25) | NR | NR

CI = confidence interval; mm Hg = millimeters mercury; RCT = randomized controlled trial; RDN = renal denervation; SBP = systolic blood pressure

* The mean between-group difference is calculated as the mean change from baseline in the renal denervation group minus the mean change from baseline in the control group.

Table 8 describes the changes in ambulatory systolic blood pressure in non-controlled observational studies.^48, 55, 57-60, 63, 65-70, 75, 76, 78, 91-121^ The median change in 24-hour ambulatory systolic blood pressure (48 studies with 3,486 patients) was −9 mm Hg, the median change in daytime ambulatory systolic blood pressure (18 studies with 1,413 patients) was −8.7 mm Hg, and the median change in nighttime ambulatory systolic blood pressure (14 studies with 1,053 patients) was −5.2 mm Hg.

Table 8 Range in effects on blood pressure reported in non-controlled studies of renal denervation devices

Blood pressure measure | N studies (N participants) | Mean followup (months) | Median (range) in change from baseline, mm Hg
Office SBP | 66 (5811) | 9.9 | -19.7 (-58.2 to 12)
Daytime ambulatory SBP | 18 (1413) | 8.7 | -7.8 (-15 to 5)
Nighttime ambulatory SBP | 14 (1035) | 8.6 | -5.2 (-14 to 0)
24-hour ambulatory SBP | 48 (3486) | 9.1 | -9 (-31 to 20)
Number of BP medications | 23 (2740) | 13.0 | -0.1 (-1.4 to 0.2)

BP = blood pressure; mm Hg = millimeters mercury

Figure 3 plots the change in ambulatory systolic blood pressure 6 months after renal denervation. The change in systolic blood pressure after denervation varied among the studies.

Figure 3 Change from baseline ambulatory systolic blood pressure 6 months after renal denervation reported in non-controlled studies, sorted by the magnitude of change

BP = blood pressure; mm Hg = millimeters of mercury

Circles represent baseline systolic ambulatory blood pressure. Diamonds represent systolic ambulatory blood pressure 6 months after renal denervation.

Figure 3 summarizes the change from baseline aumbulatory systolic blood pressure at 6 months after renal denervation reported in non-controlled studies.

###### Daytime and Nighttime Ambulatory Systolic Blood Pressures

Five of the eight studies that reported 24-hour ambulatory systolic blood pressures also reported daytime ambulatory blood pressure measurements (Table 9)^64, 87, 88, 90, 92^ and/or nighttime (Table 10) ambulatory blood pressure measurements.^64, 87, 90, 92^ We also identified two studies that reported only daytime ambulatory systolic blood pressure, but not 24-hour ambulatory blood pressures.^62, 122^ Of these two studies, one also reported nighttime ambulatory blood pressures.^62^

Table 9 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on daytime ambulatory systolic blood pressure

Author, year Study design | Mean followup (months) | RDN, N | Control group, N | Mean baseline daytime ABPM (SD) in RDN group, mmHg | Mean baseline daytime ABPM (SD) in control group, mmHg | Mean change (95% CI) from baseline in daytime ABPM in RDN group, mm Hg | Mean change (95% CI) from baseline in daytime ABPM in control group, mm Hg | Mean between-group difference^*^ (95% CI), mm Hg
Azizi, 2015^62^ RCT | 6 | RDN (Medtronic Symplicity) plus intensification of anti-hypertensive drugs, 48 | Intensification of anti-hypertensive drugs, 53 | 155.5 (16.1) | 151 (16) | -15.8 (-19.7 to -11.9) | -9.9 (-13.6 to -6.2) | -5.9 (-11.3 to -0.5)
Bhatt, 2014^87^ RCT | 6 | RDN (Medtronic Symplicity), 361 | Sham procedure, 168 | 163 (13.4) | 164.2 (15) | -7.2 (-8.9 to -5.5) | -6.1 (-8.9 to -3.3) | -1.1 (-4.4 to 2.2)
Desch, 2015^88^ RCT | 6 | RDN (Medtronic Symplicity), 29 | Sham procedure, 34 | 144.4 (4.8) | 143.0 (4.7) | -9.9 (-13.4 to -6.5) | -3.7 (-7.1 to -0.2) | -6.2 (-11.1 to -1.3)
Fadl Elmula, 2014^122^ RCT | 6 | RDN (Medtronic Symplicity), 9 | Continuation of anti-hypertensive drugs, 10 | 152 (10) | 152 (12) | -10 (-17.8 to -2.2) | -19 (-26.4 to -11.6) | 9 (-1.8 to 19.8)
Rosa, 2015^64^ RCT | 6 | RDN (Medtronic Symplicity), 52 | Intensification of anti-hypertensive drugs, 54 | 152 (12) | 150 (13) | -9 (-13.2 to -4.7) | -8.2 (-12.4 to -4) | -0.8 (-6.8 to 5.2)
Schneider, 2015^90^ RCT | 6 | RDN (Medtronic Flex), 9 | Continuation of anti-hypertensive drugs, 9 | NR | NR | 1.5 (-7.3 to 10.3) | -5.18 (-13.4 to 3.1) | 6.68 (-5.3 to 18.7)
Tsioufis, 2015^92^ Prospective cohort | 6 | RDN (St. Jude Medical EnligHTN), 31 | No renal denervation, 12 | 151.1 (13.5) | 148 (9.1) | -9.9 (-11.4 to -8.4) | 0.7 (-1 to 2.4) | -10.6 (-20.7 to -0.5)

ABPM = ambulatory blood pressure monitoring; CI = confidence interval; mm Hg = millimeters mercury; RCT = randomized controlled trial; RDN = renal denervation

* The mean between-group difference is calculated as the mean change from baseline in the renal denervation group minus the mean change from baseline in the control group.

Table 10 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on nighttime ambulatory systolic blood pressure

Author, year Study design | Mean followup (months) | RDN, N | Control group, N | Mean baseline nighttime ABPM (SD) in RDN group, mmHg | Mean baseline nighttime ABPM (SD) in control group, mmHg | Mean change (95% CI) from baseline in nighttime AMBP in RDN group, mm Hg | Mean change (95% CI) from baseline in nighttime AMBP in control group, mm Hg | Mean between-group^*^ difference (95% CI), mm Hg
Azizi, 2015^62^ RCT | 6 | RDN (Medtronic Symplicity) plus intensification of anti-hypertensive drugs, 48 | Intensification of anti-hypertensive drugs, 53 | 141.4 (17.3) | 135.5 (14.3) | -13.9 (-18 to -9.8) | -7.6 (-11.4 to -3.7) | -6.3 (-12.0 to -0.6)
Bhatt, 2014^87^ RCT | 6 | RDN (Medtronic Symplicity), 362 | Sham procedure, 168 | 152.5 (16.3) | 151.4 (18.7) | -5.6 (-7.6 to -3.7) | -2.4 (-5.2 to 0.5) | -3.3 (-6.8 to 0.2)
Desch, 2015^88^ RCT | 6 | RDN (Medtronic Symplicity), 29 | Sham procedure, 34 | 130.5 (9.7) | 132.3 (11.7) | -1.9 (-6.9 to 3.0) | -3.8 (-8.1 to 0.5) | 1.9 (-4.7 to 8.5)
Rosa, 2015^64^ RCT | 6 | RDN (Medtronic Symplicity), 52 | Intensification of anti-hypertensive drugs, 54 | 141 (16) | 141 (17) | -8 (-12.7 to -3.6) | -7.6 (-12.1 to -3.1) | -0.5 (-6.9 to 5.9)
Schneider, 2015^90^ RCT | 6 | RDN (Medtronic Flex), 9 | Continuation of anti-hypertensive drugs, 9 | NR | NR | -10.38 (-18.7 to -2) | -1.97 (-9.9 to 6) | -12.35 (-23.9 to -0.8)
Tsioufis, 2015^92^ Prospective cohort | 6 | RDN (St. Jude Medical EnligHTN), 31 | No renal denervation, 12 | 140.6 (13) | 137.9 (12.8) | -10.5 (-12.1 to -8.9) | -2.2 (-4.3 to -0.1) | -8.3 (-19.6 to 3)

ABPM = ambulatory blood pressure monitoring; CI = confidence interval; mm Hg = millimeters mercury; RCT = randomized controlled trial; RDN = renal denervation

* The mean between-group difference is calculated as the mean change from baseline in the renal denervation group minus the mean change from baseline in the control group.

The mean between-group difference in change in daytime ambulatory systolic blood pressure from baseline to 6 months, comparing renal denervation group with the control group (six RCTs and one controlled study; total N=879) ranged from −10.6 mm Hg to 6.68 mm Hg.^62, 64, 87, 88, 90, 92, 122^ The largest difference was in the prospective cohort study, which was statistically significant. Only two of the RCTs reported a statistically significant difference.

The mean between-group difference in mean change in nighttime ambulatory systolic blood pressure from baseline to 6 months, comparing renal denervation group with the control group (four RCTs and one controlled study; total N=798) ranged from −12.35 mm Hg to −0.5 mm Hg.^62, 64, 87, 90, 92^ A very small prospective cohort study reported the largest between-group difference. Only two of the RCTs reported a statistically significant difference.

##### Change in Office Blood Pressure

We identified 11 RCTs and controlled studies that reported changes in office systolic blood pressures (Table 11).^23, 62, 64, 87, 89-91, 122-125^ Of these 11 studies, the longest followup was 3 months for 1 study,^123^ 12 months for 2 studies, ^87, 124^ and 36 months for 1 study.^23^ The remaining seven studies reported 6-month followup.

###### Three-Month Change in Office Blood Pressure

The mean between-group difference in change in office systolic blood pressure from baseline to 3 months, comparing renal denervation group with the control group (1 controlled study; total N=125) was −16 mm Hg, which was statistically significant.^123^

###### Six-Month Change in Office Blood Pressure

The range of the between-group difference in mean change in office systolic blood pressure from baseline to 6 months, comparing renal denervation group with the control group (eight RCTs and two controlled studies; total N=1035) was −42 mm Hg to 1.9 mm Hg.^23, 62, 64, 87, 89-91, 122, 124, 125^ The between-group differences were statistically significant in four of the RCTs and in the one prospective cohort study.

###### Twelve-Month Change in Office Blood Pressure

The mean between-group difference in change in office blood pressure at 12 months in two RCTs (total N=394) were 2.5 mm Hg and -20 mm Hg, and statistically significant in the latter study.^87, 124^ One RCT did not report between-group differences at 12 months.^23^

###### Three-Year Change in Office Blood Pressure

Between-group differences in systolic blood pressure were not reported in the RCT with 3-year followup.^23^

###### Non-Controlled Studies

In 66 non-controlled studies that included 5,811 participants with a mean follow-up of 9.9 months, the median change in office systolic blood pressure from baseline was −19.7 mm Hg, with a range of change from −58.2 mm Hg to 12 mm Hg (Table 8).^48, 55-60, 63, 65, 67-77, 79-83, 91, 93-101, 103-108, 110-112, 114-116, 118-120, 123, 125-138^

#### Change in Number of Antihypertensive Medications after Renal Denervation

Changes in the number of antihypertensive medications after renal denervation were neither consistently nor systematically reported. Only 27 of the 83 studies reported some metric of this change.

##### RCTs and Comparative Studies

The mean between-group difference in the change in the number of antihypertensive medications from baseline to maximum followup, comparing the renal denervation group with the control group (three RCTs; total N=747) ranged from -0.7 to -0.1 (Table 12).^64, 87, 124^ The difference was statistically significant in two of the studies. Two other RCTs did not report on the mean between-group difference.

Table 12 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on change in number of blood pressure medication classes

Author, year Study design | Mean followup (months) | RDN, N | Control group, N | Mean baseline medications in RDN group, (SD) | Mean baseline medications in control group, (SD) | Mean change (95% CI) from baseline in number of medications in RDN group | Mean change (95% CI) from baseline in number of medications in control group | Mean between-group difference^*^ (95% CI)
Azizi, 2015^62^ RCT | 6 | RDN (Medtronic Symplicity), 53 | Continuation of anti-hypertensive drugs, 53 | 3 (NR) | 3 (NR) | Baseline median: 3 Final median: 5 | Baseline median: 3 Final median: 5 | NR
Rosa, 2015^64^ RCT | 6 | RDN (Medtronic Symplicity), 52 | Intensification of anti-hypertensive drugs, 54 | 5.1 (1.2) | 5.4 (1.2) | -0.02 (-0.2 to 0.1) P=0.81 | 0.3 (0.2 to 0.5) P=<0.001 | -0.3 (-0.5 to -0.1) P=<0.01
Bhatt, 2014^87^ RCT | 6 | RDN (Medtronic Symplicity), 364 | Sham procedure, 171 | 5.1 (1.4) | 5.2 (1.4) | -0.1 (-0.1 to -0.1) | 0 (0 to 0) | -0.1 (-0.5 to 0.3)
Pokushalov, 2012^124^ RCT | 12 | RDN (Unspecified), 13 | Pulmonary vein isolation, 14 | 3.8 (0.4) | 3.6 (0.6) | -0.5 (-0.6 to -0.4) | 0.2 (0.1 to 0.3) | -0.7 (-1.4 to 0)
Rosa, 2015^64^ RCT | 12 | RDN (Medtronic Simplicity), 51 | Continuation of anti-hypertensive drugs, 50 | 5.1 (1.2) | 5.4 (1.2) | 0.1 (-0.06 to 0.3) P = 0.2 | 0.2 (-0.2 to 0.6) P = 0.33 | -0.1 (-0.5 to 2) P = 0.69
Symplicity, 2010^23^ RCT | 36 | RDN (Medtronic Symplicity), 40 | Unspecified, but allowed to crossover to RDN after 6 months | 5.1 (1.5) | NR | -0.5 (-0.6 to -0.4) P=0.02 | NR | NR

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation; SD=standard deviation

* The mean between-group difference is calculated as the mean change from baseline in the renal denervation group minus the mean change from baseline in the control group.

##### Non-comparative Studies

The range of mean change in the number of antihypertensive medications from baseline to maximum followup, in the renal denervation group (within-group difference; 18 studies; total N=3003) was -1 to 0.2.^48, 55-57, 65, 66, 68, 74, 79, 98, 104, 107-109, 118, 130, 132, 134^

#### Stroke, Myocardial Infarction, Hospitalization, and Mortality

We did not identify any studies designed to assess the efficacy or effectiveness of renal denervation in reducing stroke, myocardial infarction, hospitalizations, or survival in patients with resistant hypertension. Most of the studies reported a short duration of followup with emphasis on adverse outcomes related to renal denervation rather than long-term outcomes.

##### Stroke

Three RCTs reported the incidence of stroke during followup (Table 13).^62, 64, 87^ There were eight strokes with an absolute risk difference of 2.2% (95% CI, -2 to 6.4%)^62^ and -0.1% (95% CI, -2.1 to 1.9)^87^ in the two studies that reported on stroke incidence in both study groups. Three non-controlled studies (1,302 patients) reported stroke events during a mean followup of 10 months (Table 14).^56, 104, 107^ The range of risk estimates was 0% to 2.2%. The studies did not show any statistically significant differences in risk of stroke.

Table 13 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on stroke

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^
Rosa, 2015^64^ RCT | 6 | Stroke (ischemic stroke) | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 52 (1.9) | NR | NR
Azizi, 2015^62^ RCT | 6 | Stroke (Not specified) | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 46 (2.2) | 0 / 53 (0) | 2.2 (-2 to 6.4)
Bhatt, 2014^87^ RCT | 6 | Stroke (Not specified) | Medtronic Symplicity | Sham procedure | 4 / 352 (1.1) | 2 / 171 (1.2) | -0.1 (-2.1 to 1.9)
Rosa, 2015^64^ RCT | 12 | Stroke (Ischemic stroke) | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 52 (1.9) | NR | NR

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm. The 95% confidence interval was calculated the absolute risk difference ± 1.96 * square root of the standard error. The standard error was calculated as ((the proportion in the renal denervation group * (1 – the proportion in the renal denervation group)) divided by the sample size in the renal denervation group) plus ((the proportion in the control group * (1 – the proportion in the control group)) divided by the sample size in the control group).

Table 14 Range in rates of stroke, myocardial infarction, hospitalization, and mortality reported in non-controlled studies of renal denervation devices

Blood pressure measure | N studies (N participants) | Mean followup (months) | Median (range) in risk estimate
Stroke | 3 (1302) | 10 | 0% to 2.2%
Myocardial infarction | 3 (1302) | 10 | 0% to 2%
Hospitalization | 4 (1455) | 16.5 | 0% to 8.5%
Mortality | 4 (1455) | 16.5 | 0% to 2%
Cardiovascular mortality | 2 (1153) | 9 | 0.7% to 2%

##### Myocardial Infarction

Four RCTs reported 13 myocardial infarctions during followup (Table 15).^62, 64, 87, 122^ Data were available in two studies to calculate absolute risk difference; the results were not statistically significant. Three non-controlled studies (1,302 patients) reported myocardial infarction events during a mean followup of 10 months (Table 14).^56, 104, 107^ The range of risk estimates was 0% to 2%. No statistically significant differences were seen in risk of myocardial infarction in these studies.

Table 15 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on myocardial infarction

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^
Azizi, 2015^62^ RCT | 6 | Myocardial infarction (Not specified) | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 46 (2.2) | 1 / 53 (1.9) | 0.3 (-5.3 to 5.9)
Bhatt, 2014^87^ RCT | 6 | Myocardial infarction (Not specified) | Medtronic Symplicity | Sham procedure | 6 / 352 (1.7) | 3 / 171 (1.8) | -0.1 (-2.5 to 2.3)
Fadl Elmula, 2014^122^ RCT | 6 | Myocardial infarction (Not specified) | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 9 (11.1) | NR | NR
Rosa, 2015^64^ RCT | 12 | Myocardial infarction (Not specified) | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 52 (1.9) | NR | NR

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

##### Hospitalizations

Hospitalizations during followup were reported in two RCTs.^23, 87^ The causes included hypertensive crisis, hypotension, atrial fibrillation, angina, and transient ischemic attack (Table 16). Hospitalizations were reported in four non-controlled studies (1,455 patients) with risk estimates ranging from 0% to 8.5% (Table 14).^56, 104, 107, 134^ No statistically significant differences were seen in risk of hospitalizations in these studies.

Table 16 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on hospitalization

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^
Symplicity, 2010^23^ RCT | 6 | Hospitalization (for nausea and edema) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | NR | NR
Symplicity, 2010^23^ RCT | 6 | Hospitalization (for hypertensive event) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | NR | 2 / 35 (5.7) | NR
Symplicity, 2010^23^ RCT | 6 | Hospitalization (for hypotensive episode) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | NR | 1 / 35 (2.9) | NR
Symplicity, 2010^23^ RCT | from 12 to 36 | Hospitalization (for hypertensive events) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 5 / 69 (7.2) | NR | NR
Symplicity, 2010^23^ RCT | 6 | Hospitalization (for transient ischemic attack) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | 2 / 54 (3.7) | -1.8 (-8.1 to 4.5)
Bhatt, 2014^87^ RCT | 6 | Hospitalization (for atrial fibrillation) | Medtronic Symplicity | Sham procedure | 5 / 352 (1.4) | 1 / 171 (0.6) | 0.8 (-0.9 to 2.5)
Symplicity, 2010^23^ RCT | 6 | Hospitalization (for coronary stent for angina) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | 1 / 54 (1.9) | 0 (-5.2 to 5.2)
Symplicity, 2010^23^ RCT | 6 | Hospitalization (for hypertensive emergency) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 3 / 52 (5.8) | 2 / 54 (3.7) | 2.1 (-6 to 10.2)
Symplicity, 2010^23^ RCT | 6 | Hospitalization (for hypotensive episode) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | NR | NR
Bhatt, 2014^87^ RCT | 6 | Hospitalization (for new-onset heart failure) | Medtronic Symplicity | Sham procedure | 9 / 352 (2.6) | 3 / 171 (1.8) | 0.8 (-1.8 to 3.4)
Symplicity, 2010^23^ RCT | between 12 and 36 | Hospitalization (for atrial fibrillation) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 2 / 69 (2.9) | NR | NR
Symplicity, 2010^23^ RCT | 6 | Hospitalization (for hypertension crisis after abrupt stopping of clonidine) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | NR | NR

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

##### Mortality

Mortality was reported in three RCTs (Table 17)^23, 64, 87, 88^ and four non-controlled studies (Table 14).^56, 104, 107, 134^ The studies reported very few deaths, with no statistically significant differences.

Table 17 Randomized controlled trials and controlled studies comparing the effects of renal denervation devices on mortality

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^
Bhatt, 2014^87^ RCT | 6 | Mortality (Not specified) | Medtronic Symplicity | Sham procedure | 2 / 352 (0.6) | 1 / 171 (0.6) | 0 (-1.4 to 1.4)
Bhatt, 2014^87^ RCT | 12 | Mortality (Not specified) | Medtronic Symplicity | Sham procedure | 6 / 355 (1.8) | 2 / 69 (3.6) | -1.8 (-6.4 to 2.8)
Rosa, 2015^64^ RCT | 12 | Mortality (Not specified) | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 0 / 52 (0) | 0 / 54 (0) | 0 (0 to 0)
Symplicity, 2010^23^ RCT | between 12 and 36 | Mortality (Not specified) | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 | 3 / 69 (4.3) | NR | NR

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

### KQ 7 What is the evidence for renal denervation effectiveness in other conditions such as heart failure and arrhythmias?

#### Key Point

- Data were very limited on the efficacy of renal denervation for conditions other than resistant hypertension. We provide a narrative review of literature in this area and note that scant data preclude further analyses or conclusions.

Sympathetic nervous system over-activity is thought to play a maladaptive role in multiple conditions including cardiac arrhythmias, congestive heart failure, metabolic syndrome, and sleep apnea. The evidence for the effectiveness of renal denervation in these sympathetically driven conditions is lacking in humans, and is limited primarily to case reports, case series, and first-in-man studies.

#### Cardiac Arrhythmias

The cardiac arrhythmia most widely studied with regards to the application of renal denervation is atrial fibrillation. Hypertension is a major risk factor for atrial fibrillation and the sympathetic nervous system is thought to play a pathological role in atrial electrical and structural remodeling and the development of atrial fibrillation.^139^ In a very small randomized trial (N = 27) of patients with symptomatic drug-refractory atrial fibrillation and drug-resistant hypertension (i.e., office-based systolic blood pressure greater than or equal to 160 mm Hg on three or more anti-hypertensive medications) undergoing pulmonary vein isolation with and without renal denervation, there was a lower recurrence of atrial fibrillation with renal denervation plus pulmonary vein isolation compared with pulmonary vein isolation alone at one year (69 percent versus 29 percent, P = 0.03).^124^ These results do not include atrial fibrillation that occurred within the first 3 months. As reported by the authors, the primary endpoint of the study was atrial fibrillation occurring after 3 months because early recurrence after pulmonary vein isolation is common, and does not necessarily portend an unsuccessful long-term outcome.^140^

Numerous clinical trials involving atrial fibrillation are ongoing, including the SYMPLICITY AF trial (NCT02064764), which is an industry-sponsored study of renal denervation in patients with hypertension and paroxysmal and persistent atrial fibrillation. The evidence for the efficacy of renal denervation in suppressing ventricular arrhythmias is limited to case reports of acute control of recurrent monomorphic ventricular tachycardia^141^ and ventricular electrical storm.^142^

#### Congestive Heart Failure

The sympathetic nervous system and neuro-hormonal dysregulation play a fundamental role in cardiomyopathy and heart failure with an extreme example of this being stress cardiomyopathy which is a syndrome of profound myocardial stunning from catecholamine toxicity often triggered by acute emotional stress.^143^ At the level of the kidney, renal sympathetic efferent activation stimulates renin release, sodium and water retention, and reduced renal blood flow that leads to further sympathetic activation as part of a maladaptive feedback loop.^144^

Large RCTs of renal denervation in heart failure are lacking. The Renal Artery Denervation in Chronic Heart Failure (REACH) study was a first-in-man pilot study of renal denervation in seven non-hypertensive patients with New York Heart Association (NYHA) class III to IV heart failure and a left ventricular ejection fraction of 28 percent to 58 percent with improvement in the 6-minute walk distance (mean ± standard deviation, 221 ± 33 meters to 249 ± 34 meters, P = 0.03) and reduced diuretic requirements in four patients (P = 0.046) at 6 months following renal denervation.^145^ A study of 46 patients with resistant hypertension who underwent renal denervation demonstrated that along with significant reductions in blood pressure, there were significant reductions in mean inter-ventricular septum thickness, left ventricular mass index, surrogate echocardiographic markers of left ventricular diastolic filling pressure, and isovolumic relaxation time accompanied by an increase in ejection fraction at 6 months. This highlights the improvement in overall cardiac performance and the potential cardiac remodeling benefits of renal denervation in this population.^146^ The SYMPLICITY HF trial (NCT01392196) is an ongoing industry-sponsored study designed to evaluate the safety and efficacy of renal denervation in the treatment of patients with NYHA class II to III congestive heart failure, impaired left ventricular function (i.e., ejection fraction less than 40 percent), and impaired renal function (i.e., glomerular filtration rate 30 to 75 mL/min/1.73 m2).

#### Metabolic Syndrome and Diabetes

An imbalance between the sympathetic and parasympathetic nervous system may play a role in the development of metabolic syndrome and diabetes mellitus.^147^ The sympathetic nervous system facilitates rapid accessibility of energy stores through glycogenolysis, gluconeogenesis, and lipolysis as part of the fight-or-flight response to stress. Poor parasympathetic tone, manifesting as slower heart rate recovery after exercise, has also been correlated with the development of diabetes mellitus.^148-150^ As a result, renal denervation has been investigated as a novel treatment for metabolic syndrome and diabetes mellitus. A small, non-randomized cohort study of patients with resistant hypertension showed that renal denervation (N = 37) had a mean within-group reduction in fasting glucose levels (-9.4 mg/dL; P = 0.039), fasting insulin levels (-11.6 μIU/mL; P = 0.006), and fasting C-peptide levels (-2.3 ng/mL (P = 0.002) at 3 months, compared with no significant changes in the control group (N = 13).^151^ A small Dutch trial investigated the effects of renal denervation in 29 patients with metabolic syndrome and found that renal denervation failed to improve insulin sensitivity at 12 months and had no effect on sympathetic nerve activity.^108^ Another trial of renal denervation and glucose metabolism in 51 patients with resistant hypertension also found no favorable effect of renal denervation on fasting glucose, C-peptide, or glycated hemoglobin at 12 months.^152^

#### Sleep Apnea

Sleep apnea is an important cardiovascular risk factor for hypertension, stroke, atrial fibrillation, and congestive heart failure; sympathetic nervous system activation has been attributed to it as both a cause and an effect.^153^ One “proof of concept” study of ten patients with refractory hypertension and sleep apnea showed that at 6 months following renal denervation, there was a significant reduction in office-based blood pressure, indices of glucose control (e.g., hemoglobin A_1c_ and plasma glucose concentration 2 hours after glucose administration), and the apnea-hypopnea index (median: 16.3 versus 4.5 events per hour; P = 0.059).^154^ An analysis of the Global SYMPLICITY Registry demonstrated significant blood pressure reductions at 6 months in patients with and without sleep apnea. The investigators observed that continuous positive airway pressure treatment did not seem to have an impact on blood pressure reduction in this population,^155^ highlighting the fact that like the other sympathetically driven conditions discussed, further study is necessary.

### KQ 8 What are the adverse effects or complications associated with renal denervation in the Medicare population?

#### Key Point

- Reporting of complications was neither comprehensive nor standardized across studies. Overall, relatively few complications were reported in the published studies.

#### RCTs and Comparative Cohort Studies

Of the 17 RCTs and comparative cohort studies that we reviewed, only 8 (47%) reported any complication in the renal denervation group. Complications related to femoral artery puncture (e.g., pseudoaneurysm or hematoma) were reported in 11 patients, and renal artery interventions (e.g., dissection, stenosis) were reported in six patients (Tables 18 and 19). Embolic events were reported in two patients, and renal events (increase in serum creatinine, acute kidney injury or end-stage renal disease) were reported in ten patients (Tables 20 and 21). Most studies had a short duration of followup (6 months) with only three studies having followup of 1 year or more. ^23, 87, 124^

Table 18 Adverse events related to femoral artery puncture reported in randomized controlled trials or controlled studies evaluating renal denervation devices

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^ | Number needed to harm^†^
Schneider, 2015^90^ RCT | 6 | Pseudoaneurysm at the femoral vascular access site | Medtronic Flex | Continuation of anti-hypertensive drugs | 2 / 9 (22.2) | NR | NR | NR
Rosa, 2015^64^ RCT | 6 | Postpunctual pseudoaneurysm | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 52 (2) | NR | NR | NR
Symplicity, 2010^23^ RCT | 6 | Femoral artery pseudoaneurysm | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | NR | NR | NR
Azizi, 2015^62^ RCT | 6 | Groin hematoma | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 46 (2.2) | 0 / 53 (0) | 2.2 (-2 to 6.4) | 45
Fadl Elmula, 2014^122^ RCT | 6 | Mild-to-moderate hematomas at the femoral access site | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 4 / 9 (44.4) | NR | NR | NR
Rosa, 2015^64^ RCT | 6 | Arterio-venous fistula | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 52 (2) | NR | NR | NR
Bhatt, 2014^87^ RCT | 6 | Vascular complication requiring treatment | Medtronic Symplicity | Sham procedure | 1 / 352 (0.3) | 0 / 171 (0) | 0.3 (-0.3 to 0.9) | 333
Bhatt, 2014^87^ RCT | 12 | Vascular complication | Medtronic Symplicity | Sham procedure | 1 / 355 (0.3) | 0 / 69 (0) | 0.3 (-0.3 to 0.9) | 333

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

† Number needed to harm = the inverse of the absolute risk difference.

Table 19 Adverse events related to renal artery interventions reported in randomized controlled trials or controlled studies evaluating renal denervation devices

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^ | Number needed to harm^†^
Bhatt, 2014^87^ RCT | 6 | New renal-artery stenosis of >70% | Medtronic Symplicity | Sham procedure | 1 / 332 (0.3) | 0 / 165 (0) | 0.3 (-0.3 to 0.9) | 333.3
Bhatt, 2014^87^ RCT | 6 | Renal-artery intervention | Medtronic Symplicity | Sham procedure | 0 / 352 (0) | 0 / 171 (0) | 0 (0 to 0) | NR
Pokushalov, 2012^124^ RCT | 6 | Renal artery stenosis | Unspecified | Pulmonary vein isolation | 0 / 13 (0) | 0 / 14 (0) | 0 (0 to 0) | NR
Rosa, 2015^64^ RCT | 6 | Dissection of renal artery | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 52 (2) | NR | NR | NR
Symplicity, 2010^23^ RCT | 6 | Renal artery dissection | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | NR | 1 / 35 (2.9) | NR | NR
Symplicity, 2010^23^ RCT | 6 | Progression of atherosclerotic lesion | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 43 (2.3) | NR | NR | NR
Bhatt, 2014^87^ RCT | 12 | New renal artery stenosis > 70% | Medtronic Symplicity | Sham procedure | NR | 0 / 69 (0) | NR | NR
Bhatt, 2014^87^ RCT | 12 | Renal artery reintervention | Medtronic Symplicity | Sham procedure | 2 / 355 (0.6) | 0 / 69 (0) | 0.6 (-0.2 to 1.4) | 166.7

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

† Number needed to harm = the inverse of the absolute risk difference.

Table 20 Adverse events related to embolic events reported in randomized controlled trials or controlled studies evaluating renal denervation devices

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^ | Number needed to harm^†^
Bhatt, 2014^87^ RCT | 6 | Embolic event resulting in end-organ damage | Medtronic Symplicity | Sham procedure | 1 / 352 (0.3) | 0 / 171 (0) | 0.3 (-0.3 to 0.9) | 333.3
Bhatt, 2014^87^ RCT | 12 | Significant embolic event resulting in end-organ damage | Medtronic Symplicity | Sham procedure | 1 / 355 (0.3) | 0 / 69 (0) | 0.3 (-0.3 to 0.9) | 333.3

RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

† Number needed to harm = the inverse of the absolute risk difference.

Table 21 Adverse events related to renal events reported in randomized controlled trials or controlled studies evaluating renal denervation devices

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^
Kario, 2015^89^ RCT | 6 | 50% increase in serum creatinine | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 22 (4.5) | 0 / 19 (0) | 4.5 (-4.2 to 13.2)
Bhatt, 2014^87^ RCT | 6 | Increase in serum creatinine >50% from baseline | Medtronic Symplicity | Sham procedure | 5 / 352 (1.4) | 1 / 171 (0.6) | 0.8 (-0.9 to 2.5)
Bhatt, 2014^87^ RCT | 6 | New-onset end-stage renal disease | Medtronic Symplicity | Sham procedure | 0 / 352 (0) | 0 / 171 (0) | 0 (0 to 0)
Fadl Elmula, 2014^122^ RCT | 6 | Detectable change in renal function | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 0 / 9 (0) | 0 / 10 (0) | 0 (0 to 0)
Rosa, 2015^64^ RCT | 6 | Worsening of renal function | Medtronic Symplicity | Continuation of anti-hypertensive drugs | NR | 1 / 54 (2) | NR
Bhatt, 2014^87^ RCT | 12 | New-onset end-stage renal disease | Medtronic Symplicity | Sham procedure | 1 / 355 (0.3) | 0 / 70 (0) | 0.3 (-0.3 to 0.9)
Symplicity, 2010^23^ RCT | Between 12 and 36 | Acute renal failure | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 69 (1.4) | NR | NR
Symplicity, 2010^23^ RCT | Between 12 and 36 | Renal vascular events | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 0 / 69 (0) | NR | NR

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

The studies reported a number of other adverse events that are described in Tables 22 and 23. Of these events, 104 were due to changes in blood pressure (e.g., hypotension or hypertension). The remainders were highly variable; some were related to the procedure (e.g., renal artery spasms after application of radiofrequency energy) while others were related to the effect of conscious sedation/analgesia (e.g., laryngospasm).

Table 22 Adverse events related to blood pressure reported in randomized controlled trials or controlled studies evaluating renal denervation devices

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^
Azizi, 2015^62^ RCT | 6 | Hypertension crisis | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 3 / 46 (6.5) | 3 / 53 (5.7) | 0.8 (-8.7 to 10.3)
Azizi, 2015^62^ RCT | 6 | Syncope | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 0 / 46 (0) | 1 / 53 (1.9) | -1.9 (-5.6 to 1.8)
Bhatt, 2014^87^ RCT | 6 | Hypertensive crisis or emergency | Medtronic Symplicity | Sham procedure | 9 / 352 (2.6) | 9 / 171 (5.3) | -2.7 (-6.4 to 1)
Fadl Elmula, 2014^122^ RCT | 6 | Symptomatic hypotension | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 9 (11.1) | 4 / 10 (40) | -28.9 (-65.5 to 7.7)
Rosa, 2015^64^ RCT | 6 | Refusal to continue treatment with spironolactone because of symptomatic blood pressure reduction | Medtronic Symplicity | Continuation of anti-hypertensive drugs | NR | 5 / 54 (9) | NR
Rosa, 2015^64^ RCT | 6 | Refusal to start spironolactone treatment | Medtronic Symplicity | Continuation of anti-hypertensive drugs | NR | 2 / 54 (4) | NR
Symplicity, 2010^23^ RCT | 6 | Post-procedural drop in blood pressure resulting in reduction in anti-hypertensive drugs | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | NR | NR
Bhatt, 2014^87^ RCT | 12 | Hypertensive crisis/emergency | Medtronic Symplicity | Sham procedure | 17 / 355 (4.8) | 4 / 69 (5.5) | -0.7 (-6.5 to 5.1)

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

Table 23 Other adverse events reported in randomized controlled trials or controlled studies evaluating renal denervation devices

Author, year Study design | Mean followup (months) | Outcome definition | RDN | Control group | n/N (%) in RDN group | n/N (%) in control group | Absolute risk difference, %^*^
Kario, 2015^89^ RCT | 6 | Major adverse event | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 0 / 22 (0) | 0 / 19 (0) | 0 (0 to 0)
Azizi, 2015^62^ RCT | 6 | Lumbar pain | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 2 / 46 (4.3) | 0 / 53 (0) | 4.3 (-1.6 to 10.2)
Azizi, 2015^62^ RCT | 6 | Hypokalemia | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 46 (2.2) | 0 / 53 (0) | 2.2 (-2 to 6.4)
Azizi, 2015^62^ RCT | 6 | Hyperkalemia | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 46 (2.2) | 0 / 53 (0) | 2.2 (-2 to 6.4)
Azizi, 2015^62^ RCT | 6 | Pancreatitis | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 46 (2.2) | 0 / 53 (0) | 2.2 (-2 to 6.4)
Rosa, 2015^64^ RCT | 6 | Unstable angina | Medtronic Symplicity | Continuation of anti-hypertensive drugs | NR | 1 / 54 (1.9) | NR
Rosa, 2015^64^ RCT | 6 | Spasms after application of radiofrequency energy | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 4 / 52 (8) | NR | NR
Rosa, 2015^64^ RCT | 6 | Laryngospasm after analgosedation | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 52 (2) | NR | NR
Rosa, 2015^64^ RCT | 6 | Asymptomatic bradycardia after procedure | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 2 / 52 (4) | NR | NR
Rosa, 2015^64^ RCT | 6 | Phlebitis associated with peripheral line | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 52 (2) | NR | NR
Rosa, 2015^64^ RCT | 6 | Hyperkalemia | Medtronic Symplicity | Continuation of anti-hypertensive drugs | NR | 6 / 54 (11) | NR
Rosa, 2015^64^ RCT | 6 | Antiandrogen effect of spironolactone | Medtronic Symplicity | Continuation of anti-hypertensive drugs | NR | 7 / 54 (13) | NR
Fadl Elmula, 2014^122^ RCT | 6 | Bradycardia | Medtronic Symplicity | Continuation of anti-hypertensive drugs | 1 / 9 (11.1) | NR | NR
Fadl Elmula, 2014^122^ RCT | 6 | Sexual dysfunction | Medtronic Symplicity | Continuation of anti-hypertensive drugs | NR | 2 / 10 (20) | NR
Symplicity, 2010^23^ RCT | 6 | Urinary tract infection | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | NR | NR
Symplicity, 2010^23^ RCT | 6 | Extended hospital admission for assessment of paresthesia | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | NR | NR
Symplicity, 2010^23^ RCT | 6 | Back pain | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 1 / 52 (1.9) | NR | NR
Symplicity, 2010^23^ RCT | 6 | Bradycardia | Medtronic Symplicity | Unspecified, but allowed to crossover to RDN after 6 months | 7 / 52 (13) | NR | NR

NR = not reported; RCT = randomized controlled trial; RDN = renal denervation

* Absolute risk difference = event rate in the renal denervation arm minus the event rate in the control arm.

#### Non-comparative Cohort Studies

Of the 59 non-comparative studies, we found reports of complications in 23 (39%) (Appendix E, Table 9). Complications related to femoral artery puncture (e.g., pseudoaneurysm or hematoma) were reported in 12 patients, and renal artery interventions (e.g., dissection, stenosis) were reported in 15 patients. No embolic events were reported. Renal events (e.g., increase in serum creatinine, acute kidney injury or end-stage renal disease) were reported in 30 patients.