# References

1 Nwankwo T, Yoon SS, Burt V, et al. (2013). Hypertension among adults in the United States: National Health and Nutrition Examination Survey, 2011-2012. NCHS Data Brief.
2 Yoon SS, Carroll MD, Fryar CD. (2015). Hypertension Prevalence and Control Among Adults: United States, 2011-2014. NCHS Data Brief.
3 Go AS, Mozaffarian D, Roger VL, et al. (2014). Heart disease and stroke statistics--2014 update: a report from the American Heart Association. Circulation.
4 Enam N, Kakkad K, Amin A, et al. (2014). Management of hypertension in the hemodialysis population: a review of the literature. Journal of Community Hospital Internal Medicine Perspectives.
5 Weber MA, Schiffrin EL, White WB, et al. (2014). Clinical practice guidelines for the management of hypertension in the community: a statement by the American Society of Hypertension and the International Society of Hypertension. J Clin Hypertens (Greenwich).
6 Calhoun DA, Jones D, Textor S, et al. (2008). Resistant hypertension: diagnosis, evaluation, and treatment. A scientific statement from the American Heart Association Professional Education Committee of the Council for High Blood Pressure Research. Hypertension.
7 Mancia G, Fagard R, Narkiewicz K, et al. (2013). 2013 ESH/ESC guidelines for the management of arterial hypertension: the Task Force for the Management of Arterial Hypertension of the European Society of Hypertension (ESH) and of the European Society of Cardiology (ESC). Eur Heart J.
8 National Clinical Guideline Centre. (2011). Hypertension. Clinical management of primary hypertension in adults.
9 National Heart, Lung,, and Blood Institute. (2015). Landmark NIH study shows intensive blood pressure management may save lives.
10 Egan BM, Zhao Y, Axon RN, et al. (2011). Uncontrolled and apparent treatment resistant hypertension in the United States, 1988 to 2008. Circulation.
11 Irvin MR, Shimbo D, Mann DM, et al. (2012). Prevalence and correlates of low medication adherence in apparent treatment-resistant hypertension. J Clin Hypertens (Greenwich).
12 Muntner P, Davis BR, Cushman WC, et al. (2014). Treatment-resistant hypertension and the incidence of cardiovascular disease and end-stage renal disease: results from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Hypertension.
13 Schlaich MP, Sobotka PA, Krum H, et al. (2009). Renal sympathetic-nerve ablation for uncontrolled hypertension. N Engl J Med.
14 (2011). Higgins JPT, G S, et al., editors. Cochrane handbook for systemic reviews of interventions Version 5.1.0.
15 Downs SH, Black N. (1998). The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health.
16 Schlaich MP, Hering D, Sobotka PA, et al. (2012). Renal denervation in human hypertension: mechanisms, current findings, and future prospects. Curr Hypertens Rep.
17 DiBona GF. (2005). Physiology in perspective: The Wisdom of the Body. Neural control of the kidney. Am J Physiol Regul Integr Comp Physiol.
18 Smithwick RH, Thompson JE. (1953). Splanchnicectomy for essential hypertension; results in 1,266 cases. J Am Med Assoc.
19 Grimson KS, Orgain ES, et al. (1949). Results of treatment of patients with hypertension by total thoracic and partial to total lumbar sympathectomy, splanchnicectomy and celiac ganglionectomy. Ann Surg.
20 Schlaich MP, Krum H, Whitbourn R. (2009). Effects of renal sympathetic denervation on noradrenaline spillover and systemic blood pressure in patients with resistant hypertension. J Hypertens.
21 Schlaich M, Krum H, Walton T. (2009). A novel catheter based approach to denervate the human kidney reduces blood pressure and muscle sympathetic nerve activity in a patient with end stage renal disease and hypertension. J Hypertens.
22 Esler M, Schlaich M, Sobotka P. (2009). Catheter-based renal denervation reduces total body and renal noradrenaline spillover and blood pressure in resistant hypertension. J Hypertens.
23 Symplicity HTNI, Esler MD, Krum H, et al. (2010). Renal sympathetic denervation in patients with treatment-resistant hypertension (The Symplicity HTN-2 Trial): a randomised controlled trial. Lancet.
24 Laffin LJ, Bakris GL. (2015). Renal denervation for resistant hypertension and beyond. Adv Chronic Kidney Dis.
25 Giles TD, Materson BJ, Cohn JN, et al. (2009). Definition and classification of hypertension: an update. J Clin Hypertens (Greenwich).
26 Lewington S, Clarke R, Qizilbash N, et al. (2002). Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. Lancet.
27 Chobanian AV, Bakris GL, Black HR, et al. (2003). Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Hypertension.
28 (1991). Prevention of stroke by antihypertensive drug treatment in older persons with isolated systolic hypertension. Final results of the Systolic Hypertension in the Elderly Program (SHEP). SHEP Cooperative Research Group. JAMA.
29 Kostis JB, Davis BR, Cutler J, et al. (1997). Prevention of heart failure by antihypertensive drug treatment in older persons with isolated systolic hypertension. SHEP Cooperative Research Group. JAMA.
30 Einhorn PT, Davis BR, Wright JT, et al. (2010). ALLHAT: still providing correct answers after 7 years. Curr Opin Cardiol.
31 Beckett NS, Peters R, Fletcher AE, et al. (2008). Treatment of hypertension in patients 80 years of age or older. N Engl J Med.
32 Wright JT, Williamson JD, Whelton PK, et al. (2015). A Randomized Trial of Intensive versus Standard Blood-Pressure Control. N Engl J Med.
33 Ogden LG, He J, Lydick E, et al. (2000). Long-term absolute benefit of lowering blood pressure in hypertensive patients according to the JNC VI risk stratification. Hypertension.
34 Staessen JA, Wang JG, Thijs L. (2001). Cardiovascular protection and blood pressure reduction: a meta-analysis. Lancet.
35 Husten L. (2013). The FDA, Surrogate Endpoints, and Blood Pressure Drugs.
36 Law MR, Morris JK, Wald NJ. (2009). Use of blood pressure lowering drugs in the prevention of cardiovascular disease: meta-analysis of 147 randomised trials in the context of expectations from prospective epidemiological studies. BMJ.
37 Lv J, Ehteshami P, Sarnak MJ, et al. (2013). Effects of intensive blood pressure lowering on the progression of chronic kidney disease: a systematic review and meta-analysis. CMAJ.
38 Dahlof B, Devereux RB, Kjeldsen SE, et al. (2002). Cardiovascular morbidity and mortality in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet.
39 Wright JT, Bakris G, Greene T, et al. (2002). Effect of blood pressure lowering and antihypertensive drug class on progression of hypertensive kidney disease: results from the AASK trial. JAMA.
40 (2002). Major outcomes in high-risk hypertensive patients randomized to angiotensin-converting enzyme inhibitor or calcium channel blocker vs diuretic: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). JAMA.
41 (2003). Diuretic versus alpha-blocker as first-step antihypertensive therapy: final results from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Hypertension.
42 Mann JF, Schmieder RE, McQueen M, et al. (2008). Renal outcomes with telmisartan, ramipril, or both, in people at high vascular risk (the ONTARGET study): a multicentre, randomised, double-blind, controlled trial. Lancet.
43 Fried LF, Emanuele N, Zhang JH, et al. (2013). Combined angiotensin inhibition for the treatment of diabetic nephropathy. N Engl J Med.
44 Weintraub WS, Luscher TF, Pocock S. (2015). The perils of surrogate endpoints. Eur Heart J.
45 Howard VJ, Tanner RM, Anderson A, et al. (2015). Apparent Treatment-resistant Hypertension Among Individuals with History of Stroke or Transient Ischemic Attack. Am J Med.
46 Chobanian AV, Bakris GL, Black HR, et al. (2003). The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA.
47 James PA, Oparil S, Carter BL, et al. (2014). 2014 evidence-based guideline for the management of high blood pressure in adults: report from the panel members appointed to the Eighth Joint National Committee (JNC 8). JAMA.
48 Ewen S, Meyer MR, Cremers B, et al. (2015). Blood pressure reductions following catheter-based renal denervation are not related to improvements in adherence to antihypertensive drugs measured by urine/plasma toxicological analysis. Clin Res Cardiol.
49 Taler SJ, Textor SC, Augustine JE. (2002). Resistant hypertension: comparing hemodynamic management to specialist care. Hypertension.
50 Williams B, MacDonald TM, Morant S, et al. (2015). Spironolactone versus placebo, bisoprolol, and doxazosin to determine the optimal treatment for drug-resistant hypertension (PATHWAY-2): a randomised, double-blind, crossover trial. Lancet.
51 Dahal K, Kunwar S, Rijal J, et al. (2015). The Effects of Aldosterone Antagonists in Patients With Resistant Hypertension: A Meta-Analysis of Randomized and Nonrandomized Studies. Am J Hypertens.
52 Acelajado MC, Pisoni R, Dudenbostel T, et al. (2012). Refractory hypertension: definition, prevalence, and patient characteristics. J Clin Hypertens (Greenwich).
53 Flack JM, Bhatt DL, Kandzari DE, et al. (2015). An analysis of the blood pressure and safety outcomes to renal denervation in African Americans and Non-African Americans in the SYMPLICITY HTN-3 trial. J Am Soc Hypertens.
54 Kandzari DE, Bhatt DL, Brar S, et al. (2015). Predictors of blood pressure response in the SYMPLICITY HTN-3 trial. Eur Heart J.
55 Tsioufis CP, Papademetriou V, Dimitriadis KS, et al. (2015). Catheter-based renal denervation for resistant hypertension: Twenty-four month results of the EnligHTN I first-in-human study using a multi-electrode ablation system. Int J Cardiol.
56 Kim BK, Bohm M, Mahfoud F, et al. (2015). Renal denervation for treatment of uncontrolled hypertension in an Asian population: results from the Global SYMPLICITY Registry in South Korea (GSR Korea). J Hum Hypertens.
57 Id D, Bertog SC, Ziegler AK, et al. (2015). Predictors of Blood Pressure Response: Obesity Is Associated With a Less Pronounced Treatment Response After Renal Denervation. Catheter Cardiovasc Interv.
58 Ott C, Schmid A, Toennes SW, et al. (2015). Central pulse pressure predicts BP reduction after renal denervation in patients with treatment-resistant hypertension. EuroIntervention.
59 Ott C, Mahfoud F, Schmid A, et al. (2015). Renal denervation preserves renal function in patients with chronic kidney disease and resistant hypertension. J Hypertens.
60 Dorr O, Liebetrau C, Mollmann H, et al. (2015). Brain-derived neurotrophic factor as a marker for immediate assessment of the success of renal sympathetic denervation. J Am Coll Cardiol.
61 Dorr O, Liebetrau C, Mollmann H, et al. (2015). Influence of Renal Sympathetic Denervation on Cardiac Extracellular Matrix Turnover and Cardiac Fibrosis. Am J Hypertens.
62 Azizi M, Sapoval M, Gosse P, et al. (2015). Optimum and stepped care standardised antihypertensive treatment with or without renal denervation for resistant hypertension (DENERHTN): a multicentre, open-label, randomised controlled trial. Lancet.
63 Sievert H, Schofer J, Ormiston J, et al. (2015). Renal denervation with a percutaneous bipolar radiofrequency balloon catheter in patients with resistant hypertension: 6-month results from the REDUCE-HTN clinical study. EuroIntervention.
64 Rosa J, Widimsky P, Tousek P, et al. (2015). Randomized comparison of renal denervation versus intensified pharmacotherapy including spironolactone in true-resistant hypertension: six-month results from the Prague-15 study. Hypertension.
65 Ewen S, Ukena C, Linz D, et al. (2015). Reduced effect of percutaneous renal denervation on blood pressure in patients with isolated systolic hypertension. Hypertension.
66 Verloop WL, Vink EE, Spiering W, et al. (2015). Effects of renal denervation on end organ damage in hypertensive patients. Eur J Prev Cardiol.
67 Dorr O, Liebetrau C, Mollmann H, et al. (2015). Beneficial effects of renal sympathetic denervation on cardiovascular inflammation and remodeling in essential hypertension. Clin Res Cardiol.
68 Vink EE, Verloop WL, Bost RB, et al. (2014). The blood pressure-lowering effect of renal denervation is inversely related to kidney function. J Hypertens.
69 Papademetriou V, Tsioufis CP, Sinhal A, et al. (2014). Catheter-based renal denervation for resistant hypertension: 12-month results of the EnligHTN I first-in-human study using a multielectrode ablation system. Hypertension.
70 Verloop WL, Vink EE, Spiering W, et al. (2014). Renal denervation in multiple renal arteries. Eur J Clin Invest.
71 Poss J, Mahfoud F, Ukena C, et al. (2014). Association of vitamin D status and blood pressure response after renal denervation. Clin Res Cardiol.
72 Lenski D, Kindermann I, Lenski M, et al. (2013). Anxiety, depression, quality of life and stress in patients with resistant hypertension before and after catheter-based renal sympathetic denervation. EuroIntervention.
73 Vogel B, Kirchberger M, Zeier M, et al. (2014). Renal sympathetic denervation therapy in the real world: results from the Heidelberg registry. Clin Res Cardiol.
74 Zuern CS, Eick C, Rizas KD, et al. (2013). Impaired cardiac baroreflex sensitivity predicts response to renal sympathetic denervation in patients with resistant hypertension. J Am Coll Cardiol.
75 Ott C, Mahfoud F, Schmid A, et al. (2013). Renal denervation in moderate treatment-resistant hypertension. J Am Coll Cardiol.
76 Worthley SG, Tsioufis CP, Worthley MI, et al. (2013). Safety and efficacy of a multi-electrode renal sympathetic denervation system in resistant hypertension: the EnligHTN I trial. Eur Heart J.
77 Schmid A, Ditting T, Sobotka PA, et al. (2013). Does renal artery supply indicate treatment success of renal denervation?. Cardiovasc Intervent Radiol.
78 Prochnau D, Heymel S, Gobel B, et al. (2013). Resistant hypertension: multivariate predictors of blood pressure response to renal denervation. Int J Cardiol.
79 Symplicity HTNI. (2011). Catheter-based renal sympathetic denervation for resistant hypertension: durability of blood pressure reduction out to 24 months. Hypertension.
80 de Sousa Almeida M, de Araujo Goncalves P, Branco P, et al. (2016). Impact of Renal Sympathetic Denervation on Left Ventricular Structure and Function at 1-Year Follow-Up. PLoS One.
81 Burchell AE, Chan K, Ratcliffe LE, et al. (2016). Controversies Surrounding Renal Denervation: Lessons Learned From Real-World Experience in Two United Kingdom Centers. J Clin Hypertens (Greenwich).
82 Sharp AS, Davies JE, Lobo MD, et al. (2016). Renal artery sympathetic denervation: observations from the UK experience. Clin Res Cardiol.
83 Tiroch K, Sause A, Szymanski J, et al. (2015). Intraprocedural reduction of the veno-arterial norepinephrine gradient correlates with blood pressure response after renal denervation. EuroIntervention.
84 Rohla M, Nahler A, Lambert T, et al. (2016). Predictors of response to renal denervation for resistant arterial hypertension: a single center experience. J Hypertens.
85 Piper MA, Evans CV, Burda BU, et al. (2014). Screening for High Blood Pressure in Adults: A Systematic Evidence Review for the U.S. Preventive Services Task Force.
86 Salles GF, Cardoso CR, Muxfeldt ES. (2008). Prognostic influence of office and ambulatory blood pressures in resistant hypertension. Arch Intern Med.
87 Bhatt DL, Kandzari DE, O'Neill WW, et al. (2014). A controlled trial of renal denervation for resistant hypertension. N Engl J Med.
88 Desch S, Okon T, Heinemann D, et al. (2015). Randomized sham-controlled trial of renal sympathetic denervation in mild resistant hypertension. Hypertension.
89 Kario K, Ogawa H, Okumura K, et al. (2015). SYMPLICITY HTN-Japan - First Randomized Controlled Trial of Catheter-Based Renal Denervation in Asian Patients. Circ J.
90 Schneider S, Promny D, Sinnecker D, et al. (2015). Impact of sympathetic renal denervation: a randomized study in patients after renal transplantation (ISAR-denerve). Nephrol Dial Transplant.
91 Tsioufis C, Papademetriou V, Dimitriadis K, et al. (2015). Effects of multielectrode renal denervation on cardiac and neurohumoral adaptations in resistant hypertension with cardiac hypertrophy: an EnligHTN I substudy. J Hypertens.
92 Tsioufis C, Papademetriou V, Tsiachris D, et al. (2015). Impact of multi-electrode renal sympathetic denervation on short-term blood pressure variability in patients with drug-resistant hypertension. Insights from the EnligHTN I study. Int J Cardiol.
93 van Brussel PM, Eeftinck Schattenkerk DW, Dobrowolski LC, et al. (2015). Effects of renal sympathetic denervation on cardiac sympathetic activity and function in patients with therapy resistant hypertension. Int J Cardiol.
94 Hameed MA, Pucci M, Martin U, et al. (2015). Renal Denervation in Patients With Uncontrolled Hypertension and Confirmed Adherence to Antihypertensive Medications. J Clin Hypertens (Greenwich).
95 Hering D, Marusic P, Walton AS, et al. (2015). Renal artery anatomy affects the blood pressure response to renal denervation in patients with resistant hypertension. Int J Cardiol.
96 Lambert GW, Hering D, Marusic P, et al. (2015). Health-related quality of life and blood pressure 12 months after renal denervation. J Hypertens.
97 Schmid A, Schmieder R, Lell M, et al. (2015). Mid-Term Vascular Safety of Renal Denervation Assessed by Follow-up MR Imaging. Cardiovasc Intervent Radiol.
98 Miroslawska A, Solbu M, Skjolsvik E, et al. (2015). Renal sympathetic denervation: effect on ambulatory blood pressure and blood pressure variability in patients with treatment-resistant hypertension. The ReShape CV-risk study. J Hum Hypertens.
99 Lobo M, Saxena M, Jain AJ, et al. (2015). 4A.09: SAFETY AND PERFORMANCE OF THE ENLIGHTN RENAL DENERVATION SYSTEM IN PATIENTS WITH SEVERE UNCONTROLLED HYPERTENSION: 12 MONTH RESULTS FROM THE ENLIGHTN II STUDY. J Hypertens.
100 Tsioufis C, Papademetriou V, Dimitriadis K, et al. (2015). 4A.03: CATHETER-BASED RENAL DENERVATION FOR RESISTANT HYPERTENSION: 24 MONTH RESULTS OF THE ENLIGHTN I STUDY USING A MULTIELECTRODE ABLATION SYSTEM. J Hypertens.
101 Sharp A, Hameed A, Nightingale A, et al. (2015). 8B.07: RESULTS FROM THE UK RENAL DENERVATION AFFILIATION- 246 CASES FROM 17 CENTRES. J Hypertens.
102 Lambert T, Nahler A, Reiter C, et al. (2015). Influence of pseudo-resistance on the effect of renal denervation on 24-hour ambulatory blood pressure levels. Catheter Cardiovasc Interv.
103 Dorr O, Ewen S, Liebetrau C, et al. (2015). Neuropeptide Y as an indicator of successful alterations in sympathetic nervous activity after renal sympathetic denervation. Clin Res Cardiol.
104 Whitbourn R, Harding SA, Walton A. (2015). Symplicity multi-electrode radiofrequency renal denervation system feasibility study. EuroIntervention.
105 Ott C, Harazny JM, Schmid A, et al. (2015). Retinal microperfusion after renal denervation in treatment-resistant hypertensive patients. Clin Res Cardiol.
106 Lambert T, Nahler A, Reiter C, et al. (2015). Frequency of renal artery stenosis after renal denervation in patients with resistant arterial hypertension. Am J Cardiol.
107 Bohm M, Mahfoud F, Ukena C, et al. (2015). First report of the Global SYMPLICITY Registry on the effect of renal artery denervation in patients with uncontrolled hypertension. Hypertension.
108 Verloop WL, Spiering W, Vink EE, et al. (2015). Denervation of the renal arteries in metabolic syndrome: the DREAMS-study. Hypertension.
109 Vink EE, Boer A, Verloop WL, et al. (2015). The effect of renal denervation on kidney oxygenation as determined by BOLD MRI in patients with hypertension. Eur Radiol.
110 Lambert T, Gammer V, Nahler A, et al. (2015). Individual-patient visit-by-visit office and ambulatory blood pressure measurements over 24months in patients undergoing renal denervation for hypertension. Int J Cardiol.
111 Verheye S, Ormiston J, Bergmann MW, et al. (2015). Twelve-month results of the rapid renal sympathetic denervation for resistant hypertension using the OneShotTM ablation system (RAPID) study. EuroIntervention.
112 Persu A, Azizi M, Jin Y, et al. (2014). Hyperresponders vs. nonresponder patients after renal denervation: do they differ?. J Hypertens.
113 Schwerg M, Heupel C, Strajnic D, et al. (2014). Renal sympathetic denervation: early impact on ambulatory resistant hypertension. J Clin Hypertens (Greenwich).
114 Lambert T, Blessberger H, Gammer V, et al. (2014). Effects of renal denervation on ambulatory blood pressure measurements in patients with resistant arterial hypertension. Clin Cardiol.
115 Ott C, Mahfoud F, Schmid A, et al. (2014). Improvement of albuminuria after renal denervation. Int J Cardiol.
116 Kaiser L, Beister T, Wiese A, et al. (2014). Results of the ALSTER BP real-world registry on renal denervation employing the Symplicity system. EuroIntervention.
117 Volz S, Andersson B, Manhem K, et al. (2014). Effect of catheter-based renal sympathetic denervation on 24-h ambulatory blood pressure in patients with resistant hypertension. Blood Press.
118 Kyvelou SM, Sharif F, Tuohy S, et al. (2013). Renal denervation: the Irish experience. Hellenic J Cardiol.
119 Lenski M, Mahfoud F, Razouk A, et al. (2013). Orthostatic function after renal sympathetic denervation in patients with resistant hypertension. Int J Cardiol.
120 Honarvar M, Amirpour A, Pourmoghaddas M. (2013). Renal ablation for treatment of hypertension without Symplicity catheter: The first human experience. ARYA Atheroscler.
121 Prochnau D, Figulla HR, Surber R. (2012). Efficacy of renal denervation with a standard EP catheter in the 24-h ambulatory blood pressure monitoring-long-term follow-up. Int J Cardiol.
122 Fadl Elmula FE, Hoffmann P, Larstorp AC, et al. (2014). Adjusted drug treatment is superior to renal sympathetic denervation in patients with true treatment-resistant hypertension. Hypertension.
123 Lambert GW, Hering D, Esler MD, et al. (2012). Health-related quality of life after renal denervation in patients with treatment-resistant hypertension. Hypertension.
124 Pokushalov E, Romanov A, Corbucci G, et al. (2012). A randomized comparison of pulmonary vein isolation with versus without concomitant renal artery denervation in patients with refractory symptomatic atrial fibrillation and resistant hypertension. J Am Coll Cardiol.
125 Ewen S, Mahfoud F, Linz D, et al. (2014). Effects of renal sympathetic denervation on exercise blood pressure, heart rate, and capacity in patients with resistant hypertension. Hypertension.
126 Tank J, Heusser K, Brinkmann J, et al. (2015). Spike rate of multi-unit muscle sympathetic nerve fibers after catheter-based renal nerve ablation. J Am Soc Hypertens.
127 Worthley S, Kataoka Y, Nicholls S, et al. (2015). 8B.03: ATHEROMA PROGRESSION IN RENAL ARTERIES AFTER CATHETER-BASED RENAL ARTERY DENERVATION USING SERIAL VOLUMETRIC COMPUTED TOMOGRAPHY ANALYSIS: ANALYSIS FROM THE ENLIGHTN 1 TRIAL. J Hypertens.
128 Kiuchi MG, Chen S, Graciano ML, et al. (2015). Acute effect of renal sympathetic denervation on blood pressure in refractory hypertensive patients with chronic kidney disease. Int J Cardiol.
129 Eikelis N, Hering D, Marusic P, et al. (2015). The effect of renal denervation on endothelial function and inflammatory markers in patients with resistant hypertension. Int J Cardiol.
130 Poss J, Ewen S, Schmieder RE, et al. (2015). Effects of renal sympathetic denervation on urinary sodium excretion in patients with resistant hypertension. Clin Res Cardiol.
131 Kiuchi MG, Chen S, Andrea BR, et al. (2014). Renal sympathetic denervation in patients with hypertension and chronic kidney disease: does improvement in renal function follow blood pressure control?. J Clin Hypertens (Greenwich).
132 Hamza M, Khamis H. (2014). Renal sympathetic denervation for treatment of resistant hypertension: Egyptian experience. J Interv Cardiol.
133 Zhang ZH, Yang K, Jiang FL, et al. (2014). The effects of catheter-based radiofrequency renal denervation on renal function and renal artery structure in patients with resistant hypertension. J Clin Hypertens (Greenwich).
134 Krum H, Schlaich MP, Sobotka PA, et al. (2014). Percutaneous renal denervation in patients with treatment-resistant hypertension: final 3-year report of the Symplicity HTN-1 study. Lancet.
135 Dorr O, Liebetrau C, Mollmann H, et al. (2013). Renal sympathetic denervation does not aggravate functional or structural renal damage. J Am Coll Cardiol.
136 Kiuchi MG, Graciano ML, Carreira MA, et al. (2015). Long-Term Effects of Renal Sympathetic Denervation on Hypertensive Patients With Mild to Moderate Chronic Kidney Disease. J Clin Hypertens (Greenwich).
137 Ewen S, Cremers B, Meyer MR, et al. (2015). Blood pressure changes after catheter-based renal denervation are related to reductions in total peripheral resistance. J Hypertens.
138 Ripp TM, Mordovin VF, Pekarskiy SE, et al. (2015). Predictors of Renal Denervation Efficacy in the Treatment of Resistant Hypertension. Curr Hypertens Rep.
139 Patterson E, Lazzara R, Szabo B, et al. (2006). Sodium-calcium exchange initiated by the Ca2+ transient: an arrhythmia trigger within pulmonary veins. J Am Coll Cardiol.
140 Staessen JA, Jin Y, Thijs L, et al. (2013). First-in-man randomized clinical trial of renal denervation for atrial arrhythmia raises concern. J Am Coll Cardiol.
141 Ukena C, Bauer A, Mahfoud F, et al. (2012). Renal sympathetic denervation for treatment of electrical storm: first-in-man experience. Clin Res Cardiol.
142 Hoffmann BA, Steven D, Willems S, et al. (2013). Renal sympathetic denervation as an adjunct to catheter ablation for the treatment of ventricular electrical storm in the setting of acute myocardial infarction. J Cardiovasc Electrophysiol.
143 Wittstein IS, Thiemann DR, Lima JA, et al. (2005). Neurohumoral features of myocardial stunning due to sudden emotional stress. N Engl J Med.
144 Sobotka PA, Krum H, Bohm M, et al. (2012). The role of renal denervation in the treatment of heart failure. Curr Cardiol Rep.
145 Davies JE, Manisty CH, Petraco R, et al. (2013). First-in-man safety evaluation of renal denervation for chronic systolic heart failure: primary outcome from REACH-Pilot study. Int J Cardiol.
146 Brandt MC, Mahfoud F, Reda S, et al. (2012). Renal sympathetic denervation reduces left ventricular hypertrophy and improves cardiac function in patients with resistant hypertension. J Am Coll Cardiol.
147 Lindmark S, Wiklund U, Bjerle P, et al. (2003). Does the autonomic nervous system play a role in the development of insulin resistance? A study on heart rate variability in first-degree relatives of Type 2 diabetes patients and control subjects. Diabet Med.
148 Carnethon MR, Golden SH, Folsom AR, et al. (2003). Prospective investigation of autonomic nervous system function and the development of type 2 diabetes: the Atherosclerosis Risk In Communities study, 1987-1998. Circulation.
149 Carnethon MR, Jacobs DR, Sidney S, et al. (2003). Influence of autonomic nervous system dysfunction on the development of type 2 diabetes: the CARDIA study. Diabetes Care.
150 Singh JP, Larson MG, O'Donnell CJ, et al. (2000). Association of hyperglycemia with reduced heart rate variability (The Framingham Heart Study). Am J Cardiol.
151 Mahfoud F, Schlaich M, Kindermann I, et al. (2011). Effect of renal sympathetic denervation on glucose metabolism in patients with resistant hypertension: a pilot study. Circulation.
152 Matous D, Jiravsky O, Nykl I, et al. (2015). Effect of renal denervation on glucose metabolism after a 12 month follow-up. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub.
153 Shantha GP, Pancholy SB. (2015). Effect of renal sympathetic denervation on apnea-hypopnea index in patients with obstructive sleep apnea: a systematic review and meta-analysis. Sleep Breath.
154 Witkowski A, Prejbisz A, Florczak E, et al. (2011). Effects of renal sympathetic denervation on blood pressure, sleep apnea course, and glycemic control in patients with resistant hypertension and sleep apnea. Hypertension.
155 Mahfoud F, Linz D, Mancia G, et al. (2015). 8B.04: RENAL ARTERY DENERVATION FOR TREATMENT OF HYPERTENSIVE PATIENTS WITH OR WITHOUT OBSTRUCTIVE SLEEP APNEA AND RESISTANT HYPERTENSION: RESULTS FROM THE GLOBAL SYMPLICITY REGISTRY. J Hypertens.
156 Sun D, Li C, Li M, et al. (2015). Renal Denervation vs Pharmacotherapy for Resistant Hypertension: A Meta-Analysis. J Clin Hypertens (Greenwich).
157 Fadl Elmula FE, Jin Y, Yang WY, et al. (2015). Meta-analysis of randomized controlled trials of renal denervation in treatment-resistant hypertension. Blood Press.
158 Kwok CS, Loke YK, Pradhan S, et al. (2014). Renal denervation and blood pressure reduction in resistant hypertension: a systematic review and meta-analysis. Open Heart.
159 Pancholy SB, Shantha GP, Patel TM, et al. (2014). Meta-analysis of the effect of renal denervation on blood pressure and pulse pressure in patients with resistant systemic hypertension. Am J Cardiol.
160 Davis MI, Filion KB, Zhang D, et al. (2013). Effectiveness of renal denervation therapy for resistant hypertension: a systematic review and meta-analysis. J Am Coll Cardiol.
161 Lobo MD, de Belder MA, Cleveland T, et al. (2015). Joint UK societies' 2014 consensus statement on renal denervation for resistant hypertension. Heart.
162 Lee JK, Grace KA, Foster TG, et al. (2007). How should we measure medication adherence in clinical trials and practice?. Ther Clin Risk Manag.