# Methods

We sought input from Key Informants in addition to searching for relevant studies.

## Discussion with Key Informants

We recruited eight Key Informants to give input on our approach to preparing the technical brief. Key Informants included stakeholders, representing clinical experts, investigators, government agencies, and patient/consumer advocates. As partners, Centers for Medicare and Medicaid Services (CMS) representatives were included among our Key Informants.

Prior to a conference call with the Key Informants, we drafted a narrative review to address KQs 1-3. We presented the draft narrative review on these KQs to the Key Informants, and asked them to comment on our interpretation of the prevailing views of experts and to point out any divergent viewpoints that should receive more attention.

For the systematic review of evidence on KQs 4-8, we asked the Key Informants to provide feedback on our strategy for preparing a summary of the evidence. The goal of this activity was to direct us to better perform the work in a systematic, yet efficient manner. We also prepared a flow diagram and list of included studies, and asked the Key Informants if they were aware of any studies we had missed.

## Search Strategy

We conducted searches for relevant studies using PubMed, and we also identified articles from investigators' existing resources, including recommendations by Key Informants and the experts on our team. The search strategy for PubMed is provided in Appendix A. We limited the search to the last 10 years because we did not feel studies published before 2006 were relevant. Indeed, the first reported use of the renal denervation technology in a person was not published until 2010.^13^ We updated the search in March 2016.

## Eligibility Criteria

Two reviewers independently reviewed titles, abstracts, and full-text articles. We excluded abstracts and full-text articles if both reviewers agreed that the study should be excluded. We resolved any differences regarding inclusion through consensus adjudication.

We developed final eligibility criteria based on Key Informant input and Task Order Officer (TOO) approval. We defined the eligibility criteria in terms of population, intervention, comparison, outcomes, timing, and study design, and these criteria were individualized to the questions (Table 1).

Table 1 Inclusion and exclusion criteria for renal denervation studies

| Inclusion | Exclusion
Population | - Studies of adults with resistant hypertension (on at least three medications and blood pressure > 140/90 mm Hg)
Intervention | - Studies that evaluate a non-surgical renal denervation device
Comparison | - Studies that compare renal denervation with either anti-hypertensive drugs or lifestyle changes; - Concurrent comparison groups and before/after comparisons
Outcomes | - Studies addressing at least one of the following outcomes:; ○ Office or ambulatory systolic blood pressure; ○ Number of blood pressure medications; ○ Mortality, CVD mortality, stroke, myocardial infarction, congestive heart failure, hospitalization; ○ Adverse events
Timing | - Studies of any followup duration
Study design | - Randomized controlled trials, comparative observational studies with at least 10 participants per arm, or non-comparative observational studies with less than 25 participants receiving renal denervation; - Clinical trials published only as meeting or conference abstracts if the meeting or conference was for a major medical society and was held within the last 2 years | - Case reports; - Studies with no original data; - Studies not published in English

CVD = cardiovascular disease; mm Hg = millimeters of mercury

## Data Abstraction and Management

We abstracted data on the items listed in Table 2. One reviewer abstracted the data and a senior reviewer checked it. The data abstraction forms are provided in Appendix B.

Table 2 Items for data abstraction

Population | - Age; - Gender; - Race/ethnicity; - Body mass index; - Kidney function; - Diabetes status; - Left ventricular hypertrophy; - Medication use (mean number of medications used and percent using a diuretic
Intervention | - Manufacturer and model of renal denervation device; - Individual who performed the procedure; - Type of training for procedure; - Whether up-titration of antihypertensive medications was allowed; - Percent of patients who did not receive their assigned treatment
Comparator | - Type of comparator, if any
Outcomes | - Change in office or ambulatory systolic blood pressure; - Change in number of blood pressure medications; - Rates of stroke, myocardial infarction, hospitalization, and mortality; - Adverse events
Timing | - Duration of run-in period; - Followup duration
Study design | - Study design, including whether or not there was a run-in period; - Inclusion/exclusion criteria, including the minimum number of antihypertensive medications, minimum blood pressure, and minimum duration of resistant hypertension.; - Number of patients screened versus the number enrolled
Setting | - Geographic location

## Quality Assessment

Two reviewers independently assessed study quality. We assessed the quality of RCTs using the Cochrane Risk of Bias tool.^14^ We assessed the quality of comparative observational studies only if the study was multi-centered, had a run-in period, included over 25 participants per arm, and if it measured ambulatory blood pressure. If a comparative observational study met these criteria, we used selective items from the Downs and Black tool.^15^ We did not assess the quality of the non-comparative studies because the lack of a comparison group equates to having a weak study design.

## Data Presentation

We used a narrative review to answer KQs 1-3, emphasizing the prevailing view on each question, while noting where different views existed.

We used a systematic approach to answer KQs 4-8. It included:

- Comparing the study eligibility criteria with the consensus definition of resistant hypertension, given that the inclusion criteria in observational studies and RCTs were variable;
- Examining and comparing results of the subgroup analyses by age in each of the trials;
- Summarizing any analyses of demographic or clinical characteristics associated with response to renal denervation;
- Addressing the same issues in trials of renal denervation that focused on patients with heart failure or arrhythmias; and
- Summarizing and comparing the data on adverse effects and complications in each of the trials.