# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- *Paula Einhorn, M.D., M.S.
  National Institutes of Health/National Heart, Lung, and Blood Institute
  Bethesda, MD
- John Flack, M.D., M.P.H.
  Southern Illinois University
  Springfield, IL
- *Lawrence Sadwin
  Patient Advocate
  Warren, RI
- Michelle Simmons
  Patient Advocate
  Baltimore, MD
- Raymond R. Townsend, M.D.
  University of Pennsylvania Medical Center
  Philadelphia, PA
- *Matthew R. Weir, M.D.
  University of Maryland School of Medicine
  Baltimore, MD

* This Key Informant member also provided review of the draft report.