# Acknowledgments

We would like to thank Dr. Clifford Weiss for reviewing sections of the report. We would like to thank Faye Rivkin for copy editing. We would also like to thank the Key Informants, the Peer Reviewers, the Task Order Officers, and the representatives from the Centers for Medicare and Medicaid Services.