# Discussion

## Summary of Study Findings

We conducted a systematic review of literature to assess the effectiveness of renal denervation for treatment of resistant hypertension in Medicare-eligible patients. We have abstracted data from available studies, and extrapolated from these studies to the Medicare-eligible population when possible.

We abstracted 83 studies (published in 98 articles) that included 7,660 patients. This is the most comprehensive review of this topic (Table 24). Of the 83 studies, 9 were RCTs, 8 were comparative cohorts, and 66 were non-comparative cohorts. The study populations studied are only partly comparable to the Medicare-eligible population. Since the causes of treatment resistant hypertension are multifactorial, excluding all other causes of resistance (and biases in measurement) before potential need for renal denervation is difficult. None of the abstracted studies match this optimal design as described in KQ 6.

Table 24 Summary of other systematic reviews of renal denervation devices

Author, Year | Objective | Population | Date of most recent search | Number of studies included | Findings | Risk of bias
Sun, 2015^156^ | To compare the effectiveness of RDN with pharmacotherapy to treat resistant hypertension | Patients with uncontrolled BP | NR | 9 studies (6 RCTs and 3 CTs) | RDN significantly reduced office systolic and diastolic BP compared with pharmacotherapy.^*^ Pooled results from the RCTS showed no significant decrease in systolic BP with RDN compared with pharmacotherapy. | High
Fadl Elmula, 2015^157^ | To evaluate the efficacy and safety of RDN in treatment-resistant hypertensive patients | Patients with treatment-resistant hypertension taking ≥3 drug classes | NR | 8 RCTs | RDN “modestly” decreased office systolic and diastolic BP compared with control. Rates of major adverse events were similar in the control and RDN groups. RDN did not change glomerular filtration rate. | High
Kwok, 2014^158^ | To evaluate the efficacy and safety of RDN in patients with resistant hypertension | Patients who underwent catheter-based RDN | April 2014 | 3 RCTs, 8 prospective observational studies, 1 study with matched control | The highest quality evidence suggests that RDN does not significantly reduce systolic and diastolic BP. However, lower quality evidence from non-blinded RCTs and observational studies suggests that there are significant reductions in BP with RDN. | Low
Pancholy, 2014^159^ | To compare the effect of RDN with pharmacotherapy on BP and PP after 6 months in patients with resistant hypertension | Patients with resistant, uncontrolled hypertension | April 28, 2014 | 3 RCTs, 3 CTs | Compared to pharmacotherapy, RDN significantly reduces BP. However, there is high heterogeneity and further research is needed. | Low
Shantha, 2015^153^ | To evaluate the effect of RDN on OSA severity in patients with OSA | Patients with OSA and hypertension and reported an apnea-hypopnea index 6 months post-RDN | January 5, 2014 | 5 prospective cohorts | Six months post RDN, patients reported significant improvement in the apnea-hypopnea index. There is also a significant reduction is office systolic BP and a non-significant reduction in office diastolic BP. | Low
Davis, 2013^160^ | To determine the current effectiveness and safety of sympathetic renal denervation for resistant hypertension. | Patients with resistant hypertension who underwent RDN. | December 1, 2012 | 2 RCTs, 1 observational study, 9 non-controlled observational studies | RDN significantly reduced BP 6 months after the procedure. | Low

BP = blood pressure; CT = controlled trial; NR = not reported; OSA = obstructive sleep apnea; PP = pulse pressure; RCT = randomized controlled trial; RDN = renal denervation

* Results are based on a flawed analysis, which included randomized controlled trials and non-randomized studies and did not have independent study samples.

In particular, adherence to diet and medications was not routinely assessed, and only 10 (12%) of all studies described a run-in period prior to randomization. We considered the key blood pressure metric that minimizes white coat effect, observer bias, and placebo effect to be the between-group difference in 24-hour ambulatory systolic blood pressure. This metric represents the difference in blood pressure change over time between the renal denervation group and the control group. The between-group difference in 24-hour ambulatory systolic blood pressure at 6 months was highly variable in six RCTs and two comparative cohorts, ranging from -20 mm Hg to -1.96 mm Hg. After excluding two comparative cohorts,^91, 92^ the between-group difference in 24-hour ambulatory systolic blood pressure change at 6 months in the RCTs, all of which used Medtronic's Symplicity device, ranged from -8 mm Hg to -0.5 mm Hg; the results were not statistically significant in all but one RCT. The within-group changes in office systolic blood pressure at 6 months with renal denervation, usually the primary outcome in reported studies, ranged from -42 mm Hg to 1.9 mm Hg in RCTs and comparative cohorts, and from -58.2 mm Hg to 12 mm Hg in non-comparative cohorts.

Unlike treatment with oral antihypertensive medications, the renal denervation procedure is invasive, and despite the carefully selected study populations, complications occurred, such as femoral artery pseudoaneurysm or hematoma, and renal artery stenosis or dissection requiring further interventions.

## Limitations of Evidence

Blood pressure change alone may be an imperfect surrogate for clinical outcomes; therefore, studies of clinical endpoints are needed. The renal denervation studies were not designed or powered to detect a long-term difference between groups in clinical endpoints such as stroke, myocardial infarction, hospitalization, or mortality, and few studies report these outcomes. The reports of benefits of renal denervation in other conditions, such as heart failure and arrhythmia, were limited to case reports and case series. Benefits of renal denervation by specific subgroups (age, gender, race/ethnicity), were seldom reported and inconsistent, and often did not specifically address the Medicare-eligible population.

We specifically evaluated the published studies for procedure characteristics, but details on the technique of the procedure and the training or experience of the interventionalist were not uniformly reported. Most studies reported short-term complications of the procedure, generally during 6 months of follow-up. Long-term sequelae of renal denervation or procedure-related complications are not known. The large variability in within-group changes in office systolic blood pressure with renal denervation is likely from white coat effect, observation bias, and placebo effect; the RCTs with a sham procedure and blinding minimized these biases and reported smaller changes in blood pressure. Other potential explanations of the disparity between observational studies and RCTs include heterogeneity of the “resistant hypertension” patient population and variable eligibility criteria.

Differences in denervation technique and completeness of the renal denervation procedure in ablating renal sympathetic nerves may also contribute to the differences between RCTs and observational studies. The learning curve and limited operator experience with first generation renal denervation technology could play a role in the variability in blood pressure response to treatment. However, the robust blood pressure drop in the early clinical trials was seen with use of first generation renal denervation devices with limited operator experience, suggesting that flaws in trial design, bias, or other factors (patient selection, medication adherence, etc.) may be more important than technique. Next generation renal denervation technology uses multi-polar catheters or alternative modalities of nerve ablation such as ultrasound or chemical-based denervation, and are in development or in the early trial phase. Coupled with technical factors, such as more targeted nerve ablation (distal renal arteries, branch vessel origins, circumferential, four quadrant), these issues may help to mitigate operator error and improve the completeness and efficacy of denervation, though this remains to be seen.

## Limitations of the Review Process

We limited our search to English language articles indexed by PubMed and may have missed relevant, non-English published literature. As our review was limited to published literature, it was therefore subject to publication or selective outcome reporting bias (i.e., where the authors do not publish negative results). We excluded studies with sample size less than 10, attempting to balance the risk of bias associated with including only large studies of this topic, with selective reporting of small studies. However, throughout the report, we try to focus on the studies that have the lowest risk of bias, such as RCTs, regardless of sample size. We also excluded studies where the study population overlapped a study population in other published trials. Finally, we limited our data abstraction to systolic blood pressure as systolic hypertension is the predominant form of hypertension in the Medicare-eligible population, aged 65 years or older.

## Future Research Needs

In this report, we focused on the use of renal denervation in patients with treatment resistant hypertension, which is a complicated multifactorial process and a highly heterogeneous clinical syndrome. Renal sympathetic system overactivity is likely one of the many contributors to uncontrolled blood pressure in such patients. At present, there are no techniques or biomarkers to identify individual patients with hypertension where renal sympathetic system activation is a key contributor to elevated blood pressure. Future research is needed in this area to allow selection of appropriate candidates for renal denervation. Such studies should carefully screen and exclude patients with secondary causes of hypertension.

Research is also needed to standardize renal denervation techniques and develop tests to assess adequacy of renal denervation while the procedure is being performed. As was noted by the Joint UK Societies in 2014 when it issued a consensus statement calling for a continued moratorium on routine use of renal denervation for resistant hypertension, there is much room for improvement in the design and conduct of research on the effectiveness of renal denervation for resistant hypertension.^161^ The well-known biases in blood pressure assessment (e.g., white coat effect, observer bias, and placebo effect) require that future studies of renal denervation efficacy should consider between-group differences in ambulatory blood pressure change as the primary metric of interest, rather than the convenient, but often inaccurate, office blood pressure measurements. Future trials should carefully monitor medication adherence using objective methods such as pill counts.^162^

The long-term consequences of the renal denervation procedures and of disrupting the renal sympathetic nervous system are unknown. Future research should ensure long-term followup of the patients undergoing renal denervation to assess for long-term procedure-related outcomes, unintended consequences of blood pressure lowering, as well as clinically valid endpoints such as stroke, myocardial infarction, and cardiovascular death. Furthermore, an RCT is needed that directly compares renal denervation with an antihypertensive medication strategy to reduce blood pressure and prevent long-term cardiovascular complications.

## Conclusions and Implications

Limited evidence suggests that renal denervation in patients with treatment resistant hypertension lowers systolic blood pressure, but the results were highly variable and the studies reviewed were not designed to determine improvement in clinical endpoints. The most rigorously conducted RCTs showed much smaller blood pressure reduction as compared with observational non-comparative studies. Further research is needed to identify optimal candidates for renal denervation, refine next generation renal denervation technology, develop methods for assessing completeness of renal denervation procedure, and demonstrate efficacy of renal denervation in reducing blood pressure and improving clinical endpoints including the risk of stroke, myocardial infarction, heart failure, and death in patients with hypertension.