# Background

## Introduction

Hypertension is the leading cause of cardiovascular disease, kidney failure, and death in the general population. In the United States, the prevalence of hypertension in adults was 29 percent in 2012.^1, 2^ Hypertension prevalence is even higher in the Medicare population, exceeding 60 percent for adults older than 65 years and over 90 percent for Medicare dialysis patients.^3, 4^ Evidence-based practice guidelines affirm that treatment of hypertension reduces the risks of cardiovascular disease and death, and multiple medications and lifestyle interventions can reduce blood pressure.^5-8^

Despite guidelines supporting blood pressure control, less than half of adults with hypertension reach goal blood pressure, as defined by the older guidelines (less than 140/90 mm Hg).^1^ Recently, the landmark Systolic Blood Pressure Intervention Trial (SPRINT) reported that targeting a systolic blood pressure of 120 mm Hg instead of 140 mm Hg reduced rates of cardiovascular events by almost a third and the risk of death by almost a quarter.^9^ If this lower blood pressure target is adopted by clinicians, an even greater proportion of adults with hypertension will be above the goal blood pressure, highlighting the importance of new methods for controlling blood pressure.

Failure to reach goal blood pressure despite “adequate” treatment is operationally defined as “apparent treatment resistant hypertension.”^10, 11^ This definition was developed to: a) identify patients with secondary causes of hypertension, such as pheochromocytoma, syndrome of apparent mineralocorticoid excess, or renal artery stenosis, that have specific medical or surgical treatments; b) identify patients with uncontrolled blood pressure that may benefit from specialized hypertension care; and c) provide a framework for testing therapies for resistant hypertension. Patients with apparent treatment resistant hypertension can include those with “pseudo-resistance” from dietary, lifestyle, and medication non-adherence, as well as those with “true resistance.” Data from 14,684 participants in the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT) suggest that irrespective of the mechanism, patients with apparent treatment resistant hypertension are at a 30 to 50 percent higher risk for death, stroke, or coronary heart disease, and almost a 2-fold higher risk of end-stage renal disease and new-onset heart failure compared with patients without apparent treatment resistant hypertension.^12^

In this context, innovative methods to reduce blood pressure may offer a way to improve cardiovascular outcomes and reduce the risk of myocardial infarction, stroke, heart failure, kidney failure, disability, and death. Renal denervation is a relatively new technology involving catheter-based radiofrequency (or sonar) ablation of renal sympathetic nerves to reduce blood pressure. Clinical trial data are conflicting about the efficacy of renal denervation in lowering blood pressure, with resulting uncertainty regarding its role in hypertensive patients.

Clarifying the role of renal denervation in routine care of Medicare beneficiaries requires an understanding of: a) the pathogenesis of hypertension in patients over the age of 65 years, disabled individuals, and those on dialysis; b) factors that contribute to apparent treatment resistant hypertension in these subgroups; c) other options for treatment; and d) a synthesis of the available studies.

## Guiding Questions

In this section we map the generic Guiding Questions (GQ) used in technical briefs prepared by the Evidence-based Practice Centers (EPCs) to the specific Key Questions (KQ) addressed in this technical brief.

GQ 1: Describe the Technology/Intervention

- KQ 1. What is the theoretical renal denervation mechanism of action?

GQ 2: Describe the Context in which the Technology/Intervention Is Used

- KQ 2. What is the evidence for blood pressure measurement and use as a surrogate outcome?
- KQ 3. What is the clinical definition of resistant hypertension, and what are the treatment alternatives?
- KQ 4. For randomized controlled trials (RCTs) and observational studies of renal denervation, what are the inclusion criteria for patients, and how do clinical characteristics match the clinical definition of resistant hypertension?

GQ 3: Describe the Current Evidence of the Technology/Intervention

- KQ 5. What are the predictors of response in Medicare eligible patients who are appropriate candidates for renal denervation?
- KQ 6. What is the evidence for renal denervation effectiveness in reducing blood pressure, stroke, myocardial infarction, and hospitalization and/or improving survival in Medicare eligible patients with resistant hypertension?
- KQ 7. What is the evidence for renal denervation effectiveness in other conditions such as heart failure and arrhythmias?
- KQ 8. What are the adverse effects or complications associated with renal denervation in the Medicare population?

GQ 4: Identify the Important Issues Raised by the Technology/Intervention