# Appendix F References

1 Azizi M, Sapoval M, Gosse P, et al. (2015). Optimum and stepped care standardised antihypertensive treatment with or without renal denervation for resistant hypertension (DENERHTN): a multicentre, open-label, randomised controlled trial. Lancet.
2 Bhatt DL, Kandzari DE, O'Neill WW, et al. (2014). A controlled trial of renal denervation for resistant hypertension. N Engl J Med.
3 Bohm M, Mahfoud F, Ukena C, et al. (2015). First report of the Global SYMPLICITY Registry on the effect of renal artery denervation in patients with uncontrolled hypertension. Hypertension.
4 Burchell AE, Chan K, Ratcliffe LE, et al. (2016). Controversies Surrounding Renal Denervation: Lessons Learned From Real-World Experience in Two United Kingdom Centers. J Clin Hypertens (Greenwich).
5 de Sousa Almeida M, de Araujo Goncalves P, Branco P, et al. (2016). Impact of Renal Sympathetic Denervation on Left Ventricular Structure and Function at 1-Year Follow-Up. PLoS One.
6 Desch S, Okon T, Heinemann D, et al. (2015). Randomized sham-controlled trial of renal sympathetic denervation in mild resistant hypertension. Hypertension.
7 Dorr O, Liebetrau C, Mollmann H, et al. (2013). Renal sympathetic denervation does not aggravate functional or structural renal damage. J Am Coll Cardiol.
8 Dorr O, Ewen S, Liebetrau C, et al. (2015). Neuropeptide Y as an indicator of successful alterations in sympathetic nervous activity after renal sympathetic denervation. Clin Res Cardiol.
9 Dorr O, Liebetrau C, Mollmann H, et al. (2015). Brain-derived neurotrophic factor as a marker for immediate assessment of the success of renal sympathetic denervation. J Am Coll Cardiol.
10 Dorr O, Liebetrau C, Mollmann H, et al. (2015). Beneficial effects of renal sympathetic denervation on cardiovascular inflammation and remodeling in essential hypertension. Clin Res Cardiol.
11 Eikelis N, Hering D, Marusic P, et al. (2015). The effect of renal denervation on endothelial function and inflammatory markers in patients with resistant hypertension. Int J Cardiol.
12 Ewen S, Mahfoud F, Linz D, et al. (2014). Effects of renal sympathetic denervation on exercise blood pressure, heart rate, and capacity in patients with resistant hypertension. Hypertension.
13 Ewen S, Meyer MR, Cremers B, et al. (2015). Blood pressure reductions following catheter-based renal denervation are not related to improvements in adherence to antihypertensive drugs measured by urine/plasma toxicological analysis. Clin Res Cardiol.
14 Ewen S, Ukena C, Linz D, et al. (2015). Reduced effect of percutaneous renal denervation on blood pressure in patients with isolated systolic hypertension. Hypertension.
15 Ewen S, Cremers B, Meyer MR, et al. (2015). Blood pressure changes after catheter-based renal denervation are related to reductions in total peripheral resistance. J Hypertens.
16 Ewen S, Dorr O, Ukena C, et al. (2015). Blood pressure variability after catheter-based renal sympathetic denervation in patients with resistant hypertension. J Hypertens.
17 Fadl Elmula FE, Hoffmann P, Larstorp AC, et al. (2014). Adjusted drug treatment is superior to renal sympathetic denervation in patients with true treatment-resistant hypertension. Hypertension.
18 Hameed MA, Pucci M, Martin U, et al. (2015). Renal Denervation in Patients With Uncontrolled Hypertension and Confirmed Adherence to Antihypertensive Medications. J Clin Hypertens (Greenwich).
19 Hamza M, Khamis H. (2014). Renal sympathetic denervation for treatment of resistant hypertension: Egyptian experience. J Interv Cardiol.
20 Hering D, Marusic P, Walton AS, et al. (2015). Renal artery anatomy affects the blood pressure response to renal denervation in patients with resistant hypertension. Int J Cardiol.
21 Honarvar M, Amirpour A, Pourmoghaddas M. (2013). Renal ablation for treatment of hypertension without Symplicity catheter: The first human experience. ARYA Atheroscler.
22 Id D, Bertog SC, Ziegler AK, et al. (2015). Predictors of Blood Pressure Response: Obesity Is Associated With a Less Pronounced Treatment Response After Renal Denervation. Catheter Cardiovasc Interv.
23 Kaiser L, Beister T, Wiese A, et al. (2014). Results of the ALSTER BP real-world registry on renal denervation employing the Symplicity system. EuroIntervention.
24 Kario K, Ogawa H, Okumura K, et al. (2015). SYMPLICITY HTN-Japan - First Randomized Controlled Trial of Catheter-Based Renal Denervation in Asian Patients. Circ J.
25 Kim BK, Böhm M, Mahfoud F, et al. (2015). Renal denervation for treatment of uncontrolled hypertension in an Asian population: results from the Global SYMPLICITY Registry in South Korea (GSR Korea). J Hum Hypertens.
26 Kiuchi MG, Chen S, Andrea BR, et al. (2014). Renal sympathetic denervation in patients with hypertension and chronic kidney disease: does improvement in renal function follow blood pressure control?. J Clin Hypertens (Greenwich).
27 Kiuchi MG, Chen S, Graciano ML, et al. (2015). Acute effect of renal sympathetic denervation on blood pressure in refractory hypertensive patients with chronic kidney disease. Int J Cardiol.
28 Kiuchi MG, Graciano ML, Carreira MA, et al. (2015). Long-Term Effects of Renal Sympathetic Denervation on Hypertensive Patients With Mild to Moderate Chronic Kidney Disease. J Clin Hypertens (Greenwich).
29 Krum H, Schlaich MP, Sobotka PA, et al. (2014). Percutaneous renal denervation in patients with treatment-resistant hypertension: final 3-year report of the Symplicity HTN-1 study. Lancet.
30 Kyvelou SM, Sharif F, Tuohy S, et al. (2013). Renal denervation: the Irish experience. Hellenic J Cardiol.
31 Lambert GW, Hering D, Esler MD, et al. (2012). Health-related quality of life after renal denervation in patients with treatment-resistant hypertension. Hypertension.
32 Lambert T, Blessberger H, Gammer V, et al. (2014). Effects of renal denervation on ambulatory blood pressure measurements in patients with resistant arterial hypertension. Clin Cardiol.
33 Lambert T, Nahler A, Reiter C, et al. (2015). Frequency of renal artery stenosis after renal denervation in patients with resistant arterial hypertension. Am J Cardiol.
34 Lambert T, Gammer V, Nahler A, et al. (2015). Individual-patient visit-by-visit office and ambulatory blood pressure measurements over 24months in patients undergoing renal denervation for hypertension. Int J Cardiol.
35 Lambert GW, Hering D, Marusic P, et al. (2015). Health-related quality of life and blood pressure 12 months after renal denervation. J Hypertens.
36 Lambert T, Nahler A, Reiter C, et al. (2015). Influence of pseudo-resistance on the effect of renal denervation on 24-hour ambulatory blood pressure levels. Catheter Cardiovasc Interv.
37 Lenski D, Kindermann I, Lenski M, et al. (2013). Anxiety, depression, quality of life and stress in patients with resistant hypertension before and after catheter-based renal sympathetic denervation. EuroIntervention.
38 Lenski M, Mahfoud F, Razouk A, et al. (2013). Orthostatic function after renal sympathetic denervation in patients with resistant hypertension. Int J Cardiol.
39 Lobo M, Saxena M, Jain AJ, et al. (2015). 4A.09: SAFETY AND PERFORMANCE OF THE ENLIGHTN RENAL DENERVATION SYSTEM IN PATIENTS WITH SEVERE UNCONTROLLED HYPERTENSION: 12 MONTH RESULTS FROM THE ENLIGHTN II STUDY. J Hypertens.
40 Ott C, Mahfoud F, Schmid A, et al. (2013). Renal denervation in moderate treatment-resistant hypertension. J Am Coll Cardiol.
41 Ott C, Mahfoud F, Schmid A, et al. (2014). Improvement of albuminuria after renal denervation. Int J Cardiol.
42 Ott C, Schmid A, Toennes SW, et al. (2015). Central pulse pressure predicts BP reduction after renal denervation in patients with treatment-resistant hypertension. EuroIntervention.
43 Ott C, Mahfoud F, Schmid A, et al. (2015). Renal denervation preserves renal function in patients with chronic kidney disease and resistant hypertension. J Hypertens.
44 Ott C, Harazny JM, Schmid A, et al. (2015). Retinal microperfusion after renal denervation in treatment-resistant hypertensive patients. Clin Res Cardiol.
45 Papademetriou V, Tsioufis CP, Sinhal A, et al. (2014). Catheter-based renal denervation for resistant hypertension: 12-month results of the EnligHTN I first-in-human study using a multielectrode ablation system. Hypertension.
46 Persu A, Azizi M, Jin Y, et al. (2014). Hyperresponders vs. nonresponder patients after renal denervation: do they differ?. J Hypertens.
47 Pokushalov E, Romanov A, Corbucci G, et al. (2012). A randomized comparison of pulmonary vein isolation with versus without concomitant renal artery denervation in patients with refractory symptomatic atrial fibrillation and resistant hypertension. J Am Coll Cardiol.
48 Poss J, Mahfoud F, Ukena C, et al. (2014). Association of vitamin D status and blood pressure response after renal denervation. Clin Res Cardiol.
49 Poss J, Ewen S, Schmieder RE, et al. (2015). Effects of renal sympathetic denervation on urinary sodium excretion in patients with resistant hypertension. Clin Res Cardiol.
50 Prochnau D, Figulla HR, Surber R. (2012). Efficacy of renal denervation with a standard EP catheter in the 24-h ambulatory blood pressure monitoring-long-term follow-up. Int J Cardiol.
51 Prochnau D, Heymel S, Gobel B, et al. (2013). Resistant hypertension: multivariate predictors of blood pressure response to renal denervation. Int J Cardiol.
52 Ripp TM, Mordovin VF, Pekarskiy SE, et al. (2015). Predictors of Renal Denervation Efficacy in the Treatment of Resistant Hypertension. Curr Hypertens Rep.
53 Rohla M, Nahler A, Lambert T, et al. (2016). Predictors of response to renal denervation for resistant arterial hypertension: a single center experience. J Hypertens.
54 Rosa J, Widimsky P, Tousek P, et al. (2015). Randomized comparison of renal denervation versus intensified pharmacotherapy including spironolactone in true-resistant hypertension: six-month results from the Prague-15 study. Hypertension.
55 Scheurig-Muenkler C, Weiss W, Foert E, et al. (2013). Renal denervation for refractory hypertension - technical aspects, complications and radiation exposure. Rofo.
56 Schmid A, Ditting T, Sobotka PA, et al. (2013). Does renal artery supply indicate treatment success of renal denervation?. Cardiovasc Intervent Radiol.
57 Schmid A, Schmieder R, Lell M, et al. (2015). Mid-Term Vascular Safety of Renal Denervation Assessed by Follow-up MR Imaging. Cardiovasc Intervent Radiol.
58 Schneider S, Promny D, Sinnecker D, et al. (2015). Impact of sympathetic renal denervation: a randomized study in patients after renal transplantation (ISAR-denerve). Nephrol Dial Transplant.
59 Schwerg M, Heupel C, Strajnic D, et al. (2014). Renal sympathetic denervation: early impact on ambulatory resistant hypertension. J Clin Hypertens (Greenwich).
60 Sharp A, Hameed A, Nightingale A, et al. (2015). 8B.07: RESULTS FROM THE UK RENAL DENERVATION AFFILIATION-246 CASES FROM 17 CENTRES. J Hypertens.
61 Sharp AS, Davies JE, Lobo MD, et al. (2016). Renal artery sympathetic denervation: observations from the UK experience. Clin Res Cardiol.
62 Sievert H, Schofer J, Ormiston J, et al. (2015). Renal denervation with a percutaneous bipolar radiofrequency balloon catheter in patients with resistant hypertension: 6-month results from the REDUCE-HTN clinical study. EuroIntervention.
63 Symplicity HTNI, Esler MD, Krum H, et al. (2010). Renal sympathetic denervation in patients with treatment-resistant hypertension (The Symplicity HTN-2 Trial): a randomised controlled trial. Lancet.
64 Symplicity HTNI. (2011). Catheter-based renal sympathetic denervation for resistant hypertension: durability of blood pressure reduction out to 24 months. Hypertension.
65 Tiroch K, Sause A, Szymanski J, et al. (2015). Intraprocedural reduction of the veno-arterial norepinephrine gradient correlates with blood pressure response after renal denervation. EuroIntervention.
66 Tsioufis C, Papademetriou V, Tsiachris D, et al. (2015). Impact of multi-electrode renal sympathetic denervation on short-term blood pressure variability in patients with drug-resistant hypertension. Insights from the EnligHTN I study. Int J Cardiol.
67 Tsioufis CP, Papademetriou V, Dimitriadis KS, et al. (2015). Catheter-based renal denervation for resistant hypertension: Twenty-four month results of the EnligHTN I first-in-human study using a multi-electrode ablation system. Int J Cardiol.
68 Tsioufis C, Papademetriou V, Dimitriadis K, et al. (2015). Effects of multielectrode renal denervation on cardiac and neurohumoral adaptations in resistant hypertension with cardiac hypertrophy: an EnligHTN I substudy. J Hypertens.
69 Tsioufis C, Papademetriou V, Dimitriadis K, et al. (2015). 4A.03: CATHETER-BASED RENAL DENERVATION FOR RESISTANT HYPERTENSION: 24 MONTH RESULTS OF THE ENLIGHTN I STUDY USING A MULTIELECTRODE ABLATION SYSTEM. J Hypertens.
70 van Brüssel PM, Eeftinck Schattenkerk DW, Dobrowolski LC, et al. (2015). Effects of renal sympathetic denervation on cardiac sympathetic activity and function in patients with therapy resistant hypertension. Int J Cardiol.
71 Verheye S, Ormiston J, Bergmann MW, et al. (2015). Twelve-month results of the rapid renal sympathetic denervation for resistant hypertension using the OneShotTM ablation system (RAPID) study. EuroIntervention.
72 Verloop WL, Vink EE, Spiering W, et al. (2014). Renal denervation in multiple renal arteries. Eur J Clin Invest.
73 Verloop WL, Spiering W, Vink EE, et al. (2015). Denervation of the renal arteries in metabolic syndrome: the DREAMS-study. Hypertension.
74 Verloop WL, Vink EE, Spiering W, et al. (2015). Effects of renal denervation on end organ damage in hypertensive patients. Eur J Prev Cardiol.
75 Vink EE, Verloop WL, Bost RB, et al. (2014). The blood pressure-lowering effect of renal denervation is inversely related to kidney function. J Hypertens.
76 Vink EE, Boer A, Verloop WL, et al. (2015). The effect of renal denervation on kidney oxygenation as determined by BOLD MRI in patients with hypertension. Eur Radiol.
77 Vogel B, Kirchberger M, Zeier M, et al. (2014). Renal sympathetic denervation therapy in the real world: results from the Heidelberg registry. Clin Res Cardiol.
78 Volz S, Andersson B, Manhem K, et al. (2014). Effect of catheter-based renal sympathetic denervation on 24-h ambulatory blood pressure in patients with resistant hypertension. Blood Press.
79 Whitbourn R, Harding SA, Walton A. (2015). Symplicity multi-electrode radiofrequency renal denervation system feasibility study. EuroIntervention.
80 Worthley SG, Tsioufis CP, Worthley MI, et al. (2013). Safety and efficacy of a multi-electrode renal sympathetic denervation system in resistant hypertension: the EnligHTN I trial. Eur Heart J.
81 Worthley S, Kataoka Y, Nicholls S, et al. (2015). 8B.03: ATHEROMA PROGRESSION IN RENAL ARTERIES AFTER CATHETER-BASED RENAL ARTERY DENERVATION USING SERIAL VOLUMETRIC COMPUTED TOMOGRAPHY ANALYSIS: ANALYSIS FROM THE ENLIGHTN 1 TRIAL. J Hypertens.
82 Zhang ZH, Yang K, Jiang FL, et al. (2014). The effects of catheter-based radiofrequency renal denervation on renal function and renal artery structure in patients with resistant hypertension. J Clin Hypertens (Greenwich).
83 Zuern CS, Eick C, Rizas KD, et al. (2013). Impaired cardiac baroreflex sensitivity predicts response to renal sympathetic denervation in patients with resistant hypertension. J Am Coll Cardiol.