# Appendix E Evidence Tables

Table 1 Characteristics of studies evaluating renal denervation devices

Table 2 Population characteristics of studies evaluating renal denervation devices

Table 3 Intervention characteristics

Table 4 Results of controlled studies evaluating blood pressure outcomes

Table 5 Results of controlled studies evaluating clinical outcomes

Table 6 Results of controlled studies evaluating adverse events

Table 7 Results of non-controlled studies evaluating blood pressure outcomes

Table 8 Results of non-controlled studies evaluating clinical outcomes

Table 9 Results of non-controlled studies evaluating adverse events

Table 10 Study quality of randomized controlled trials evaluating renal denervation devices