# Appendix D Studies Excluded for Overlapping Populations

Bartus K, Sadowski J, Kapelak B, et al. (2013). Denervation (ablation) of nerve terminalis in renal arteries: early results of interventional treatment of arterial hypertension in Poland. Kardiol Pol.
Bartus K, Sadowski J, Kapelak B, et al. (2014). Denervation of nerve terminals in renal arteries: one-year follow-up of interventional treatment of arterial hypertension. Kardiol Pol.
Brandt MC, Mahfoud F, Reda S, et al. (2012). Renal sympathetic denervation reduces left ventricular hypertrophy and improves cardiac function in patients with resistant hypertension. J Am Coll Cardiol.
Brandt MC, Reda S, Mahfoud F, et al. (2012). Effects of renal sympathetic denervation on arterial stiffness and central hemodynamics in patients with resistant hypertension. J Am Coll Cardiol.
Hering D, Lambert EA, Marusic P, et al. (2013). Renal nerve ablation reduces augmentation index in patients with resistant hypertension. J Hypertens.
Hering D, Marusic P, Walton AS, et al. (2014). Sustained sympathetic and blood pressure reduction 1 year after renal denervation in patients with resistant hypertension. Hypertension.
Id D, Kaltenbach B, Bertog SC, et al. (2013). Does the presence of accessory renal arteries affect the efficacy of renal denervation?. JACC Cardiovasc Interv.
Karanasos A, Van Mieghem N, Bergmann MW, et al. (2015). Multimodality Intra-Arterial Imaging Assessment of the Vascular Trauma Induced by Balloon-Based and Nonballoon-Based Renal Denervation Systems. Circ Cardiovasc Interv.
Krum H, Schlaich M, Whitbourn R, et al. (2009). Catheter-based renal sympathetic denervation for resistant hypertension: a multicentre safety and proof-of-principle cohort study. Lancet.
Mahfoud F, Cremers B, Janker J, et al. (2012). Renal hemodynamics and renal function after catheter-based renal sympathetic denervation in patients with resistant hypertension. Hypertension.
Mahfoud F, Schlaich M, Kindermann I, et al. (2011). Effect of renal sympathetic denervation on glucose metabolism in patients with resistant hypertension: a pilot study. Circulation.
Mahfoud F, Ukena C, Schmieder RE, et al. (2013). Ambulatory blood pressure changes after renal sympathetic denervation in patients with resistant hypertension. Circulation.
Mahfoud F, Urban D, Teller D, et al. (2014). Effect of renal denervation on left ventricular mass and function in patients with resistant hypertension: data from a multi-centre cardiovascular magnetic resonance imaging trial. Eur Heart J.
Schirmer SH, Sayed MM, Reil JC, et al. (2015). Atrial Remodeling Following Catheter-Based Renal Denervation Occurs in a Blood Pressure- and Heart Rate-Independent Manner. JACC Cardiovasc Interv.
Schirmer SH, Sayed MM, Reil JC, et al. (2014). Improvements in left ventricular hypertrophy and diastolic function following renal denervation: effects beyond blood pressure and heart rate reduction. J Am Coll Cardiol.
Ukena C, Mahfoud F, Spies A, et al. (2013). Effects of renal sympathetic denervation on heart rate and atrioventricular conduction in patients with resistant hypertension. Int J Cardiol.