# Appendix C List of Excluded Studies

(2012). Renal sympathetic denervation for hypertension. Med Lett Drugs Ther.
Ahmed H, Neuzil P, Skoda J, et al. (2012). Renal sympathetic denervation using an irrigated radiofrequency ablation catheter for the management of drug-resistant hypertension. JACC Cardiovasc Interv.
Armaganijan L, Staico R, Abizaid A, et al. (2013). Unilateral renal artery sympathetic denervation may reduce blood pressure in patients with resistant hypertension. J Clin Hypertens (Greenwich).
Armaganijan L, Staico R, Moraes A, et al. (2014). Renal denervation using an irrigated catheter in patients with resistant hypertension: a promising strategy?. Arq Bras Cardiol.
Baroni M, Nava S, Giupponi L, et al. (2015). Effects of Renal Sympathetic Denervation on Arterial Stiffness and Blood Pressure Control in Resistant Hypertensive Patients: A Single Centre Prospective Study. High Blood Press Cardiovasc Prev.
Bartus K, Sadowski J, Kapelak B, et al. (2013). Denervation (ablation) of nerve terminalis in renal arteries: early results of interventional treatment of arterial hypertension in Poland. Kardiol Pol.
Bartus K, Sadowski J, Kapelak B, et al. (2014). Denervation of nerve terminals in renal arteries: one-year follow-up of interventional treatment of arterial hypertension. Kardiol Pol.
Bausback Y, Friedenberger J, Hertting K, et al. (2014). Renal denervation for hypertension refractory to renal artery stenting. J Endovasc Ther.
Benamer H, Mylotte D, Garcia-Alonso C, et al. (2013). Ann Cardiol Angeiol (Paris).
Berukstis A, Vajauskas D, Gargalskaite U, et al. (2016). Impact of renal sympathetic denervation on cardiac sympathetic nerve activity evaluated by cardiac MIBG imaging. EuroIntervention.
Bilge M, Tolunay H, Kurmus O, et al. (2012). Percutaneous renal denervation in patients with resistant hypertension-first experiences in Turkey. Anadolu Kardiyol Derg.
Bortolotto LA, Midlej-Brito T, Pisani C, et al. (2013). Renal denervation by ablation with innovative technique in resistant hypertension. Arq Bras Cardiol.
Brandt MC, Mahfoud F, Reda S, et al. (2012). Renal sympathetic denervation reduces left ventricular hypertrophy and improves cardiac function in patients with resistant hypertension. J Am Coll Cardiol.
Brandt MC, Reda S, Mahfoud F, et al. (2012). Effects of renal sympathetic denervation on arterial stiffness and central hemodynamics in patients with resistant hypertension. J Am Coll Cardiol.
Brinkmann J, Heusser K, Schmidt BM, et al. (2012). Catheter-based renal nerve ablation and centrally generated sympathetic activity in difficult-to-control hypertensive patients: prospective case series. Hypertension.
Ciardetti M, Coceani M, Pastormerlo LE, et al. (2015). Renal denervation in resistant arterial hypertension: Effects on neurohormonal activation and cardiac natriuretic peptides. Int J Cardiol.
Courand PY, Dauphin R, Rouviere O, et al. (2014). Ann Cardiol Angeiol (Paris).
Damascelli B, Patelli G, Ticha V, et al. (2013). Catheter-based radiofrequency renal sympathetic denervation for resistant hypertension. J Vasc Interv Radiol.
de Jager RL, Blankestijn PJ. (2013). Pathophysiology I: the kidney and the sympathetic nervous system. EuroIntervention.
Denolle T, Chamontin B, Doll G, et al. (2014). Presse Med.
Diego-Nieto A, Cruz-Gonzalez I, Martin-Moreiras J, et al. (2015). Severe Renal Artery Stenosis After Renal Sympathetic Denervation. JACC Cardiovasc Interv.
Dobrowolski L, Schattenkerk DE, Krediet C, et al. (2015). 4A.08: ASSESSING MODULATIONS IN SYMPATHETIC NERVE ACTIVITY AFTER RENAL SYMPATHETIC DENERVATION USING RENAL 123I-MIBG SCINTIGRAPHY. J Hypertens.
Doltra A, Messroghli D, Stawowy P, et al. (2014). Potential reduction of interstitial myocardial fibrosis with renal denervation. J Am Heart Assoc.
Donazzan L, Mahfoud F, Ewen S, et al. (2015). Effects of catheter-based renal denervation on cardiac sympathetic activity and innervation in patients with resistant hypertension. Clin Res Cardiol.
Donazzan L, Mahfoud F, Schirmer SH, et al. (2015). Renal nerve ablation. Heart.
Dong H, Jiang X, Liang T, et al. (2014). One-year outcomes of percutaneous renal denervation for the treatment of resistant hypertension: the first Chinese experience. Chin Med J (Engl).
Dores H, de Sousa Almeida M, de Araujo Goncalves P, et al. (2014). Renal denervation in patients with resistant hypertension: six-month results. Rev Port Cardiol.
Ewen S, Ukena C, Linz D, et al. (2013). The sympathetic nervous system in chronic kidney disease. Curr Hypertens Rep.
Ezzahti M, Moelker A, Friesema EC, et al. (2014). Blood pressure and neurohormonal responses to renal nerve ablation in treatment-resistant hypertension. J Hypertens.
Fadl Elmula FE, Hoffmann P, Fossum E, et al. (2013). Renal sympathetic denervation in patients with treatment-resistant hypertension after witnessed intake of medication before qualifying ambulatory blood pressure. Hypertension.
Fischell TA, Fischell DR, Ghazarossian VE, et al. (2015). Next generation renal denervation: chemical “perivascular” renal denervation with alcohol using a novel drug infusion catheter. Cardiovasc Revasc Med.
Fontenla A, Garcia-Donaire JA, Hernandez F, et al. (2013). Management of resistant hypertension in a multidisciplinary unit of renal denervation: protocol and results. Rev Esp Cardiol (Engl Ed).
Ghadri JR, Gaehwiler R, Jaguszewski M, et al. (2015). Impact of local vascular lesions assessed with optical coherence tomography and ablation points on blood pressure reduction after renal denervation. Swiss Med Wkly.
Grassi G, Seravalle G, Brambilla G, et al. (2015). Blood pressure responses to renal denervation precede and are independent of the sympathetic and baroreflex effects. Hypertension.
Grassi G, Seravalle G, Trevano FQ, et al. (2015). Asymmetric and Symmetric Dimethylarginine and Sympathetic Nerve Traffic after Renal Denervation in Patients with Resistant Hypertension. Clin J Am Soc Nephrol.
Hayek SS, Abdou MH, Demoss BD, et al. (2013). Prevalence of resistant hypertension and eligibility for catheter-based renal denervation in hypertensive outpatients. Am J Hypertens.
Hering D, Lambert EA, Marusic P, et al. (2013). Renal nerve ablation reduces augmentation index in patients with resistant hypertension. J Hypertens.
Hering D, Mahfoud F, Walton AS, et al. (2012). Renal denervation in moderate to severe CKD. J Am Soc Nephrol.
Hering D, Marusic P, Walton AS, et al. (2014). Sustained sympathetic and blood pressure reduction 1 year after renal denervation in patients with resistant hypertension. Hypertension.
Heusser H, Tank J, Brinkmann J, et al. (2013). Response to catheter-based renal nerve ablation and centrally generated sympathetic activity in difficult-to- control hypertensive patients. Hypertension.
Heusser K, Tank J, Brinkmann J, et al. (2013). Response to blood pressure and sympathetic nervous system response to renal denervation. Hypertension.
Id D, Kaltenbach B, Bertog SC, et al. (2013). Does the presence of accessory renal arteries affect the efficacy of renal denervation?. JACC Cardiovasc Interv.
Ierna S, Biondi-Zoccai G, Bachis C, et al. (2013). Transcatheter renal sympathetic ablation for resistant hypertension: in vivo insights in humans from optical coherence tomography. Int J Cardiol.
Jin Y, Jacobs L, Baelen M, et al. (2014). Rationale and design of the Investigator-Steered Project on Intravascular Renal Denervation for Management of Drug-Resistant Hypertension (INSPiRED) trial. Blood Press.
Johns EJ, Abdulla MH. (2013). Renal nerves in blood pressure regulation. Curr Opin Nephrol Hypertens.
Johns EJ. (2013). Autonomic regulation of kidney function. Handb Clin Neurol.
Johns EJ. (2014). The neural regulation of the kidney in hypertension and renal failure. Exp Physiol.
Jordan J, Heusser K, Brinkmann J, et al. (2013). Response to catheter-based renal nerve ablation and centrally generated sympathetic activity in difficult-to- control hypertensive patients: prospective case series. Hypertension.
Judd E, Calhoun DA. (2014). Apparent and true resistant hypertension: definition, prevalence and outcomes. J Hum Hypertens.
Kaczmarek K, Ptaszynski P, Krekora J, et al. (2013). An electrophysiological approach using 3D electroanatomical mapping system for catheter-based renal denervation: the first Polish experience. Kardiol Pol.
Kaltenbach B, Franke J, Bertog SC, et al. (2013). Renal sympathetic denervation as second-line therapy in mild resistant hypertension: a pilot study. Catheter Cardiovasc Interv.
Kaltenbach B, Id D, Franke JC, et al. (2012). Renal artery stenosis after renal sympathetic denervation. J Am Coll Cardiol.
Karanasos A, Van Mieghem N, Bergmann MW, et al. (2015). Multimodality Intra-Arterial Imaging Assessment of the Vascular Trauma Induced by Balloon-Based and Nonballoon-Based Renal Denervation Systems. Circ Cardiovasc Interv.
Kario K, Bakris GL, Bhatt D. (2015). 4A. 10: PREFERENTIAL REDUCTION IN MORNING/NOCTURNAL HYPERTENSION BY RENAL DENERVATION FOR DRUG-RESISTANT HYPERTENSION: A NEW ABPM ANALYSIS OF SYMPLICITY HTN-3 AND HTN-JAPAN. J Hypertens.
Kario K, Bhatt DL, Brar S, et al. (2015). Effect of Catheter-Based Renal Denervation on Morning and Nocturnal Blood Pressure: Insights From SYMPLICITY HTN-3 and SYMPLICITY HTN-Japan. Hypertension.
Kario K, Ikemoto T, Kuwabara M, et al. (2015). Catheter-Based Renal Denervation Reduces Hypoxia-Triggered Nocturnal Blood Pressure Peak in Obstructive Sleep Apnea Syndrome. J Clin Hypertens (Greenwich).
Kiuchi MG, Graciano ML, de Queiroz Carreira MA, et al. (2015). Effects of renal sympathetic denervation in left ventricular hypertrophy in CKD refractory hypertensive patients. Int J Cardiol.
Kiuchi MG, Maia GL, de Queiroz Carreira MA, et al. (2013). Effects of renal denervation with a standard irrigated cardiac ablation catheter on blood pressure and renal function in patients with chronic kidney disease and resistant hypertension. Eur Heart J.
Kiuchi MG, Mion D, Graciano ML, et al. (2016). Proof of concept study: Improvement of echocardiographic parameters after renal sympathetic denervation in CKD refractory hypertensive patients. Int J Cardiol.
Korovesis S, Giazitzoglou E, Pantos I, et al. (2014). Renal denervation for resistant hypertension: acute results and long-term follow-up. Hellenic J Cardiol.
Krum H, Schlaich M, Whitbourn R, et al. (2009). Catheter-based renal sympathetic denervation for resistant hypertension: a multicentre safety and proof-of-principle cohort study. Lancet.
Kucherov VV, Fursov AN, Chernetsov VA, et al. (2014). Klin Med (Mosk).
Lambert GW, Dhar AK, Schlaich MP. (2013). Cognitive performance in patients with resistant hypertension following renal sympathetic denervation. EuroIntervention.
Lepor NE, Karns A. (2013). Hypertension. Left ventricular hypertrophy and cardiac function in patients with resistant hypertension. Rev Cardiovasc Med.
Lobo MD, de Belder MA, Cleveland T, et al. (2015). Joint UK societies' 2014 consensus statement on renal denervation for resistant hypertension. Heart.
Lu Y, Zhang L, Zhou X, et al. (2015). Renal sympathetic denervation: A potential alternative strategy for managing patients with heart failure. Int J Cardiol.
Luetkens JA, Wilhelm K, Dusing R, et al. (2015). Renal denervation: results of a single-center cohort study. Rofo.
Luo D, Zhang X, Lu CZ. (2013). Renal sympathetic denervation for the treatment of resistant hypertension with chronic renal failure: first-in-man experience. Chin Med J (Engl).
Mabin T, Sapoval M, Cabane V, et al. (2012). First experience with endovascular ultrasound renal denervation for the treatment of resistant hypertension. EuroIntervention.
Mahfoud F, Böhm M, Rump LC, et al. (2013). Catheter-based renal nerve ablation and centrally generated sympathetic activity in difficult-to-control hypertensive patients: prospective case series. Hypertension.
Mahfoud F, Cremers B, Janker J, et al. (2012). Renal hemodynamics and renal function after catheter-based renal sympathetic denervation in patients with resistant hypertension. Hypertension.
Mahfoud F, Schlaich M, Kindermann I, et al. (2011). Effect of renal sympathetic denervation on glucose metabolism in patients with resistant hypertension: a pilot study. Circulation.
Mahfoud F, Ukena C, Schmieder RE, et al. (2013). Ambulatory blood pressure changes after renal sympathetic denervation in patients with resistant hypertension. Circulation.
Mahfoud F, Urban D, Teller D, et al. (2014). Effect of renal denervation on left ventricular mass and function in patients with resistant hypertension: data from a multi-centre cardiovascular magnetic resonance imaging trial. Eur Heart J.
Manakshe G, Chakravarthi R, Hussaini S, et al. (2013). Renal sympathetic denervation for treatment of resistant hypertension -indigenous technique. Indian Heart J.
Matous D, Jiravsky O, Nykl I, et al. (2015). Effect of renal denervation on glucose metabolism after a 12 month follow-up. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub.
McArdle MJ, deGoma EM, Cohen DL, et al. (2015). Beyond blood pressure: percutaneous renal denervation for the management of sympathetic hyperactivity and associated disease states. J Am Heart Assoc.
McLellan AJ, Schlaich MP, Taylor AJ, et al. (2015). Reverse cardiac remodeling after renal denervation: Atrial electrophysiologic and structural changes associated with blood pressure lowering. Heart Rhythm.
Middlekauff HR. (2015). A mechanistic explanation for the minimal impact of renal denervation on 24-h ambulatory blood pressure in SIMPLICITY HTN-3. J Am Coll Cardiol.
Miller MA, Gangireddy SR, Dukkipati SR, et al. (2014). Renal sympathetic denervation using an electroanatomic mapping system. J Am Coll Cardiol.
Miroslawska A, Solbu M, Skjolsvik E, et al. (2016). Renal sympathetic denervation: effect on ambulatory blood pressure and blood pressure variability in patients with treatment-resistant hypertension. The ReShape CV-risk study. J Hum Hypertens.
Mortensen K, Franzen K, Himmel F, et al. (2012). Catheter-based renal sympathetic denervation improves central hemodynamics and arterial stiffness: a pilot study. J Clin Hypertens (Greenwich).
Murai H, Okuyama Y, Sakata Y, et al. (2015). Different responses of arterial blood pressure to electrical stimulation of the renal artery in patients with resistant hypertension. Int J Cardiol.
Olsen LK, Kamper AL, Svendsen JH, et al. (2014). High incidence of secondary hypertension in patients referred for renal denervation--the Copenhagen experience. Blood Press.
Ong PJ, Foo D, Ho HH. (2012). Successful treatment of resistant hypertension with percutaneous renal denervation therapy. Heart.
Oparil S. (2011). Can catheter-based renal denervation be used safely and effectively to substantially reduce blood pressure in treatment-resistant hypertensive patients?. Curr Cardiol Rep.
Ott C, Janka R, Schmid A, et al. (2013). Vascular and renal hemodynamic changes after renal denervation. Clin J Am Soc Nephrol.
Patane S. (2015). Sympathetic and Autonomic Effects of Renal Denervation on Atrial Remodeling and Atrial Arrhythmias. JACC Cardiovasc Interv.
Persu A, Durand-Zaleski I, Renkin J, et al. (2013). Quality of life after renal denervation. Hypertension.
Persu A, Jin Y, Azizi M, et al. (2014). Blood pressure changes after renal denervation at 10 European expert centers. J Hum Hypertens.
Persu A, Renkin J, Thijs L, et al. (2012). Renal denervation: ultima ratio or standard in treatment-resistant hypertension. Hypertension.
Prochnau D, Heymel S, Otto S, et al. (2014). Renal denervation with cryoenergy as second-line option is effective in the treatment of resistant hypertension in non-responders to radiofrequency ablation. EuroIntervention.
Prochnau D, Lucas N, Kuehnert H, et al. (2012). Catheter-based renal denervation for drug-resistant hypertension by using a standard electrophysiology catheter. EuroIntervention.
Qiu M, Shan Q, Chen C, et al. (2016). Renal sympathetic denervation improves rate control in patients with symptomatic persistent atrial fibrillation and hypertension. Acta Cardiol.
Ricke J, Seidensticker M, Becker S, et al. (2016). Renal Sympathetic Denervation by CT-Guided Ethanol Injection: A Phase II Pilot Trial of a Novel Technique. Cardiovasc Intervent Radiol.
Rimoldi SF, Scheidegger N, Scherrer U, et al. (2014). Anatomical eligibility of the renal vasculature for catheter-based renal denervation in hypertensive patients. JACC Cardiovasc Interv.
Roleder T, Skowerski M, Wiecek A, et al. (2016). Long-term follow-up of renal arteries after radio-frequency catheter-based denervation using optical coherence tomography and angiography. Int J Cardiovasc Imaging.
Rong S, Zhu H, Liu D, et al. (2015). Noninvasive Renal Denervation for Resistant Hypertension Using High-Intensity Focused Ultrasound. Hypertension.
Rosa J, Zelinka T, Petrak O, et al. (2014). Importance of thorough investigation of resistant hypertension before renal denervation: should compliance to treatment be evaluated systematically?. J Hum Hypertens.
Rundqvist B, Volz S, Manhem K, et al. (2013). Lakartidningen.
Sanders MF, Blankestijn PJ, Voskuil M, et al. (2016). Safety and long-term effects of renal denervation: Rationale and design of the Dutch registry. Neth J Med.
Savard S, Frank M, Bobrie G, et al. (2012). Eligibility for renal denervation in patients with resistant hypertension: when enthusiasm meets reality in real-life patients. J Am Coll Cardiol.
Scherlag MA, Scherlag BJ. (2013). A randomized comparison of pulmonary vein isolation with versus without concomitant renal artery denervation in patients with refractory symptomatic atrial fibrillation and resistant hypertension. J Am Coll Cardiol.
Schirmer SH, Sayed MM, Reil JC, et al. (2015). Atrial Remodeling Following Catheter-Based Renal Denervation Occurs in a Blood Pressure- and Heart Rate-Independent Manner. JACC Cardiovasc Interv.
Schirmer SH, Sayed MM, Reil JC, et al. (2014). Improvements in left ventricular hypertrophy and diastolic function following renal denervation: effects beyond blood pressure and heart rate reduction. J Am Coll Cardiol.
Schlaich M, Hering D, Lambert G, et al. (2013). Blood pressure and sympathetic nervous system response to renal denervation. Hypertension.
Schlaich MP, Bart B, Hering D, et al. (2013). Feasibility of catheter-based renal nerve ablation and effects on sympathetic nerve activity and blood pressure in patients with end-stage renal disease. Int J Cardiol.
Schmieder RE, Ott C, Schmid A, et al. (2016). Adherence to Antihypertensive Medication in Treatment-Resistant Hypertension Undergoing Renal Denervation. J Am Heart Assoc.
Schmieder RE, Ott C, Veelken R, et al. (2015). 7B.01: FINAL ANALYSIS ON ADHERENCE TO ANTIHYPERTENSIVE MEDICATION IN TREATMENT RESISTANT HYPERTENSION (TRH) UNDERGOING RENAL DENERVATION (RDN). J Hypertens.
Seravalle G, Dell'Oro R, Trevano FQ, et al. (2015). 4A.04: EFFECTS OF RENAL DENERVATION ON ASYMMETRIC DIMETHYLARGININE AND SYMPATHETIC NERVE TRAFFIC IN RESISTANT HYPERTENSIVE PATIENTS. J Hypertens.
Sridhar GS, Watson T, Han CK, et al. (2015). Profound Sustained Hypotension Following Renal Denervation: A Dramatic Success?. Arq Bras Cardiol.
Stabile E, Ambrosini V, Squarcia R, et al. (2013). Percutaneous sympathectomy of the renal arteries: the OneShot Renal Denervation System is not associated with significant vessel wall injury. EuroIntervention.
Staessen JA, Jin Y, Thijs L, et al. (2013). First-in-man randomized clinical trial of renal denervation for atrial arrhythmia raises concern. J Am Coll Cardiol.
Tank J, Heusser K, Brinkmann J, et al. (2015). Spike rate of multi-unit muscle sympathetic nerve fibers after catheter-based renal nerve ablation. J Am Soc Hypertens.
Taylor J. (2013). CardioPulse: ESC recommends patients and centres for renal denervation: recommendations on catheter-based renal denervation for treatment resistant hypertension should guide reimbursement. Eur Heart J.
Templin C, Jaguszewski M, Ghadri JR, et al. (2013). Vascular lesions induced by renal nerve ablation as assessed by optical coherence tomography: pre- and post-procedural comparison with the Simplicity catheter system and the EnligHTN multi-electrode renal denervation catheter. Eur Heart J.
Tofield A. (2015). Recurrent atrial fibrillation reduced after renal denervation with pulmonary vein ablation in select patients. Eur Heart J.
Tsioufis C, Papademetriou V, Dimitriadis K, et al. (2016). Long-term effects of multielectrode renal denervation on cardiac adaptations in resistant hypertensive patients with left ventricular hypertrophy. J Hum Hypertens.
Tsioufis C, Papademetriou V, Dimitriadis K, et al. (2015). 8B.08: SUSTAINED BENEFICIAL EFFECTS OF MULTI-ELECTRODE RENAL DENERVATION ON CARDIAC ADAPTATIONS IN RESISTANT HYPERTENSION: A 24-MONTHS FOLLOW-UP STUDY. J Hypertens.
Tsioufis C, Papademetriou V, Tsiachris D, et al. (2014). Drug-resistant hypertensive patients responding to multielectrode renal denervation exhibit improved heart rate dynamics and reduced arrhythmia burden. J Hum Hypertens.
Tuohy ST, Kyvelou SG, Gleeson PJ, et al. (2015). The effect of renal sympathetic denervation on nocturnal dipping in patients with resistant hypertension; observational data from a tertiary referral centre in the Republic of Ireland. Ir J Med Sci.
Ukena C, Mahfoud F, Kindermann I, et al. (2011). Cardiorespiratory response to exercise after renal sympathetic denervation in patients with resistant hypertension. J Am Coll Cardiol.
Ukena C, Mahfoud F, Spies A, et al. (2013). Effects of renal sympathetic denervation on heart rate and atrioventricular conduction in patients with resistant hypertension. Int J Cardiol.
van Brüssel PM, Eeftinck Schattenkerk DW, Dobrowolski LC, et al. (2016). Effects of renal sympathetic denervation on cardiac sympathetic activity and function in patients with therapy resistant hypertension. Int J Cardiol.
Vemulapalli S, Ard J, Bakris GL, et al. (2014). Proceedings from Duke resistant hypertension think tank. Am Heart J.
Verloop WL, Vink EE, Voskuil M, et al. (2013). Eligibility for percutaneous renal denervation: the importance of a systematic screening. J Hypertens.
Vink EE, Blankestijn PJ. (2013). Catheter-based renal nerve ablation and centrally generated sympathetic activity in difficult-to-control hypertensive patients. Hypertension.
Vink EE, Verloop WL, Siddiqi L, et al. (2014). The effect of percutaneous renal denervation on muscle sympathetic nerve activity in hypertensive patients. Int J Cardiol.
Vonend O, Antoch G, Rump LC, et al. (2012). Secondary rise in blood pressure after renal denervation. Lancet.
Voskuil M, Verloop WL, Blankestijn PJ, et al. (2011). Percutaneous renal denervation for the treatment of resistant essential hypertension; the first Dutch experience. Neth Heart J.
Waksman R, Barbash IM, Chan R, et al. (2013). Beta radiation for renal nerve denervation: initial feasibility and safety. EuroIntervention.
Wang L, Lu CZ, Zhang X, et al. (2013). Zhonghua Xin Xue Guan Bing Za Zhi.
Weber MA, Kirtane A, Mauri L, et al. (2015). Renal Denervation for the Treatment of Hypertension: Making a New Start, Getting It Right. Clin Cardiol.
White WB, Turner JR, Sica DA, et al. (2014). Detection, evaluation, and treatment of severe and resistant hypertension: proceedings from an American Society of Hypertension Interactive forum held in Bethesda, MD, U.S.A., October 10th 2013. J Am Soc Hypertens.
Witkowski A, Prejbisz A, Florczak E, et al. (2011). Effects of renal sympathetic denervation on blood pressure, sleep apnea course, and glycemic control in patients with resistant hypertension and sleep apnea. Hypertension.
Wu B, Hong M, Wu H, et al. (2015). Renal sympathetic denervation might be an adjunctive treatment approach for managing ventricular arrhythmia. Int J Cardiol.
Wybraniec MT, Czerwienska B, Lelek M, et al. (2015). Plasma renalase concentration before and after radiofrequency renal denervation in patients with resistant hypertension. J Hum Hypertens.
Yang WY, Staessen JA. (2015). Hypertension: Renal denervation-promising data from the DENERHTN trial. Nat Rev Nephrol.
Zaman S, Pouliopoulos J, Al Raisi S, et al. (2013). Novel use of NavX three-dimensional mapping to guide renal artery denervation. EuroIntervention.
Zhao MM, Tan XX, Ding N, et al. (2013). Zhonghua Yi Xue Za Zhi.
Zheng XX, Li XY, Lyu YN, et al. (2016). Possible mechanism by which renal sympathetic denervation improves left ventricular remodelling after myocardial infarction. Exp Physiol.
Ziakas A, Gossios T, Doumas M, et al. (2014). The pathophysiological basis of renal nerve ablation for the treatment of hypertension. Curr Vasc Pharmacol.
Ziegler AK, Bertog S, Kaltenbach B, et al. (2015). Efficacy and safety of renal denervation in elderly patients with resistant hypertension. Catheter Cardiovasc Interv.
Zuern CS, Rizas KD, Eick C, et al. (2012). Effects of Renal Sympathetic Denervation on 24-hour Blood Pressure Variability. Front Physiol.