# Appendix B Forms

Title Review Form

Title review form shows the authors and title of the article and the key questions

Abstract Review Form

Abstract review form shows the authors, title and link to the full-text pdf, option to exclude with reasons for exclusion and option to include/ unclear

Full Article Review Form

Full article review form shows the authors, title and abstract of the article, option to exclude with reasons for exclusion and option to include

Data Abstraction – Study Design Form

Data abstraction-study design form shows the authors, title and abstract of the article and details of study (location and design, trial type, if there was a run-in period, total intended follow up duration for RCTs, mean/median follow up duration for observational studies, total number of patients screened, total number at enrollment or cohort inception, if the study has a registered protocol, If it included patients with resistant hypertension, exclusion criteria, study funders, adherence assessment during run-in period, which subgroups were conducted)

Data Abstraction – Population Form

Data abstraction-population form shows the authors and title of the article and details of baseline characteristics of the study population (Total at enrollment, age, sex, race/ethnicity, body mass index, estimated GFR/serum creatinine, chronic kidney disease stages, diabetes status, left ventricular hypertrophy, medication use)

Data Abstraction – Intervention Form

Data abstraction-intervention form shows the authors, title and abstract of the article and details of the intervention group (Type of intervention, manufacturer and device for renal denervation, who performed the procedure, training to perform the procedure, was medication up titration allowed in the RDN arm, the percent of patients who did not receive their assigned treatment)

Data Abstraction – Outcomes Form

Data abstraction-outcomes form shows the details of each outcome (Type, definition, timing, results reported for subgroup, Continuous Outcomes: mean within and between group difference, baseline measures of cohort, final measures of outcome, Dichotomous Outcomes: Incidence of the outcome by intervention group, measures of association for comparison of outcome between intervention groups, what were the results adjusted for in the final model)

Data Abstraction – Quality Form

Data abstraction-quality form shows the details of how quality was assured (Study design, single/multi centered, run-in period, sample size, type of BP measured, sequence generation, allocation concealment, blinding of participants, personnel and outcomes assessors, incomplete outcome data, selective outcome reporting, other sources of bias)