# Appendix A Detailed Electronic Database Search Strategies

Search # | Query | Hits
1 | denervation[mh] AND (kidney[mh] OR “renal artery”[mh]) | 2247
2 | “renal denervation”[tiab] OR “renal-artery denervation”[tiab] OR “renal artery denervation”[tiab] OR “renal sympathetic denervation”[tiab] | 1796
3 | #1 or #2 (denervation[mh] AND (kidney[mh] OR “renal artery”[mh])) OR (“renal denervation”[tiab] OR “renal-artery denervation”[tiab] OR “renal artery denervation”[tiab] OR “renal sympathetic denervation”[tiab]) | 2941
4 | #3 AND (Addresses[ptyp] OR News[ptyp] OR Patient Education Handout[ptyp] OR Bibliography[ptyp] OR Dictionary[ptyp] OR Directory[ptyp] OR Legal Cases[ptyp] OR Legislation[ptyp] OR Newspaper Article[ptyp] OR Periodical Index[ptyp]) ((denervation[mh] AND (kidney[mh] OR “renal artery”[mh])) OR (“renal denervation”[tiab] OR “renal-artery denervation”[tiab] OR “renal artery denervation”[tiab] OR “renal sympathetic denervation”[tiab])) AND (Addresses[ptyp] OR News[ptyp] OR Patient Education Handout[ptyp] OR Bibliography[ptyp] OR Dictionary[ptyp] OR Directory[ptyp] OR Legal Cases[ptyp] OR Legislation[ptyp] OR Newspaper Article[ptyp] OR Periodical Index[ptyp]) | 7
5 | #3 NOT #4 ((denervation[mh] AND (kidney[mh] OR “renal artery”[mh])) OR (“renal denervation”[tiab] OR “renal-artery denervation”[tiab] OR “renal artery denervation”[tiab] OR “renal sympathetic denervation”[tiab])) NOT (Addresses[ptyp] OR News[ptyp] OR Patient Education Handout[ptyp] OR Bibliography[ptyp] OR Dictionary[ptyp] OR Directory[ptyp] OR Legal Cases[ptyp] OR Legislation[ptyp] OR Newspaper Article[ptyp] OR Periodical Index[ptyp]) | 2934
6 | #5 NOT (animal[mh] NOT human[mh]) (((denervation[mh] AND (kidney[mh] OR “renal artery”[mh])) OR (“renal denervation”[tiab] OR “renal-artery denervation”[tiab] OR “renal artery denervation”[tiab] OR “renal sympathetic denervation”[tiab])) NOT (Addresses[ptyp] OR News[ptyp] OR Patient Education Handout[ptyp] OR Bibliography[ptyp] OR Dictionary[ptyp] OR Directory[ptyp] OR Legal Cases[ptyp] OR Legislation[ptyp] OR Newspaper Article[ptyp] OR Periodical Index[ptyp])) NOT (animal[mh] NOT human[mh]) | 1266
7 | #6 AND “2005/01/01”[pdat] : “2016/03/08”/[pdat] ((((denervation[mh] AND (kidney[mh] OR “renal artery”[mh])) OR (“renal denervation”[tiab] OR “renal-artery denervation”[tiab] OR “renal artery denervation”[tiab] OR “renal sympathetic denervation”[tiab])) NOT (Addresses[ptyp] OR News[ptyp] OR Patient Education Handout[ptyp] OR Bibliography[ptyp] OR Dictionary[ptyp] OR Directory[ptyp] OR Legal Cases[ptyp] OR Legislation[ptyp] OR Newspaper Article[ptyp] OR Periodical Index[ptyp])) NOT (animal[mh] NOT human[mh])) | 1098
7 | ((((denervation[mh] AND (kidney[mh] OR “renal artery”[mh])) OR (“renal denervation”[tiab] OR “renal-artery denervation”[tiab] OR “renal artery denervation”[tiab] OR “renal sympathetic denervation”[tiab])) NOT (Addresses[ptyp] OR News[ptyp] OR Patient Education Handout[ptyp] OR Bibliography[ptyp] OR Dictionary[ptyp] OR Directory[ptyp] OR Legal Cases[ptyp] OR Legislation[ptyp] OR Newspaper Article[ptyp] OR Periodical Index[ptyp])) NOT (animal[mh] NOT human[mh])) AND “2005/01/01”[pdat] : “2015/12/31”/[pdat] | 11095