# Results

## Introduction

This chapter first describes the results of the literature searches and then provides the results for the outcomes of interest in the following order: delay or avoidance of total knee replacement; measures of function, including ADLs/IADLs; quality of life; pain; and adverse events.

## Results of Literature Searches

The searches of peer reviewed literature identified 2,461 unique titles (Figure 2). The partner, CMS, provided 84 titles, of which all but 9 were already included in the search results. Reference mining of those studies yielded an additional 10 titles. The searches of grey literature yielded 48 titles. Information provided by manufacturers (Scientific Information Packets (SIPs)) included two titles, of which two unique titles were accepted. Altogether, 2,528 titles and abstracts went on to dual screening.

Of the 2,528 titles, 512 were initially identified for full-text review. The remaining 2,016 titles and abstracts were rejected for being animal or in vitro studies (405), not reporting on OA of the knee (324), not using intra-articular HA injections (417), not reporting any outcomes of interest (170), having an inappropriate study design (e.g., obvious commentaries or non-systematic reviews) (407), not enrolling a population of interest (30), or being written in a non-English language (258). Three articles could not be obtained and two had duplicate data.

A second level of screening was conducted on the 512 titles and abstracts initially identified for full-text review. Of the 512 titles, 366 were rejected: Studies were rejected at this stage for the following reasons: language not English (8), study design (124); participants excluded (10); interventions not of interest (7); outcomes not of interest (103); mean age less than 65 (78); AE reports with sample size less than 500 (29); or duplicate data (7). Of the remaining 83 studies, two systematic reviews were accepted, 81 were background articles, and 63 were original studies that underwent detailed abstraction. These included RCTs that reported function, ADLs/IDLs, QoL, arthroplasty, and/or AEs (25); case series or prospective cohort studies reporting AEs or arthroplasty (total knee replacement) (20); or case reports reporting AEs (18). Of the case series and cohort studies that reported AEs, only those that enrolled populations of 500 or greater were included, to ensure detection of rare AEs. Appendix B provides a list of excluded studies with the reasons for exclusion.

Figure 2 Literature Flow Diagram

Figure Notes: ADLs=Activities of Daily Living; IADLs=Instrumental Activities of Daily Living; AEs=Adverse events; CMS=Center for Medicaid Services; SIPs: Scientific Information Packets

Figure 2. Literature Flow Diagram Figure 2 is the flow chart that summarizes the study retrieval and selection process for articles. The information displayed in the figure is described in the section entitled Results of Literature Searches>.

Table 2 Strength of Evidence

Outcome | Strength of evidence Grade | Study Design | No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Finding
Arthroplasty | Insufficient | RCTs | 2 13 | High | Direct | Consistent | Imprecise | Suspected | TKR not intended outcome | No pooled effect size
Arthroplasty | Insufficient | Observational | 2 13 | High | Direct | Consistent | Imprecise | Suspected | TKR not intended outcome | No pooled effect size
Function: HAs vs. placebo | Low | RCTs | 10 | Moderate | Direct | Inconsistent | Precise | None | 2ndary outcome | −0.23 (−0.34, 0.02)
Function: HA vs. HA | Insufficient | RCTs | 5 | High | Direct | Inconsistent | Imprecise | unknown | 2ndary outcome | No pooled effect size
Quality of Life | Insufficient | RCTs | 2^*^ 1 | High | n/a | n/a | n/a | n/a | Different outcome measures | No pooled effect size
Adverse Events: total | Moderate | RCTs Observational cohort case reports | 25 4 18 | Moderate | Direct | Consistent | Precise | Unknown | Cohort studies included patients <65 | Similar rates of AEs were reported in studies of HA and placebo
Adverse Events: serious (SAEs) | Moderate for the rarity of SAEs; Low for a difference between the intervention and placebo groups | RCTs | 25 | Moderate | Direct | Consistent | Imprecise | Unknown | Causal mechanism not proposed for some SAEs | Joint: 0.77(0.25, 2.31) Other: 0.62(0.23, 1.57)

Table Notes:

* Two trials compared Synvisc® to Hyalgan;® one trial compared Hyalgan® to saline. Each used a different measure

## Delay or avoidance of knee replacement surgery

Three RCTs and 13 observational studies reported on knee replacement (TKR) after administration of intra-articular HA injections. Of the three RCTs, only one assessed TKR as a prespecified outcome; the other two reported it as a treatment failure.

### Key Points

- Three RCTs enrolled small numbers of patients and reported on TKR, although it was not a prespecified outcome of interest in two of the studies: One reported higher rates of TKR among HA-treated patients, whereas the other two reported higher rates among placebo-treated patients.
- Six case series and seven cohort studies reported on TKR as an outcome following HA treatment. Most studies reported delays in TKR in patients who received HA injections compared with the usual progression among patients who did not receive TKR, or lower rates of TKR in patients receiving HA than usually seen in the absence of such treatment. Two studies that assessed risk factors for undergoing TKR among patients who received HA found that only baseline severity and age were factors: those in the 60 to 69 year old age range in one study and in the 65 to 79-year range in the other were significantly more likely than those younger or older to undergo TTKR, and in the former study, the time from diagnosis to TTKR was faster for this age group. No study reported the criteria for knee replacement surgery or the characteristics that distinguished those who underwent surgery.

### Detailed Synthesis

No systematic reviews were identified that reported on studies assessing the rate of TKR among patients who were treated with HA.

Randomized Controlled Trials. We identified three randomized trials49,50,51 that reported the number of people who underwent arthroplasty. However, TKR was a pre-specified outcome of interest in only one of the studies, and the others showed indications of high risk of bias. Two of the three trials demonstrated non-significant trends, indicating that fewer people in the Hyalgan® group had arthroplasty than the placebo group.

A 1993 study by Dougados and colleagues was a 1-year trial of Hyalectin, a higher molecular weight avian product (four weekly doses) vs. saline placebo (quality assessed as moderate risk for bias).49 A group of 110 patients (mean age 68, 71% women) were divided into two groups; the primary outcome was improvement in effusion and secondary outcomes were pain and function. Between week 7 and 52, two patients in the active intervention group and 5 in the placebo group underwent TKR (OR 0.41, 95% CI 0.09, 1.89).

A 2003 study by Forster and Straw was a 1-year trial of Hyalgan, a lower molecular weight avian product (5 weekly doses) vs. arthroscopic washout (quality assessed as moderate risk).50 A group of 38 patients (mean age 62, proportion of women not reported) were randomized into the two groups. At 1 year, two patients from the active intervention and one patient from the arthroscopy group had undergone TKR; one patient from the active intervention and two patients from the arthroscopy group were on a waiting list for TKR; and two additional patients from the active intervention group had undergone arthroscopy and were on a waiting list for TKR (OR 0.54, 95% CI 0.08, 3.59).

A 2008 study by Blanco and colleagues was a 1-year trial of two cycles of Hyalgan (5 weekly doses each) vs. placebo control (quality assessed as low risk of bias).51 A group of 42 patients (mean age 67.9, 76% women) on the waiting list for TKR were randomly assigned to the two treatment groups. The primary outcome was avoidance or delay of TKR; secondary outcomes included WOMAC pain, function, and stiffness, and adverse events. At one year, survival analysis showed a non-statistically significant higher survival time until knee replacement in the HA group compared with the placebo group (368.8 days vs. 253.9 days, p=0.249). The proportion who discontinued treatment at 24 weeks due to lack of efficacy was also non-statistically significantly higher in the placebo group (87% vs. 64%, p=0.06). Knee surgery was avoided in 9 HA-treated patients and 3 placebo-treated patients (OR 0.30, 95% C, 0.08, 1.10). The randomized trials are described in evidence tables included in Appendix C.

Observational Studies. Six retrospective case series (reported in 7 articles) reported on TKR as an outcome (Table 3).52–58 Numbers of enrolled patients ranged from 69 (73 knees) to 1,342 (1,863 knees). Three of the studies administered Hylan GF-20 (Synvisc®, a higher molecular weight avian product), one administered Hyalgan, one administered Suplasyn, a lower molecular weight synthetic, and one administered Supartz™, a medium-high molecular weight avian hyaluronic acid. Follow-up times ranged from 6 months to 12 years. Rates of TKR in these studies of HA-treated patients varied from fewer than 1% for 310 patients treated with Suplasyn and followed for 6 months,55 to 25% of 1,863 knees treated with Hylan GF-20 and followed over 12 years.58 None of the studies specified the criteria used by the treating physicians for recommending patients to undergo surgery, although all 863 patients included in the study by Waddell and Bricker were classified as Kellgren-Lawrence stage IV56, had failed to obtain relief from pharmacologic agents, and were considered candidates for TKR.

Two medium52,54 and one large56 case series on patients treated with HA assessed the effect of various factors on the likelihood of these patients undergoing TTKR and the time to TTKR by age group. One medium-size 2002 study52 by Barrett and colleagues reported that those who underwent TTKR tended to be older than those who did not but that BMI did not differ between the groups. The other medium sized study, a 2001 study by Evanich and colleagues, reported that those with Grade IV (67%) and those 65–79 years of age (34%) were more likely than those with less severe disease or in older or younger age groups to get TKR.54 The largest study, a 2007 study by Waddell and Bricker, found that the likelihood of stage IV patients undergoing TKR did not differ by sex, BMI, history of effusion, or baseline VAS for pain. Only age range was a factor: HA-treated patients 60 to 69 were significantly more likely to undergo TKR than patients under 50, patients 70 to 79, and those over 80, and patients in the younger age groups (50–79) were 2–3-fold more likely to get a TKR than those 80 and over. Median time to TKR for HA recipients was 1.8 years (range 14–2,147 days). Median followup time was 2.2 years (7–2,222 days). Seventy-five percent of knees had not had TKR by 3.8 years. Time to TKR was associated only with age: 60–69 year olds had a significantly shorter time to TKR than other age groups.56

A subsequent followup of the Waddell and Bricker study re-assessed the 863 patients who were treated between 1997 and 2003 as well as the full cohort of 1,342 patients who continued to be followed through 2010.^58^ The number of treatment courses ranged from 1 to 7. For the original cohort, the mean observation period (time to TKR) for patients who underwent TKR was 3.1 years; patients who did not undergo TKR were observed for a mean of 10.9 years. The overall incidence of TKR was 28% in this group. For the full cohort, the mean observation period (time to TKR) for patients who underwent TKR was 2.8 years; patients who did not undergo TKR were followed for a mean of 8.7 years (mean for all patients 7.2 years). The rate of TKR for the full cohort was 25%. A comparison group of stage IV patients who did not elect HA underwent TKR within 3 months. Survival analysis demonstrated that HA treatment delayed the need for TKR in 75% of patients by 7.3 years. As in the original analysis, age was the only factor associated with tendency to undergo TKR.

Several other case series also reported on the average or longest time to TKR in treated patients. For example, the case series by Barrett and by Evanich reported mean lag times of more than 6 months in those who underwent the procedure,52,54 and a large 2010 multi-site study of Supartz™ by Whitman reported that the mean time to TKR was 1.99 years and time to TKR was as long as 4 years.57

Nine articles reported on seven cohort studies that assessed TKR as an outcome (Table 4).59–67 Numbers of enrolled patients ranged from 76 (92 knees) to 1,047 (1,489 knees). All studies enrolled patients with mean ages over 65, except one.66 Three studies administered Hylan GF-20 (Synvisc); two administered Hyalgan; one administered Durolane, a non-avian product of medium molecular weight administered as a single injection; and one administered Adant, a non-avian medium molecular weight product administered in three to five weekly doses. Follow up times ranged from 6 months to 4.5 years. Rates of TKR varied among studies as did the methods of reporting. One study that administered Hyalgan reported that over two years, 12 of 15 patients originally scheduled for TKR cancelled the procedure.59 The study that reported its findings in three articles reported that over a followup of 24 months, 20% of patients underwent TKR;62 over 54 months, 28.4% of patients had undergone TTKR, with a mean time to surgery of 15.4 months.61 When they stratified patients by Ahlback Grade, 4% of patients in the lowest severity group (Ahlback Grades of 1 or 2) underwent TKR, 32.9% of patients in the medium severity group underwent TKR, and 13.4% of patients in the highest severity group underwent TKR.63 Hylan GF-20 was associated with lower rates of TKR in two studies by the same group,64,65 but with a 22% rate of TKR in another study.66 As with the retrospective studies, no study specified the criteria used to recommend patients proceed to TKR.

A modification of the Newcastle-Ottawa instrument was used to assess the risk of bias of the included observational studies (Table 5). Risk of bias varied, with most studies indicating scoring on the moderate to high risk of bias side. Few studies attempted to control for baseline differences in comorbidities, few reported financial conflicts of interest, and patients were aware of their treatment in every instance.

Table 3 Case Series Reporting on Knee Replacement as an Outcome

Author, Year Country | # patients/ mean age (SD)/age range/ % female/ mean BMI/ mediating factors | Inclusion criteria/ exclusion criteria | Intervention/ dosing schedule/ follow-up times | Outcomes reported | Efficacy results | AEs results | Conclusions and comments
Evanich, 2001^54^ US | 84 patients/66±14 years/age range NR/61% women/BMI NR | First 100 knees to receive HA at authors’ clinic | Hylan GF-20 (Synvisc) 3 injections FU 12 months | Pain, function, TKR, other procedures (CS injection, arthroscopy) over 12 months | Loss to followup 14 patients; 80 knees in 70 patients followed over 12 months 20 of 80 (25%) knees underwent TTKR (20 patients) at an average of 6.7 months Those with Grade IV (67%) and those 65–79 years of age (34%) were more likely than those with less severe disease or in other age groups to get TKR. 2 more had arthroscopy. | 12 knees experienced AEs: 1 case of staph septic arthritis (2 weeks post initial injection), 11 cases of pain and swelling | Higher and lower age (compared with 65–79 years) and lesser severity decreased likelihood of undergoing TTKR. Outcomes assessed by clinic nurse, not patient’s own provider
Barrett, 2002^52^ | 249 patients (363 knees) treated Mean age 72 years /range 30–97 years/ 51.2% female/ BMI 29 Non-participants (those unavailable to be assessed): 127 (176 knees) | Inclusion: ACR OA diagnosis and radiogram within prior 6 months, completion of 5-injection course Exclusion: receipt of 2^nd^ course within 12 months (to study effects of single treatment course); significant alteration in exercise routine within 6 months | Hyalgan 5 injections/ 1 per week 6 months | Lack of TTKR or other significant intervention therapy; secondary outcomes assessed in patients who avoided TKR: QOL, pain (reported as improvement, non-improvement) | 60.1% of knees (61.8% of patients) were considered clinically improved at 6 mos. 39.9% were judged as failures (20.3% underwent TTKR); Risk for TKR depended somewhat on compartmental involvement | “Excellent safety profile” | Single-course Hyalgan delayed or avoided TTKR for at least 6 months in the majority of knees. Successes tended to be younger but did not differ on BMI Comment: 1. Unclear whether comparison group received treatments or what their success rate was 2. one of the 2 authors is employed by the manufacturer
Campbell, 2004^53^ | 69 (73 knees)/ 62.2 years /range 37–90/ 44% women | Inclusion: Confirmation with plain x-rays or arthroscopy; Exclusion: none | Hylan GF-20 (Synvisc) 3 injections immediately after arthrocentesis Mean FU 8 months | Subjective improvement, total knee replacement, other treatments | 61 patients identified for followup (90%) 51% of respondents reported a range of improvement; 11 patients underwent surgery including 7 knee replacements | Swelling/redness (6 patients) Pain at injection site (12) Apparent sepsis (3) | Patients were allowed to continue other methods of management; HA provided short-term relief for about half of patients but authors had largely discontinued use
Mazieres, 2007^55^ France MESSAGE Study | 310 patients, 296 of whom were assessed for outcomes:/69± 10 years/age range 36–88; 65% women/BMI 28±5 (30% obese) 36.5% of patients had both knees affected | Inclusion:>18 years; knee OA meeting ACR criteria; inadequate self- or MD-reported response to level 1 or 2 analgesics or NSAIDS within last 3 months Exclusion: effusion; history of intra-articular CS therapy within past 3 months, history of HA therapy within last year; scheduled surgery on target knee; contraindications to intra-articular injections; known hypersensitivity to HA; pregnancy | Suplasyn 3 injections FU 3 months, 6 months | Kellgren Lawrence, Lequesne; WOMAC pain and function, QoL (SF-12); costs (including procedures) | Of the 310, 14 were withdrawn early; 296 patients were assessed for outcomes: 1 partial TKR and 1 TKR were performed; significant improvements in WOMAC, Lequesne, SF-12 | NR | <1% TTKR after at least 2 injections Suplasyn
Waddell, 2007^56^ Waddell, 2014^58^ US | 1,187 knees (863 patients)/mean age of patients who underwent TKR: 66.8±10.02(36–89), patients without TKR: 67.5±13.3 (28–98); 60% Female for both groups | Inclusion criteria: Any grade OA; unsuccessful treatment with NSAIDs and analgesics (WOMAC or pain VAS score of 50 or more) Exclusion criteria: mechanical problems, deformities due to OA, contraindications to HA (hypersensitivity, target knee joint infections, skin diseases, infections in area of injection site) (inclusion criteria for TKR: K-L Grade IV and VAS pain score ≥60) | Hylan GF-20 (Synvisc) 3 injections (1997–2003) administered using a fluoroscopic technique to ensure accurate needle placement; repeat courses for some patients; prescription pain killers allowed for post injection pain and swelling FU 5 years | Primary outcome time to TTKR | 19% of knees treated with HA underwent TKR. Undergoing TTKR did not differ by sex, mean age, BMI, history of effusion, or baseline VAS for pain. Only age range was a factor. Patients 60–69 were significantly more likely than patients under 50, patients 70–79, and those over 80 to undergo TKR, and patients in the younger age groups (50–79) were 2–3 fold more likely to get a TTKR than those 80 and over. Median time to TKR for HA recipients was 1.8 years (14–2,147 days). Median followup time was 2.2 years (7–2,222 days). 75% of knees had not had TKR by 3.8 years. Time to TKR was associated only with age: 60–69 year olds had a significantly shorter time to TKR than other age groups. | NR | Retrospective case series review; TKR candidates who are not candidates for HA in this clinic typically undergo surgery within 3 months of first visit; in comparison, median time to TKR in HA recipients was 638 days (median followup 810 days). Authors acknowledge lack of information on patients who did not receive TKR within the followup time and other limitations.
Whitman, 2010^57^ US | 220 patients (303 knees); average age 70.9; range 35–99; 74.5% female | Inclusion: age≥18 years, confirmed diagnosis of OA, at least one repeat treatment with Supartz™ Exclusion: NR | 5 weekly injections, follow-up 5 years | Pain, TKR, AEs | Overall rate of TKR: 23/303 (7.6%) Local site rates (5 sites) ranged from 1.8% to 24.0%. Mean time to TKR 1.99 years (0.5 to 4 years) | 26 total AEs none severe | Supartz was thought to delay or prevent need for TKR. 92 percent of patients reported improvement in pain

Table Notes: CS corticosteroids; FU follow-up; HA hyaluronic acid; OA osteoarthritis; TKR total knee replacement

Table 4 Cohort Studies Reporting on Total Knee Replacement as an Outcome

Author, Year Country | # patients/ mean age (SD)/age range/ % female/ mean BMI/ mediating factors | Inclusion criteria/ exclusion criteria | Intervention/ dosing schedule | Outcomes reported/Follow- up times | Efficacy results | AEs results | Conclusions and comments
Neustadt, 2003^59^ US | 76 patients (92 knees)/64±7.4 years/40–80 years/60% > 65 years/21% female | Authors did not specify inclusion or exclusion criteria but all patients had moderate-severe OA, Kellgren-Lawrence II-IV, pain unresponsive to conventional treatments | Hyalgan 5 weekly injections | Physical exam, radiographs, AEs, ADLs/QoL, TKR/ weekly and then at 6, 12, and 24 months | 72% of patients achieved >50% improvement in in pain for ≥1 year 12 of 15 patients scheduled for TKR no longer considered procedure necessary at 1 year; 15 of 19 avoided or delayed TKR at 2 years. | No systemic AEs Minor AEs were infrequent and included injection site bruising and pain, rare headache, nausea; no pseudoseptic reactions | HA seemed to be associated with reduced need for TKR. Improvement decreased with increasing Kellgren-Lawrence score, but this was not determined for TKR
Waddell, 2005^65^ US | 85 patients (66 completed 26 weeks, 24 completed 104 weeks;)/65.5±11.1 years/64.8% female | Inclusion criteria: healthy, ambulatory men or women aged _40 years; diagnosed with OA (at least 3 months earlier, ACR criteria); WOMAC score ≥2 on pain while walking on a flat surface; a score of 50–90 mm VAS; failure to obtain OA knee pain relief with previous therapy of analgesics or NSAIDs; having received a clinical benefit from an initial course given at least 3 months prior. Exclusion: any serious systemic disease or significant psychiatric or neurological disorder; pregnant or nursing women, or women of childbearing age not using reliable birth control; known allergy to avian products, any components of hyaluronan-based injection devices, or corticosteroid injections; acetaminophen hypersensitivity; or use of an investigational drug or device within 90 days prior to the study; other joint diseases or conditions; patella femoral knee pain; acute synovitis; palpable effusion at screening or baseline; local AE with first course of hylan G-F 20; history of any joint sepsis; major surgery or arthroscopy in either knee within 6 months before screening or planned during the study; arthroplasty at the target joint; oral or intra-articular corticosteroid or any other intra-articular injection at the target joint within 3 months, or at a non-target joint within 4 weeks of screening; or use of glucosamine or chondroitin sulfate within 30 days prior to study entry | Hylan GF-20: 3 weekly injections | Pain, mobility, medication, AEs, TKR (counted as reason for loss to followup), 104 weeks follow-up | At 52 weeks, of 59 remaining patients, 1 patient had undergone TKR. No more TKRs were reported through 104 weeks. | AEs were reported only as possibly, probably, or definitely treatment-related. 1 patient experienced severe arthrosis. No AE-related discontinuations | Repeated course of HA provided continued pain relief
Waddell, 2006^64^ US | 1,047 patients (1,489 knees)/mean age 65.3/60% female 71% grade IV Kellgren-Lawrence | Inclusion criteria: OA diagnosis, lack of response to NSAIDS and analgesics Exclusion criteria: mechanical symptoms or deformities due to OA, contraindications to HA | Hylan GF-20: 3 weekly injections | Pain, mobility, medication, AEs, TKR, 26 weeks follow-up | 21 patients (2%) underwent TKR before the end of the 26-week followup period | 49 patients experienced 54 local AEs (pain and swelling) 12 patients experienced severe local pain and swelling. All resolved spontaneously or with aspiration and corticosteroids. AEs did not affect efficacy. | Proportion of patients who underwent TKR was low
Turajane, 2007a,62 Turajane, 2007b63 Turajane, 2009^61^ Thailand | 195 patients (220 knees)/68.74 years/range 50–84 years/75% female/BMI 25.21 | Inclusion criteria: Primary knee OA by ACR criteria, failure of conservative treatment more than 6 months (anti-inflammatories), no contraindication for surgery Exclusion criteria: other degenerative arthritis or other joint disease, previous surgery, allergy to avian protein or sodium hyaluronate, any intra-articular treatment within prior 6 months | Hyalgan: 3 weekly injections, at least 1 course Patients who responded well received additional courses at 12-month intervals | Cost analysis of HA after ≥2 years follow-up WOMAC, delay or cancellation of surgery, AEs Follow-up >24 months (24–48 months) Time to TKR over 54-month follow-up | 183 patients (206 knees) completed treatment; 146 patients (164 knees) responded to HA; 37 patients required surgery by 24 months (20%). Of the responders, 83 patients received a second course of tx and 14 received a third course. WOMAC improved in all groups. Group 1 (Ahlback grades 1,2):89.1% of patients delayed or cancelled knee surgery; 10.9% underwent surgery: 2 underwent TKR, 3 arthroscopy Group 2: 67.1% delayed/cancelled surgery; 23 patients (32.9%) underwent TKR Group 3: 86.5% delayed surgery; 13.4% underwent TKR Incidence of TKR: 28.4% Mean time to TKR: 15.4 months (0.7–51.7 months) Mean follow-up time for patients who did not undergo TKR was 45.6 months (19.0–53.1 months) | NR | Retrospective cohort study enrolled 2001–2004 HA is cost effective Repeated courses of HA were efficacious in delaying TKR in patients who responded to tx
Anand, 2010^66^ US | 167 patients/mean age 59.4 (range 15–92)/57% female Ahlbeck classification used: 1 Grade 1, 20 Grade 2, 104 Grade 3, 5 Grade 4 | Inclusion criteria (for analysis): 1 completed course of HA, failure at previous protocol (NSAIDS, strength training, weight reduction, shoe modification, bracing, topical anesthetics, intra-articular CS) 119 patients had undergone prior arthroscopy. | Patients offered HA or TKR; all opted to try HA: Synvisc (1999–2003) | Self-reported satisfaction, TKR, AEs/6 months—5 years FU | 130 patients underwent chart evaluation. Average number of courses HA: 1.6, 6–36 months between intervals. 45 patients were advised to proceed to surgery (including 17 who responded poorly at 6 months). 29/45 underwent surgery, including 24 TKR and 5 partial (22%). All TKR patients were Grade 3–4 at baseline. Of 109 patients seen at 5-year followup, 58.7% had not had surgery and were doing well. | 3 patients developed toxic synovitis | Authors conclude HA can delay need for TKR
Korkmaz, 2013^67^ Turkey | 705 patients/mean ages and sex ratios reported by diagnostic group and treatment group; only Grade 4 patients in the HA group had mean age>65 (68±13.3) | Inclusion criteria: ACR diagnosis Exclusion criteria: intra-articular injection within prior 3 months; arthroscopic intervention within prior year; history of pain with intra-articular injection | 218 patients received Adant once weekly for 3 weeks; 487 patients received only NSAIDs and exercise prescriptions (2007–2009) | Surgical intervention at 1-year follow-up | 197 patients received all HA treatments. Of those patients, 20 surgical procedures were done, including 7 TKR (3 were done in patients with grade 3 OA and 4 in patients with grade 4 OA). Of 487 patients who received NSAIDs, 62 had surgery, including 26 TKR | NR | Rates of total surgical procedures did not differ between groups but there was a non-significant decrease in procedures among those with the most advanced OA treated with HA (compared with NSAIDS) and in TKR among the HA-treated groups
Jurado, 2013^60^ Spain | 224 patients/65.7 years/age range 34–89/67.9% female/ | Inclusion criteria: diagnosis of OA according to Spanish Society of Rheumatology criteria; no other mechanical joint problems; no contraindications to HA; consistent use of same HA product; minimum 1-year followup Criteria for referral for TKR were grade IV OA and age<75 or Grade III and age >60 | Durolane (NASHA HA) 22 patients (9.2%) did not receive HA | Referral and time to referral for TKR/mean follow up 374 days (95% CI, 323, 425) (range 0–1547 days) Effects of gender, age, comorbidity, number of joints affected, severity at last follow-up, progression, pain, HA on time to TKR | 40 patients (17.9%) were referred for TKR. Mean follow-up was 328 days (95% CI, 232, 424). 20 of the 40 referred received TKR. 9.1% of these patients were referred for surgery (these patients had lower average Kellgren-Lawrence classifications than those treated with HA) Viscosupplementation increased the time between referral until surgery but not significantly. | NR | Age over 65, involvement of both knees, severity of OA, lower pain intensity, and HA were each associated with longer time to TKR; HA was associated with 1093 days to TKR (95% CI. 980, 1206) vs. 694 with no treatment (95%CI, 548, 839) (p=.064)

Table 5 Risk of Bias Assessment for Observational Studies Included in Assessment of Total Knee Replacement^*^

Author, Year | Representativeness | Control for differences | Loss to follow-up | Masking exposures | Ascertainment^**^ | Other treatment modalities | Valid outcomes^**^ | AE collection | Financial COI | Author COI
Evanich, 2001^54^ | Y | Y | N | Y | Y | N | Y | N | N | NR
Barrett, 2002^52^ | N | NR | Y | Y | Y | Y | Y | NA | N | N
Neustadt, 2003^59^ | Y | Y | Y | N | Y | N | Y | Y | N | Y
Campbell, 2004^53^ | N | NR | N | Y | Y | N | Y | N | Y | Y
Waddell, 2005^65^ | N | Y | Y | N | Y | Y | Y | Y | N | NR
Waddell, 2006^64^ | Y | Y | Y | N | N | Y | Y | Y | N | Y
Waddell, 2007^56^ | Y | Y | Y | N | Y | Y | Y | N | N | N
Mazieres, 2007^55^ | Y | N | Y | Y | Y | Y | Y | NA | NR | NR
Turajane, 2007^62^ | N | Y | Y | N | Y | N | Y | NA | NR | NR
Anand, 2010^66^ | N | N | Y | N | Y | Y | Y | NA | Y | Y
Jurado, 2013^60^ | N | Y | Y | N | Y | Y | Y | NA | Y | Y
Korkmaz, 2013^67^ | NR | N | Y | N | Y | N | Y | NA | NR | NR
Waddell, 2014^58^ | Y | Y | Y | N | Y | Y | Y | Y | Y | Y
Whitman, 2010^57^ | Y | N | Y | N | Y | N | Y | N | N | N

Table Notes:

* See Appendix D for assessment tool. Y=yes (low risk); N=no (high risk); NR=not reported; NA=not applicable; COI conflict of interest; #also includes Turajan, 2007^63^ and 2009;^61^ ;

** Ascertainment: Yes indicates the diagnosis and/or treatment outcome were validated by medical report; Validity of outcomes: Yes indicates the outcome measure(s) have been validated for the condition and treatment of interest.

## Intra-articular injection of hyaluronic acid and measures of function

We identified 18 randomized trials that compared the effects of HA with placebo or another HA using a validated assessment of function that included the WOMAC and/or Lequesne Index, or ADLs/ IADLs, in individuals with OA of the knee whose average age was 65 or older.

### Description of included studies

Of the 18 trials that reported on function as an outcome, sample sizes ranged from 32 to 495.^49–51,68–82^ Only a small proportion were US studies; the rest were conducted in Canada, the UK, Germany, France, Denmark, Sweden, Thailand, and Taiwan, and one was a multinational European trial. Of the trials, 11 were compared to a placebo,49,51,69,71–74,76,79,81,82 six compared two HA devices head to head (one study had both a head-to-head comparison and a placebo group),68,70,76–78,80 and two studies compared an HA to another active treatment.50,75 Two studies conducted followup at 52 weeks49,82, one conducted followup at 4 weeks,79 one ran for 12 weeks,78 and the remainder conducted follow-up at 6 months (26 weeks).50,51,68–77,80,81 Most studies included Hyalgan, five included Synvisc, and one each included Adant, NRD101 (a medium molecular weight non-avian HA), Orthovisc, Supartz, Suplasyn, and GO-ON.

Nearly all studies reported functional outcomes using either the WOMAC functional domain or Lequesne functional index; one study measured KOOS activities, and one measured ADLs. In order to decide if the Lequesne index was similar enough to the WOMAC for pooling, we looked at 4 trials70,75,76,78 that reported both outcomes to see if the conclusions based on these two indices agreed (within trial). Conclusions for three of the four trials were the same for WOMAC and Lequesne. The one the differed78 had different follow-up times for the WOMAC and Lequesne Index. Thus, we believed that the results of trials that only reported the Lequesne Index could be pooled with those of WOMAC trials. The one trial68 that reported on ADL/IADLs was deemed different enough from the other function outcomes to preclude pooling. These studies are described in Table 6 and in the evidence table in Appendix C.

The risk of bias for these RCTs varied widely from 0 to 12 (of 12) indicators of unclear or high risk of bias (Figure 4). The characteristics most often not reported or clearly not considered were allocation concealment and blinding of providers. In addition, although not considered in assessment for risk of bias, almost no studies reported the proportion of participants who responded (reporting only the mean difference in response from baseline).

### Key Points

- Our meta-analysis of ten studies that compared the effects of an HA to those of a placebo control showed a significant improvement in WOMAC-assessed function following HA treatment compared to placebo (standardized effect size or standardized mean difference [SMD] −0.23, 95% CI −0.45, −0.01) that did not achieve the MCID of −0.37 applied by Rutjes but did exceed the MCII of −0.20 utilized in the recent network meta-analysis by Bannuru and colleagues and the MCII of −0.12 used in one of the included trials (based on the pooled effect size, about 11 percent would have exceeded the MCID of 0.37 in improvement and about 33% would have exceeded the MCII of −0.12).
- The number of head-to-head trials is too small to be able to assess the relative superiority of one HA over another.
- Although most studies reported findings at 6 months’ follow-up, one study with 4 weeks follow-up and two studies with 52 weeks’ follow-up also reported a positive effect of the device on functional outcomes.
- One study, a head-to-head trial comparing two types of HA, assessed the proportion of patients who achieved a minimum clinically important improvement in function: 69% of patients given an intermediate-weight HA and 56% of patients given a lower-molecular weight HA. Seven studies assessed the proportion of patients with patient- or investigator reported global improvement; of the four that were placebo-controlled, three reported significant increases in the proportion of HA-treated patients who improved, compared with the proportion of placebo-treated patients who improved.
- No studies assessed the effect of HA on range of motion.
- No studies assessed the durability of effect.

### Detailed Synthesis

Placebo-controlled trials. Eleven trials49,51,69,71–74,76,79,81,82 presented data comparing the effect of HA on function to that of a sham-injected placebo group with blinded assessment (Table 6). All but one69 reported a mean change from baseline or a baseline and follow-up mean by treatment group. Four trials71,74,79,81 did not report the standard deviation of the mean change, so we estimated it using the standard deviations of the baseline and follow-up mean change. One of these trials71 also did not report a follow-up standard deviation so it was imputed. We included the WOMAC function scale from 4 trials71–73,79, Lequesne index from 3 trials49,74,76 and KOOS activities from one trial.81 One trial76 reported both the WOMAC and the Lequesne Index. In this case, we used the Lequesne Index, as it provided more data.

Pooled analysis of ten placebo-controlled trials showed a small increase in function for the HA-treated group (standardized effect size or standardized mean difference [SMD] −0.23, 95% CI −0.45, −0.01) at follow-up using the HKSJ method (Figure 3).49,51,71–74,76,79,81,82 This finding indicates that those in the HA group had statistically significantly better functioning than those in the placebo group. We calculated that the effect size corresponded to an improvement of 8.28 units (on a 0–100 VAS scale) which was smaller than the MCID used in the systematic review of the effects of HA conducted by Rutjes17 but exceeded the MCII of −0.20 recommended by OARSI-OMERACT24 as well as that derived by Tubach and colleagues.45

The I^2^ is 54.0%, indicating low to moderate heterogeneity. Both the Begg’s and Egger’s test showed no evidence of publication bias (p=0.245 and p=0.418, respectively). One of the included studies reported a stronger effect for placebo than for the active treatment,76 and one study showed no effect for either.81 All but three of the studies reported follow-up at 6 months; sensitivity analyses that excluded all of the studies that reported follow-up sooner (4 weeks)79 or later (52 weeks)49 individually did not result in a large difference from our main result (SMD=−0.23 and SMD=−0.25, respectively) (Figure 3). Among the comparisons not included in the meta-analysis, one study compared the effect of Hyalgan to that of placebo using a standard assessment for ADLs.68 This study found no significant improvement in ADLs at 6 months among the Hyalgan-treated group (SMD −0.08 95% CI −0.57, 0.42)

A 1998 study by Altman that compared Hyalgan (5 weekly treatments) to placebo as well as to NSAIDs found that Hyalgan significantly improved WOMAC function at 6 months over placebo but no differences were seen between Hyalgan and NSAIDs.69 This study had a large sample size but a high dropout rate.

Head-to-Head Comparisons of HA. Five trials reported function data and compared one HA to another70,76,77 ,78,80 at 26 weeks. Three of these trials had standard deviations imputed.77,78,80 Since the comparisons were quite heterogeneous, we did not do a meta-analytic pooling.

A 2012 multi-site study by Berenbaum and colleagues that compared the lower-molecular weight Hyalgan to a medium-molecular weight device, GO-ON, reported greater improvement in WOMAC-assessed function at 6 months for the GO-ON treated group than for the Hyalgan group (SMD −0.326, 95% CI −0.52, −0.13).70

Two studies compared Hyalgan to the high-molecular-weight HA, Synvisc.77,80 One very small 2012 Thai study by Khanasuk reported a significant improvement in WOMAC function for single injections of both devices at 6 months, with no difference between the two (SMD 0.053, 95% CI −0.66, 0.77).77 A much larger 2008 UK study by Raman that compared five weekly treatments with Hyalgan (the standard dosing schedule) to three weekly treatments with Synvisc reported a significant and much larger effect for Synvisc than for Hyalgan (SMD −0.882, 95%CI −1.09,−0.68) at 6 months.80

One 2011 study by Pavelka and colleagues compared Synvisc to Sinovial, a medium-molecular weight (800–1200kD) HA of non-avian origin.78 At 12 weeks follow-up, both groups of patients showed the same degree of improvement on the Lequesne index (SMD 0.100, 95%CI −0.11, 0.30). At 6 months’ follow-up, both groups showed a larger improvement in function, this time assessed by the WOMAC function scale, and again, no difference was seen between groups (SMD −0.009 95% CI −0.21, 0.19).

Non-pharmacologic comparisons. Two studies compared the effects of a HA to that of another active treatment. One small UK study that compared Hyalgan to arthroscopic washout of the affected knee found comparable improvement in function (as assessed by the Lequesne index) for both groups at 6 and 12 months (SMD −0.028 95% CI −0.66, 0.61).50

One large 2003 trial in France by Kahan and colleagues compared the effects of a standard dosing schedule of Synvisc with that of conventional treatment (which was not defined by this study, but often indicates a series of treatments of increasing intensity, e.g., NSAIDs and exercise, physical therapy, orthotics, and bracing.75 At 6 months’ follow-up, Synvisc improved function significantly compared with conventional treatment, as assessed with both the WOMAC (SMD −0.567, 95% CI −0.75, −0.39) and the Lequesne index (SMD −0.494, 95% CI −0.67, −0.32).

Percent of Patients Showing Improvement. One of the studies that met inclusion criteria reported the percentage of participants who met prespecified criteria for improvement in function. The 2012 study by Berenbaum and colleagues, which compared the intermediate molecular weight Go-On with the lower molecular weight Hyalgan (see above), assessed the proportion of patients who achieved a minimum clinically important improvement (MCII) in function: 69% of patients who received Go-On and 56% of patients given Hyalgan demonstrated a MCII.70 Seven studies assessed the proportion of patients with patient- or investigator reported global improvement (according to prespecified criteria).70,73,75,76,78,81,82 Four were placebo-controlled (two others were head-to-head comparisons only, and the remaining study compared HA to conventional treatment);73,76,81,82 Of the four placebo-controlled trials (26–52 weeks in duration), three reported increases in the proportion of HA-treated patients who improved (according to themselves or the investigator), compared with the proportion of placebo-treated patients who improved.73,76,81

Effect Duration. Effect duration could not be derived from the identified studies. As described above, the longest followup point for most of the included studies was 6 months; three studies assessed function at 52 weeks. One study that compared the effects of a course of Hyalgan with that of arthroscopic washout through 52 weeks on Lequesne Index score reported that function at 52 weeks was improved over function at baseline in both groups, that function appeared to be continuing to improve at 52 weeks in both groups, and that improvement was not significantly different in the HA-treated group than in the group that underwent washout.50 A study that compared the effect of Hyalectin to that of a saline placebo at 7 weeks and 52 weeks after initiation of treatment, showed that Lequesne Index scores continued to improve through 12 months in both groups but that improvement was significantly greater in the Hyalectin group (p=0.03).49 Finally, a third study compared the effects of Hylan G-F 20 (Synvisc) with that of a lower molecular weight preparation of HA on WOMAC function scores over 52 weeks: Hylan-G-F 20 recipients showed comparable improvement in WOMAC scores from 3 months through 12 months, whereas HA showed a significant improvement only at 3 months.80

Table 6 Summary of studies reporting functional outcomes

Author, Year Location | # Patients (Knees)/ Mean Age (SD)/ Age Range/% Female | Comorbidities | Study Arms | Relevant Outcomes Reported/ Follow Up Times
Grecomoro et al., 1987^83^ Italy | 34(40) Mean age: 64.88 (10.94) % Female: 19/34 | Involvement of both knees: 6/34 | Arm 1: N = 20 knees Mean age: NR Placebo/sham Arm 2: N = 20 knees Mean age: NR Hyalgan Molecular weight: 500K–750K Total treatments: 3 Time between treatment: 1 week
Dixon et al., 1988^68^ UK | 63(NR) Mean age: 68.5 (NR) % Female: 54 | NR | Arm 1: N = 33 Mean age: nr Hyalgan 0.2mg/2 ml Molecular weight: NR Placebo/sham Arm 2: N = 30 Mean age: nr Hyalgan 20mg/2 ml Molecular weight: NR Paracetamol was permitted but NSAIDS, corticosteroids, and strong analgesics were not Total treatments: Varied 1 for first 3 weeks and then 2 | [underlined: ADL/IDLS] (Follow up time: 25 weeks) Arm 1: Hyalgan 0.2mg/2 ml, N=33 Mean change from baseline: −1 (10.5) * Arm 2: Hyalgan 20mg/2 ml, N=30 Mean change from baseline: −1.8 (10.5) * [underlined: Study-level:] ADL/IDLS Standard mean difference: −0.076 (−0.57, 0.42)
Dougados et al., 1993^49^ France | 110 Mean age: 69.0 (10.6) % Female: 71.0 | NR | Arm 1: N=55 Placebo/sham Arm 2: N=55 Hyalectin (Hyalgan) Molecular weight: 500–730 kDa Total treatments: 4 Time between treatment: 1 week | [underlined: Lequesne index] (Follow up time: 52 weeks) Arm 1: Placebo, N=48 Mean change from baseline: −2.7 (4.1) Arm 2: Hyalgan 500–730 kDa, N=47 Mean change from baseline: −4.4 (5.1) [underlined: Number of patients with arthroscopy] (Follow up time: 52 weeks) Arm 1: Placebo, N=48 Count = 5 (10.4%) Arm 2: Hyalgan 500–730 kDa, N=47 Count = 2 (4.3%) [underlined: Study-level]: Lequesne index Standard mean difference: −0.360 (−0.77, 0.04) Number of patients with arthroscopy OR: 0.409 (0.09, 1.89)
Henderson et al., 1994^84^ UK | 91(NR) Mean age: NR (NR) % Female: 69 | Involvement of both knees: >99% | Arm 1: N = 20 (Severity group I) Mean age: 60.0(1.9) Placebo/sham Arm 2: N = 26 Severity Group 2 Second placebo group Arm 3: N = 18 Severity Group 1 Mean age: 63.9(1.9) Hyalgan (20mg/2mL) Molecular weight: NR Arm 4: N = 26 Severity Group 2 Mean age: 67.0(1.7) Hyalgan Total treatments: 5 Time between treatment: 1 week
Altman et al., 1998^69^ US | 495(NR) Mean age: 64 (10 (whole group)) % Female: 57 | NR | Arm 1: N = 115 Mean age: 65 (10) Placebo/sham Acetaminophen up to 4000mg /day permitted as rescue Arm 2: N = 105 Mean age: 62(10) Hyalgan 20mg/2ml Molecular weight: 500–730kD Oral placebo for naproxen twice daily and Acetaminophen up to 4000mg/day permitted as rescue Arm 3: N = 113 Mean age: 63(9) NSAID Total treatments: 5 Time between treatment: 1 week | [underlined: WOMAC physical function] (Follow up time: 26 weeks) Arm 1: Placebo, N=115 Arm 2: Hyalgan 20mg/2ml 500–730kD, N=105 Arm 3: NSAIDs, N=113 [underlined: Study-level]: WOMAC physical function HA group improvement more than placebo group p=0.047
Huskisson et al., 1999^74^ United Kingdom | 100(NR) Mean age: nr (nr) % Female: 67 | | Arm 1: N = 50 Mean age: 64.8 (9.3) Placebo/sham Arm 2: N = 50 Mean age: 65.8 (8.8) Hyalgan Molecular weight: 500–730 kDa Total treatments: 5 Time between treatment: 1 week | [underlined: Lequesne functional index] (Follow up time: 26 weeks) Arm 1: Placebo, N=41 Mean change from baseline: −1.4 (7.8) Arm 2: Hyalgan 500–730 kDa, N=40 Mean change from baseline: −2.2 (7.9) [underlined: Study-level]: Lequesne functional index Standard mean difference: −0.101 (−0.54, 0.34)
Roman et al., 2000^85^ Spain | 49 Mean age: 65.14 (9.77) % Female: 83.7 | NR | Arm 1: N = 30 Mean age: NR Adant Molecular weight: 900 kD Arm 2: N = 19 Mean age: NR Hyalgan Molecular weight: 800 kD Total treatments: 5 Time between treatment: 1 week
Brandt et al., 2001^71^ US | 226(NR) Mean age: NR (NR) % Female: 63 | Involvement of both knees: HA: 78% Saline: 88% | Arm 1: N = 112 Mean age: 67(8.4) Placebo/sham Arm 2: N = 114 Mean age: 65(8.4) Orthovisc (2 mL, 15mg/mL) Molecular weight: 1000–2900 kD (considered high MW) Total treatments: 3 Time between treatment: 1 week | [underlined: WOMAC function] (Follow up time: 27 weeks) Arm 1: Placebo, N=69 Mean change from baseline: −9.8 (15.1) * Arm 2: Orthovisc (2 mL, 15mg/mL) 1000–2900 kD (considered high MW), N=66 Mean change from baseline: −14.7 (15.1) * [underlined: Study-level]: WOMAC function Standard mean difference: −0.323 (−0.66, 0.02)
Tamir et al., 2001^86^ Israel | 49 Mean age: 71 (NR) % Female: 73.5 | NR | Arm 1: N = 24 Mean age: 70 Placebo/sham Arm 2: N = 25 Mean age: 71 Bio-Hy Molecular weight: 3000 kDa Total treatments: 5 Time between treatment: 1 week
Karlsson et al., 2002^76^ Sweden | 246(NR) Mean age: reported by arm below (reported by arm below) % Female: 61 | NR | Arm 1: N = 66 (57 PP) Mean age: 71(6) Placebo/sham Arm 2: N = 92 (76 PP) Mean age: 72(7) Artzal (2.5 ml 1% hyaluronan) Molecular weight: 1,000 kDa Arm 3: N = 88 (77 PP) Mean age: 70(7) Synvisc (2 ml 0.8%) Molecular weight: 7,000 kDa Total treatments: 3 Time between treatment: 1 day | [underlined: Lequesne algofunctional index] (Follow up time: 26 weeks) Arm 1: Placebo, N=57 Mean change from baseline: −4.7 (4.4) Arm 2: Artzal (2.5 ml 1% hyaluronan) 1,000 kDa, N=76 Mean change from baseline: −3.9 (4.6) Arm 3: Synvisc (2 ml 0.8%) 7,000 kDa, N=77 Mean change from baseline: −4.4 (4.1) [underlined: WOMAC physical function] (Follow up time: 26 weeks) Arm 1: Placebo, N=57 Mean change from baseline: −11.1 (14.8) * Arm 2: Artzal (2.5 ml 1% hyaluronan) 1,000 kDa, N=76 Mean change from baseline: −7.3 (14.9) * Arm 3: Synvisc (2 ml 0.8%) 7,000 kDa, N=77 Mean change from baseline: −11.7 (14.7) * [underlined: Study-level]: WOMAC physical function Standard mean difference: 0.260 (−0.09, 0.60) Arms 2 vs 1 WOMAC physical function Standard mean difference: −0.297 (−0.62, 0.02) Arms 3 vs 2 Lequesne algofunctional index Standard mean difference: 0.176 (−0.17, 0.52) Arms 2 vs 1 Lequesne algofunctional index Standard mean difference: −0.115 (−0.43, 0.20) Arms 3 vs 2
Petrella et al., 2002^79^ Canada | 120 Mean age: 65.5 (9.5) % Female: 45.8 | Involvement of both knees: 0% | Arm 1: N = 28 Mean age: 62.6 (9.5) Placebo/sham Arm 2: N = 25 Mean age: 67.3 (8.9) Suplasyn Molecular weight: NR Placebo pill Arm 3: N = 29 Mean age: 65.0 (9.7) Suplasyn Molecular weight: NR NSAID Arm 4: N = 26 Mean age: 66.3 (8.8) NSAID Total treatments: 3 Time between treatment: 1 week | [underlined: WOMAC disability] (Follow up time: 4 weeks) Arm 1: Placebo, N=28 Mean change from baseline: −0.99 (3) Arm 2: Suplasyn NR, N=25 Mean change from baseline: −1.65 (2.5) Arm 3: Suplasyn+NSAIDs NR, N=29 Mean change from baseline: −1.17 (2.7) Arm 4: NSAIDs, N=26 Mean change from baseline: −1.56 (2.8) [underlined: Study-level:] WOMAC disability Standard mean difference: −0.234 (−0.77, 0.31)
Forster et al., 2003^50^ UK | 38 Mean age: 61.5 (NR) % Female: NR | NR | Arm 1: N = 19 Mean age: 63 Arthroscopic washout Arm 2: N = 19 Mean age: 60 Hyalgan Molecular weight: 500–730 kD Total treatments: 5 Time between treatment: 1 week | [underlined: Lequesne index] (Follow up time: 26 weeks) Arm 1: Arthroscopic washout, N=19 Mean change from baseline: −1 (25) * Arm 2: Hyalgan 500–730 kD, N=19 Mean change from baseline: −1.5 (6) * [underlined: Number of patients with arthroscopy] (Follow up time: 52 weeks) Arm 1: Arthroscopic washout, N=15 Count = 3 (20%) Arm 2: Hyalgan 500–730 kD, N=17 Count = 2 (11.8%) [underlined: Study-level:] Lequesne index Standard mean difference: −0.028 (−0.66, 0.61) Number of patients with arthroscopy OR: 0.546 (0.08, 3.59)
Kahan et al., 2003^75^ France | 506 Mean age: 66 (10) % Female: 67.5 | Involvement of both knees: 74 | Arm 1: N = 253 Mean age: 66 (10) Conventional treatment Arm 2: N = 253 Mean age: 66 (10) Synvisc Molecular weight: NR Total treatments: 3 Time between treatment: 1 week | [underlined: Lequesne index] (Follow up time: 26 weeks) Arm 1: Conventional treatment, N=253 Mean change from baseline: −1.6 (4) Arm 2: Synvisc, N=253 Mean change from baseline: −3.6 (4.1) [underlined: WOMAC function] (Follow up time: 26 weeks) Arm 1: Conventional treatment, N=247 Mean change from baseline: −7 (20.6) Arm 2: Synvisc, N=251 Mean change from baseline: −18.4 (19.6) [underlined: Study-level:] Lequesne index Standard mean difference: −0.494 (−0.67, −0.32) WOMAC function Standard mean difference: −0.567 (−0.75, −0.39)
Leopold et al., 2003^87^ US | 100(NR) Mean age: NR (NR) % Female: CS: 56 HA: 52 | NR | Arm 1: N = 42 Mean age: 64 Arm 2: N = 38 Mean age: 66 Hylan G-F 20 (16mg/2ml) Total treatments: 3 HA 1CS Time between treatment: 1 week
Pham et al., 2004^82^ France | 301 Mean age: 64.9 (7.7) % Female: 65 average | NR | Arm 1: N = 85 Mean age: 64.9 (7.7) Placebo/sham Arm 2: N = 131 Mean age: 71.0 NRD101 Molecular weight: 1.900 kDa Arm 3: N = 85 Mean age: 64.5 Diacerein Total treatments: 12? (3 course every 3 months for a year) Time between treatment: 1 week | [underlined: Lequesne’s algofunctional index] (Follow up time: 52 weeks) Arm 1: Oral placebo+saline, N=85 Mean change from baseline: 10.5 (3.1) Arm 3: NRD101 1.900 kDa, N=131 Mean change from baseline: 11.1 (2.8) [underlined: Study-level:] Lequesne’s algofunctional index Standard mean difference: −0.070 (−0.34, 0.21)
Blanco et al., 2008^51^ Spain | 42 Mean age: 68.3 ((9.1)) % Female: 76 | NR | Arm 1: N = 20 Mean age: 68.3(9.1) Placebo/sham Paracetamol and/or diclofenac as rescue analgesics Arm 2: N = 22 Mean age: 67.5(8.1) Adant Molecular weight: 900 kDa Total treatments: 10 (2 cycles of 5 weekly injections, separated by 24 weeks) Time between treatment: 1 week | [underlined: Number of patients with knee surgery] (Follow up time: 24 weeks) Arm 1: Placebo, N=23 Count = 20 (87%) Arm 2: Adant 900 kDa, N=25 Count = 16 (64%) [underlined: Physical function WOMAC] (Follow up time: 24 weeks) Arm 1: Placebo, N=20 Mean change from baseline: −4.4 (18.8) Arm 2: Adant 900 kDa, N=22 Mean change from baseline: −24.7 (18) [underlined: Study-level:] Physical function WOMAC Standard mean difference: −1.080 (−1.74, −0.43) Number of patients with knee surgery OR: 0.300 (0.08, 1.10)
Lundsgaard et al., 2008^81^ Denmark | 251 Mean age: 69.6 (7.27) % Female: 52.4 | NR | Arm 1: N=84 Saline 2ml Arm 2: N=83 Saline 20 mL, no hyaluronate Arm 3: N=84 Hyalgan Molecular weight: NR Total treatments: 4 Time between treatment: 1 week | [underlined: KOOS activities] (Follow up time: 26 weeks) Arm 1: Saline 2ml, N=84 Mean change from baseline: −5 (16.3) Arm 2: Saline 20 mL, no hyaluronate, N=83 Mean change from baseline: −5.2 (15.1) Arm 3: Hyalgan 500 – 730 kD, N=84 Mean change from baseline: −4.4 (15.7) [underlined: KOOS quality of life] (Follow up time: 26 weeks) Arm 1: Saline 2ml, N=84 Mean change from baseline: −6.4 (15.7) Arm 2: Saline 20 mL, no hyaluronate, N=83 Mean change from baseline: −7.1 (12.1) Arm 3: Hyalgan 500 – 730 kD, N=84 Mean change from baseline: −3.4 (15.4) [underlined: Study-level:] KOOS activities Standard mean difference: 0.037 (−0.27, 0.34) KOOS quality of life Standard mean difference: −0.193 (−0.50, 0.11)
Petrella et al., 2008^88^ Canada | 200 Mean age: 71 (8) % Female: 30 | NR | Arm 1: N = 50 Mean age: 71+/−8 Placebo/sham Arm 2: N = 50 Mean age: 68+/−6 HA dual molecular weight Molecular weight: 580–780 kDa+1.2 to 2.0 million kDa Arm 3: N = 50 Mean age: 69+/−5 HA low molecular weight Molecular weight: 500–730 kDa Arm 4: N = 50 Mean age: 71+/9 HA high molecular weight Molecular weight: 6 million kDa Total treatments: 3 Time between treatment: 1 week
Raman et al., 2008^80^ UK | 392 Mean age: 67.2 (NR) % Female: 68 | NR | Arm 1: N = 199 Mean age: NR Synvisc (Hylan GF 20) Molecular weight: 6000 kD Arm 2: N = 193 Mean age: NR Hyalgan Molecular weight: 500 – 730 kD Total treatments: 3 for Synvisc, 5 for Hyalgan Time between treatment: 1 week | [underlined: EQ-5D] (Follow up time: 26 weeks) Arm 1: Synvisc (Hylan GF 20) 6000 kD, N=199 Mean change from baseline: −12 (25) * Arm 2: Hyalgan 500 – 730 kD, N=193 Mean change from baseline: 1 (25) * [underlined: WOMAC physical activity] (Follow up time: 26 weeks) Arm 1: Synvisc (Hylan GF 20) 6000 kD, N=199 Mean change from baseline: −21.8 (17) * Arm 2: Hyalgan 500 – 730 kD, N=193 Mean change from baseline: −6.8 (17) * [underlined: Study-level:] WOMAC physical activity Standard mean difference: −0.882 (−1.09, −0.68) EQ-5D Standard mean difference: −0.520 (−0.72, −0.32)
Huang et al., 2011^73^ Taiwan | 200(NR) Mean age: 65.0 (8.3) % Female: 76 | NR | Arm 1: N = 100 Mean age: 64.2(8.4) Placebo/sham Arm 2: N = 100 Mean age: 65.9(8.1) Hyalgan (20mg/2ml) Total treatments: 5 Time between treatment: 1 week | [underlined: WOMAC function] (Follow up time: 25 weeks) Arm 1: Placebo, N=98 Mean change from baseline: −18.2 (16.7) Arm 2: Hyalgan (20mg/2ml), N=100 Mean change from baseline: −25.16 (16.7) [underlined: Study-level:] WOMAC function Standard mean difference: −0.415 (−0.70, −0.13)
Pavelka et al., 2011^78^ Czech Republic, France, Italy, Switzerland, the Slovak Republic and Germany | 381 Mean age: 65 (9) % Female: 72.9 | Involvement of both knees: 66% | Arm 1: N = 192 Mean age: 65.1 (9.1) Synovial Molecular weight: 800 – 1,200 kD Arm 2: N = 188 Mean age: 64.9 Synvisc Molecular weight: 6,000 kD Total treatments: 3 Time between treatment: 1 week | [underlined: Lequesne algofunctional index] (Follow up time: 12 weeks) Arm 1: Synovial 800 – 1,200 kD, N=192 Mean change from baseline: −3.9 (5.2) Arm 2: Synvisc 6,000 kD, N=188 Mean change from baseline: −3.4 (5.2) [underlined: WOMAC function] (Follow up time: 26 weeks) Arm 1: Sinovial 800 – 1,200 kD, N=192 Mean change from baseline: −28 (21.8) * Arm 2: Synvisc 6,000 kD, N=188 Mean change from baseline: −28.2 (21.7) * [underlined: Study-level:] WOMAC function Standard mean difference: −0.009 (−0.21, 0.19) Lequesne algofunctional index Standard mean difference: 0.100 (−0.11, 0.30)
Petrella et al., 2011^89^ Canada | 200 Mean age: 70 (8) % Female: 57 | NR | Arm 1: N = 50 Mean age: 71 (8) Placebo/sham Arm 2: N = 50 Mean age: 68 (6) sodium hyaluronate Molecular weight: Combined high & low weight Arm 3: N = 50 Mean age: 69 (5) sodium hyaluronate - low weight Molecular weight: 500–730 KDa Arm 4: N = 50 Mean age: 71 (9) sodium hyaluronate - high weight Molecular weight: 6000 KDa Total treatments: 3 Time between treatment: 1 week
Berenbaum et al., 2012^70^ France, Germany | 426(NR) Mean age: 67 (NR) % Female: 63 | | Arm 1: N = 209 Mean age: 66.1 (8.1) Hyalgan Molecular weight: 500 kD–730 kD NSAID or paracetamol up to 4g/d as permitted as rescue medication Arm 2: N = 217 Mean age: 67.2 (7.8) GO-ON (2.5 ml, 10mg/ml) Molecular weight: 800 kD–1500 kD NSAID or paracetamol up to 4g/d as permitted as rescue medication Total treatments: 3 Time between treatment: 3 weeks | [underlined: Lequesne index] (Follow up time: 26 weeks) Arm 1: Hyalgan 500 kD–730 kD, N=209 Mean change from baseline: −3 (3.7) Arm 2: GO-ON (2.5 ml, 10mg/ml) 800 kD–1500 kD, N=217 Mean change from baseline: −4.2 (3.8) [underlined: WOMAC function] (Follow up time: 26 weeks) Arm 1: Hyalgan 500 kD–730 kD, N=209 Mean change from baseline: −15.4 (19.9) Arm 2: GO-ON (2.5 ml, 10mg/ml) 800 kD–1500 kD, N=217 Mean change from baseline: −22.2 (21.8) [underlined: Study-level:] WOMAC function Standard mean difference: −0.326 (−0.52, −0.13) Lequesne index Standard mean difference: −0.320 (−0.51, −0.13)
DeCaria et al., 2012^72^ Ontario Canada | 30(na) Mean age: NR (NR) % Female: 47 | NR | Arm 1: N = 15 Mean age: 72.93 (5.48) 500 mg acetaminophen to be taken up to 4g/day as rescue medication Placebo/sham 1.2 ml 0.001 mg/ml inert HA Arm 2: N=15 Hyaluronic acid (2 ml, 20 mg/ml) Molecular weight: 730 kD 500 mg acetaminophen to be taken up to 4g/day as rescue medication Total treatments: 3 Time between treatment: 1 week | [underlined: WOMAC function] (Follow up time: 26 weeks) Arm 1: Placebo, N=15 Mean change from baseline: −3.53 (10.15) Arm 2: Hyaluronic Acid 730 kD, N=15 Mean change from baseline: −9.07 (8.14) [underlined: Study-level:] WOMAC function Standard mean difference: −0.586 (−1.32, 0.15)
Khanasuk et al., 2012^77^ Thailand | 32(NR) Mean age: NR (NR) % Female: 80 | NR | Arm 1: N = 15 Mean age: 65.1(9.6) Hylan GF-20 (Synvisc)(single 6 ml injection) Molecular weight: Reported as High Arm 2: N = 15 Mean age: 67.0(9.5) Hyalgan (single injection Molecular weight: Reported as Low Total treatments: 1 | [underlined: SF-36 PCS] (Follow up time: 26 weeks) Arm 1: Synvisc (single 6 ml injection), N=15 Mean change from baseline: −6 (25) * Arm 2: Hyalgan (single injection, N=15 Mean change from baseline: −4 (25) * [underlined: WOMAC function] (Follow up time: 26 weeks) Arm 1: Synvisc (single 6 ml injection) Reported as High, N=15 Mean change from baseline: −20 (37.5) * Arm 2: Hyalgan (single injection Reported as Low, N=15 Mean change from baseline: −22 (37.5) * [underlined: Study-level:] WOMAC function Standard mean difference: 0.053 (−0.66, 0.77) SF-36 PCS Standard mean difference: −0.080 (−0.80, 0.64)

Figure 3 Forest Plots for Comparisons of the Effect of Hyaluronic Acid Treatment with Placebo on function (WOMAC, Lequesne, or KOOS) at 26 Weeks Follow-up:* a. studies arranged chronologically, b. studies arranged by product molecular weight

*Follow-up time for Petrella is 4 weeks and for Dougados and Pham it is 52 weeks

Figure 3. Forest Plot for Comparisons of the Effect of Hyaluronic Acid Treatment with Placebo on function (WOMAC, Lequesne, or KOOS) at 26 Weeks Follow-up* This figure, known as a forest plot, displays the effect size (outcome) for the comparison of the effect of hyaluronic acid treatment with that of placebo on function at 26 weeks follow-up. The first column shows the 8 studies that reported this outcome. The second column states the treatment name. The third column provides the molecular weights of the devices used in each study. The fourth column shows the graph: each outcome is shown relative to the vertical line that represents no difference between placebo and active treatment; the graph also shows the pooled estimate and its 95 percent confidence intervals (CI). The fifth column is the standard mean difference given for each study. Results for each study are in Table 6.

Figure 4 Risk of Bias Assessment on Randomized Controlled Trials

Legend:

Unclear=[image]

Low risk of bias=[image]

High risk of bias=[image]

Figure 4. Risk of Bias Assessment on 21 Randomized Controlled Trials Figure 4 gives the risk-of-bias (study quality) ratings for each of the criteria considered to assess study quality (adapted from the Cochrane Risk of Bias criteria) for the 21 randomized controlled trials included in the report. The criteria being assessed include random sequence generation (selection bias), allocation concealment (selection bias), blinding of participants, blinding of personal/providers, blinding of outcome assessors, incomplete outcome data (dropout rate less than 20%), incomplete outcome data addressed (attrition bias; Loss to follow-up missing or explained), selective reporting (reporting bias), and several additional sources of bias: standardized measurement tool used, washout period of at least 3 months for steroid injections or 6 months for Hyaluronic acid, co-interventions either avoided in the trial design or the authors ensured that they were similar between the index and control group, and complete outcome data. For each item, raters assign a score of low, high, or unclear risk of bias.

## Intra-articular injection of hyaluronic acid and quality of life

Three randomized trials were identified that assessed quality of life.

### Description of included studies

A 2008 randomized trial that compared treatment with Hyalgan to treatment with two different volumes of saline assessed quality of life using the KOOS quality-of-life component.81 A head-to-head trial that compared Synvisc with Hyalgan assessed quality of life using the SF-36 mental component summary,77 and a second head-to-head trial that compared Synvisc with Hyalgan assessed health-related quality of life using the EuroQol-5D index80

### Key Points

- Three trials that compared HA to saline or to another HA found no differences in quality of life or health-related quality of life between the two groups at 6 months follow-up.
- In one head to head trial of Synvisc and Hyalgan, health-related quality of life was improved in the Synvisc group from 3 weeks through the final follow-up at 12 months post-treatment.

### Detailed Synthesis

Two trials77,80 that compared Hyalgan to Synvisc and one trial81 that compared Hyalgan to saline reported on quality of life or health-related quality of life.69 All three needed to have standard deviations imputed. A meta-analytic pooling was not done since we did not have three trials with similar comparisons.

A 2008 randomized placebo-controlled trial of Hyalgan in 251 Danish adults (mean age 69, minimum age 59) assessed quality of life with the KOOS measure.81 No significant improvement was seen at 6 months compared with baseline, and there was no difference among the groups (−0.193 95% CI −0.496, 0.110), as was seen for the assessment of KOOS function.

A 2008 UK head-to-head trial comparing Hyalgan with Hylan GF-20 (Synvisc) in 393 OA patients found a significant increase in health-related quality of life at 3 months, as measured by the EuroQol EQ-5D, which was greater for the Hylan GF-20 group (−0.52 95% CI −0.72, −0.32), paralleling the WOMAC physical activity subscores, as reported above; the effect on EQ-5D score was sustained until 12 months in the Synvisc group but not the Hyalgan group.80 However a small 2012 trial in Thailand that compared the same devices among 32 patients found no improvement in quality of life in either group, as measured by the SF-36, (−0.08 95% CI −0.80, 0.64) (compared with WOMAC physical function scores, which improved equally in both groups).77

None of the three studies conducted subgroup analysis to assess possible contributing factors (such as age, disease severity, or comorbidities) to the response of quality of life to treatment with HA.

## Intra-articular injection of hyaluronic acid and pain

### Description of included studies

We identified a number of articles described as systematic reviews that summarized trials of the effects of HA on pain. One good quality 2012 review summarized the entire body of trials that compared the effects of HA with those of a sham or nonintervention control on pain; this review also included separate analysis for double-blind placebo control trials and stratified analyses for a number of potential effect modifiers. We summarize the results of this review below.17 We then identified a 2015 network meta-analysis comparing the effectiveness of pharmacological interventions and HA for knee OA.42 We summarize the results of this review as well. Many of the remaining systematic reviews are summarized in the Discussion chapter.16,17,90–93 We identified no double-blind placebo controlled randomized trials that reported the effects of HA on pain only in individuals 65 and over, and no such studies in individuals of average age 65 and over that were published subsequent to these systematic reviews; however we did identify two randomized head-to-head trials that compared the effects of two different HA products on pain in individuals of average 65 or over. These two studies are summarized below.

### Key Points

- A large, 2012 comprehensive systematic review of RCTs that assessed the effects of HA on pain in 71 RCTs (with either sham or non-sham controls) reported that HA injections significantly reduce pain when assessed at 3 months (−0.37, 95% CI −0.46, −0.28) and the effect met the criterion for a minimum clinically important difference (MCID, −0.37, which corresponds to 9 mm on a VAS scale of 0 to 100mm). When the reviewers performed a subgroup analysis that included only the 18 sham-controlled, assessor-blinded studies with sample size of 100 or more per intervention group in the pooled analysis, the effect of HA was still statistically significant (−0.11, 95% CI −0.18, −0.04), but no longer met the criterion of clinical importance. A stratified analysis comparing the effect size for all 54 studies with a sham control (regardless of size) with that of the 18 studies with a non-sham comparison obtained a pooled effect size for the sham-controlled studies of −0.34 (95% CI −0.44, −0.24), nearly equal to that for the entire group of studies and to the MCID.
- A 2015 network meta-analysis of 129 RCTs that compared the effects of oral and intraarticular pharmacologic agents, HA, and placebo on pain (52 studies compared HA with placebo and 12 compared HA with steroids) reported a significant effect size of HA compared with placebo (−0.34; 95% CI −0.42, −0.26), exceeding the prespecified absolute MCID of −0.20, based on the OMERACT-OARSI responder criteria; sensitivity analysis showed that limiting study size to 50 or more did not change the effect size but limiting the analysis to studies of 100 or more did reduce the effect size.
- No new placebo-controlled trials were identified that were not already included in the systematic review by Rutjes and colleagues or that of Bannuru and colleagues, enrolled patients of average age 65 and older, and reported on pain outcomes.
- Two new head-to-head trials compared the effects of two different HAs on pain in individuals of average age 65 or over and were not included in prior SRs. One found that single injections of a high- and low-molecular weight were equally effective in reducing pain and improving function at 6 months (with no change in quality of life), whereas another found that three injections of an intermediate molecular weight might be superior to low molecular weight HA over 6 months (with respect to reducing pain and improving function).

### Detailed Synthesis

#### Systematic review

Two systematic reviews of good to high quality, published in 2012 and 2015, were identified that compared the effects of intra-articular HA with some other intervention on pain; the quality of the reviews was assessed with AMSTAR (Table 7).17,42

The 2012 systematic review and meta-analysis by Rutjes and colleagues, which identified 89 published and unpublished randomized trials of HA with any control, assessed the effects on pain intensity.17 Of the 89 trials, the authors were able to pool 71 sham or non-intervention controlled trials (9,617 patients), obtaining an effect size of −0.37 (95%CI −0.46, −0.28), which just met their prespecified minimal clinically important difference. Pooling 18 of the larger (sample size greater than 100 per intervention group) assessor-blinded trials showed a statistically significant but clinically irrelevant effect size of −0.11(95%CI −0.18, −0.04). A stratified analysis that compared the pooled effect size for the 54 studies with a sham control with that of 18 studies with a non-sham intervention found a pooled effect size for studies with a sham control of −0.34 (95% CI −0.44, −0.24).

A 2015 network meta-analysis of 129 RCTs by Bannuru and colleagues42 compared the effects of oral and intraarticular pharmacologic agents, intraarticular HA, and placebo (oral and intraarticular) on pain. Pooling 52 studies that compared HA with placebo at 3 months’ follow-up showed a significant effect size of HA compared with placebo (−0.34; 95% CI −0.42, −0.26). This effect size was the highest for any agent assessed (all but CS were oral agents, and exceeded the prespecified absolute MCID of −0.20, based on the OARSI-OMERACT responder criteria. Sensitivity analysis showed that limiting study size to 50 or more did not change the effect size but limiting the analysis to studies of 100 or more did reduce the effect size.

Table 7 AMSTAR Assessment for Systematic Reviews of HA and Pain^*^

Study | A priori design | Duplicate screening and extraction | Comprehensive search | Grey literature inclusions | Included/excluded studies listed | Study characteristics | Quality assessment | Quality considered | Pooling appropriate | Publication bias | COI assessment
Rutjes, 2012^17^ | C^#^ | Y | Y | Y | Y | N | Y | C | Y | Y | C
Bannuru, 2015^42^ | C | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y

* See Appendix D for assessment tool. Y=yes (low risk); N=no (high risk);C=can’t respond; NA=not applicable; COI conflict of interest;

# need to access supplemental files

#### Original studies

No new placebo-controlled trials were identified that enrolled patients of average age 65 and older, and reported on pain outcomes and were not already included in the systematic reviews by Rutjes and colleagues or Bannuru and colleagues. Two randomized trials were identified that were not included in either review, enrolled populations of OA patients of average age 65 or over, and assessed the effects of two different HA products head-to-head on pain.

A multi-center trial in France and Germany compared the effects of three weekly injections of GO-ON, a non-avian medium-molecular weight HA (1800–1500kD) with those of Hyalgan, a low molecular weight product on pain in 426 patients.70 Mean differences in WOMAC pain change were 5.2(95% CI 0.9, 9.6) per protocol and 4.5 (95% CI 0.5, 8.5) (intention to treat) at 6 months, favoring GO-ON. Also, a higher proportion of patients responded to GO-ON than to Hyalgan: 70.5% of participants receiving GO-ON and 58.4% of participants receiving Hyalgan exceeded the prespecified MCII for pain. These differences paralleled the effects of the two devices on function as assessed by both the WOMAC (difference in effect size: −6.8, 95% CI −10.7, −2.8) and Lequesne indices (−1.2, 95% CI −2.0, −0.6), as described earlier in this report.

A Thai study compared the effects of a single injection of Hylan G-F 20 (Synvisc) and a single injection of Hyalgan on pain at 6 months in 30 patients. The WOMAC pain and function subscales showed significant improvement with no differences between the treatments at 6 months. QoL, as assessed by the SF-36, did not change over the same 6-month period.77

## Intra-articular injection of hyaluronic acid and adverse events

### Description of included studies

Twenty four trials, four large cohort and case series studies, and 18 case reports were identified that reported on the incidence of adverse events among individuals 65 years of age and over.

### Key Points

- In 24 placebo-controlled trials of HA, serious adverse events were small in number. Estimates are imprecise, and the magnitude of any increase in risk is very small, if present at all. The rate of non-serious AEs was higher but did not differ significantly between the HA-treated and placebo-control groups.
- Among four large cohort studies and case series, representing nearly 6,000 recipients of HA (some more than one series), one serious adverse event was reported: severe swelling and synovial fluid accumulation.
- Eighteen case reports provided reports of adverse events among 30 individuals 65 years of age or older, including five cases of sepsis (one case of staphylococcus scalded skin syndrome), and one case each of saphenous nerve injury, eosinophiluria, erythema, and herpes zoster (new onset).

### Detailed Synthesis

Adverse events reported in trials. Twenty four trials reported data on adverse events (AEs).49,51,68–89 Thirteen trials49,51,71–74,80–84,86,88 compared Hyalgan to placebo, and seven68,70,75,77,78,85,87 compared Hyalgan to an active comparator. Four trials69,76,79,89 reported data on both comparison types.

Only the placebo comparisons had enough trials within adverse event categories to pool. The results are presented in Table 8. With the assistance of a rheumatologist, we grouped the adverse events into three groups based on their site (injection site, joint [intra-articular], or other [including systemic]) and within each of the three groups, we further divided events according to whether they were serious or not serious. Examples of each type of event are also provided in Table 8.

The RCTs included in the AE analyses were assessed using items from the McHarm scale (Table 10).35 Out of 24 RCTs, four described a protocol for collecting AEs or a predefined set of AEs; the remaining 20 were unclear or indicated no predefined list of AEs. To elaborate, these 20 studies did not describe whether assessors asked patients about specific AEs on a list. Four of 24 studies described an active form of AE collection; the remainder used a passive form of AE assessment (e.g., they asked patients something more generic such as “have you experienced any adverse reactions?”) or did not describe how AEs were assessed. Fourteen of the 24 RCTs did describe assessing AEs at prespecified intervals (e.g., at follow-up appointments). In addition, eight studies reported that no serious adverse events occurred, without defining the term “serious adverse events.” However, as these weaknesses apply to both the active and placebo arms (assessors were blinded to study arm), any systematic undercounting of AEs would apply to both arms and have little effect on the relative difference.

Table 8 Pooled adverse events reported in trials, according to category

AE Group | # studies | # event HA | sample size HA | # events placebo | sample size placebo | OR | 95% CI
local, not serious (e.g., erythema) | 6 | 79 | 493 | 98 | 492 | 0.70 | (0.48, 1.03)
joint, serious (e.g., synovitis) | 5 | 8 | 447 | 10 | 442 | 0.77 | (0.25, 2.31)
joint, not serious (e.g., pain) | 7 | 97 | 518 | 121 | 559 | 0.83 | (0.60, 1.15)
other, serious (e.g., Herpes zoster) | 6 | 8 | 570 | 17 | 614 | 0.62 | (0.23, 1,57)
other, not serious (e.g., headache) | 6 | 199 | 553 | 196 | 594 | 1.26 | (0.94, 1.68)

Adverse Events reported in observational studies. In order to further investigate rare adverse events that may not have occurred during clinical trials, we searched for cohort studies that reported AEs and cases reported post-licensure.

We identified four observational studies with at least 500 subjects each that reported adverse events in patients receiving hyaluronic acid for knee osteoarthritis. Due to heterogeneity, the results are described narratively.

Petrella94 published on a cohort of 537 hyaluronic acid-naïve patients who received at least one series of three injections of Suplasyn (500 – 730 kD) in a primary care center in Ontario, Canada. All had unilateral osteoarthritis of the knee with Kellgren-Lawrence grade 1 to 3; mean age was 68 years. All but 21 patients returned for a second series of three injections. Patients were followed for a mean of 6.7 years. The study was supported by the Canadian Institutes of Health; Suplaysn was purchased by the patients and was not subsidized by the manufacturer. The primary outcome studied was pain in walking, as measured using the VAS. No serious AEs were reported, and there were no systemic (not local or intra-articular) AEs. Local AEs were observed following 1.48% and 1.32% of injections with the first and second series respectively. The authors provided no information on whether AEs were assessed passively or actively.

Kemper and colleagues95 reported on 4,253 patients of 840 orthopedic surgeons in Germany. Patients received injection of Synvisc (6000 kD) at three visits; Kellgren-Lawrence grades were not reported; 8.1% of patients had previously received hyaluronic acid injections. Mean age of the patients was 63.9 years, 60.8% were female, and 23.7% had bilateral osteoarthritis. AEs were actively elicited, serious AEs were clearly defined, and MEDRA coding was used. Adverse events were reported in 5.3% of patients and 2.9% of injections. Only one serious AE was reported; this event involved severe swelling and synovial fluid accumulation. The most commonly reported AEs were joint effusion (2.4% of patients), joint swelling (1.3%), arthralgia (1.2%), joint warmth (0.6%) and injection site erythema (0.3%). Secondary analyses were performed; surprisingly, patients younger than 70 years old were more likely to experience an AE than were older patients. Those with a longer time since diagnosis and those previously treated with viscosupplementation were also more likely to experience an AE. The product manufacturer sponsored the study; two of their scientists were co-authors.

In a large retrospective cohort study Petrella96 compared the safety of avian and non-avian hyaluronic acid for osteoarthritis of the knee. They included 1,726 patients who received avian HA and 1,971 who received non-avian HA at a large center in Canada from 1997 to 2007. Patients had Kellgren-Lawrence grade 1 to 3 evidence of knee OA; mean age was 65 years. There were no significant differences in baseline demographic characteristics or severity between groups. The group receiving avian HA had a significantly higher rate of adverse events (4.8% versus 1.7%) between the second and 10^th^ series than the group receiving non-avian HA. Rates of specific events were not reported; pain, effusion, and erythema were noted as most common. No serious adverse events were reported.

Finally, Waddell and Bricker97 published a case series of 1,158 patients in a large orthopedic practice in the US. The primary goal of the study was to assess AEs. The patients received at least one series of three injections of Synvisc. The mean age (65.8 years) and gender composition (60.6% female) were similar to the other two studies. However, the patients’ osteoarthritis of the knee was more severe; 70.9% of knees were grade four on the Kellgren-Lawrence scale, and 44.6% of patients had bilateral OA. The authors provided details on treatment method that were not reported in the other studies. A fluoroscopic technique that confirms accurate needle placement was used. To avoid local AEs, they instructed patients to rest the afternoon of the injection and use an ice pack for two to three hours. In addition, they provided patients with a prescription opioid to use if needed. Finally, they prophylactically administered an intramuscular steroid in patients who had previously experienced knee pain and swelling with injection. Local AEs were reported in 4.7% of patients (1.3% of injections) during Course 1, 13.8% of patients (4.5% of injections) during Course 2, and 17.3% of patients (5.6% of injections) during Course 3. Non-local AEs were not reported. Both authors had received previous funding from the product manufacturer, who provided support for statistical analysis and a medical writer for the manuscript. In a 2014 followup to this study, Waddell and Joseph tracked the incidence of synovitis (knee pain and swelling) over multiple treatment courses.58 The incidence was 3.5% (65/1,863 patients) following course 1, 9.5% (81/849) following course 2, 12.9% (46/356) following course 3, 12.1% (19/157) following course 4, 23.8% (15/63) following course 5, and 6.7% (2/30) following course 6. Nearly all cases were considered mild or moderate, and none were considered serious enough to require hospitalization.

Data from the 19 identified AE case reports that included patients age 65 or over are displayed in Table 9. Thirty patients were represented; 77% were female. Over half had received injections of Synvisc, which is considered a high molecular-weight product.

The most commonly reported adverse events involved joint reactions. Pullman-Mooar98 reported inflammatory knee effusions in eight patients, ranging in age from 31 to 67 years. Each of three physicians reported cases of pseudo-septic arthritis.99–101 Acute arthritis, and gout or pseudo-gout were also reported.

Importantly, five cases of sepsis were reported in three articles; one of these patients suffered from staphylococcal scalded skin syndrome.

Other adverse events included systemic reactions in two patients, granulomatous synovitis in two patients, and one case each of saphenous nerve injury, eosinophiluria, erythema, and one case of new-onset herpes zoster.

Table 9 Adverse events described in case reports

Author, Year | AE | N | Age | Sex | Co-morbidities | Brand
Joint Reaction (crystals, etc.)
Bernardeau, et al., 2001^102^ | Acute Arthritis | 2 | 59, 73 | F | NR | Synvisc
Idrissi et al., 2012^101^ | Pseudo-septic arthritis | 1 | 70 | F | NR | Ostenil
Maillefert et al., 1997^103^ | Pseud- gout (Chondrocalcinosis) | 2 | 62, 83 | F | NR | Hyaluron, unspecified
Pullman-Mooar et al., 2002^98^ | Inflammatory knee effusions | 8 | 31 to 67 | 3 M, 5 F | NR | Synvisc
Roos et al., 2004^99^ | Pseudo-septic arthritis | 1 | 70 | F | Chondrocalcinosis 2 years earlier | Ostenil
Tahiri et al., 2007^100^ | Pseudo-septic arthritis | 1 | 70 | F | Diabetes | Curavisc
Wendling et al., 2007^104^ | Acute gouty arthritis | 1 | 72 | F | Overweight, hypertension | Sinovial
Ali et al., 1999^105^ | Pseudo-gout | 1 | 74 | M | NR | Synvisc
Infections
Kunugiza et al., 2011^106^ | Staphylococcal scaled skin syndrome (sepsis) | 1 | 68 | F | NR | NR
Lequerre et al., 2002^107^ | Septic arthritis | 1 | 70 | M | NR | Synvisc
Shemesh et al., 2011^108^ | Septic arthritis | 3 | 64, 70, 75 | 1 M, 2 F | Hypertension and or hyperlipidemia | NR
Other
Iizuka et al., 2005^109^ | Saphenous nerve injury | 1 | 68 | F | Hypertension, gout | NR
Martens, 2001^110^ | Systematic inflammatory reaction | 1 | 70 | F | NR | Synvisc
Rees et al., 2001^111^ | Systemic reaction | 1 | 79 | F | Hypertension | Synvisc
Banerjee, 2002^112^ | Eosinophiluria | 1 | 68 | M | Ischemic heart disease, mild renal impairment | Hyalgan
Semih et al., 2009^113^ | Herpes zoster | 1 | 71 | M | NR | Sodium hyaluronate
Calvo et al., 2007^114^ | Erythema | 1 | 70 | F | Hypertension, pyrazolone allergy | Go-On
Michou et al., 2004^115^ | Granulomatous synovitis | 2 | 71, 72 | F | NR | Synvisc

Table 10 McHarm Table

Author, Year | Were the harms pre- defined using standardized or precise definitions? | Was the mode of harms collection specified as active? | Was the potential occurrence of harmful events collected at pre- specified intervals; for example, the occurrence of post-operative complications were evaluated on a daily basis within 30 days of the surgery? | Did the author(s) specify the number for each type of harmful event for each study group? | Was the total number of participants affected by harms specified for each study arm? | If the study reported that there were no serious AEs reported did they define serious AEs?
Altman et al., 1998^69^ | No | No | Yes | Yes | Yes | Not applicable
Berenbaum et al., 2012^70^ | Yes | No | No | Yes | Yes | Not applicable
Blanco et al., 2008^51^ | No | Yes | Yes | No | Yes | Not applicable
Brandt et al., 2001^71^ | Yes | Yes | Yes | No | Yes | Not applicable
DeCaria et al., 2012^72^ | Unclear | Unclear | No | No | No | No
Dixon et al., 1988^68^ | No | Yes | Yes | Yes | Yes | Not applicable
Dougados et al., 1993^49^ | Unclear | Unclear | No | Yes | Yes | No
Grecomoro et el., 1987^83^ | No | Unclear | Yes | Yes | Yes | No
Henderson et al., 1994^84^ | Unclear | No | Yes | No | Unclear | Not applicable
Huang et al., 2011^73^ | Unclear | Unclear | Yes | No | Yes | Not applicable
Huskisson et al., 1999^74^ | Unclear | Unclear | Yes | Yes | Yes | Not applicable
Kahan et al., 2003^75^ | Unclear | Unclear | Unclear | No | Yes | Not applicable
Karlsson et al., 2002^76^ | Yes | Unclear | Unclear | Unclear | Yes | Not applicable
Khanasuk et al., 2012^77^ | No | No | No | No | Yes | Not applicable
Leopold et al., 2003^87^ | Unclear | Unclear | Yes | No | Yes | Not applicable
Lundsgaard et al., 2008^81^ | No | No | Yes | Yes | Yes | No
Pavelka et al., 2011^78^ | No | No | Yes | No | Yes | Not applicable
Petrella et al., 2002^79^ | No | No | No | No | No | No
Petrella et al., 2008^79^ | No | Unclear | Yes | N/A | Unclear | No
Petrella et al., 2011^89^ | No | No | No | No | No | No
Pham et al., 2004^82^ | No | Yes | Yes | Yes | Yes | Not applicable
Raman et al., 2008^80^ | No | No | Yes | No | Yes | No
Roman et al., 2000^85^ | No | Unclear | Unclear | Unclear | No | Not applicable
Tamir et al., 2001^86^ | Yes | No | Unclear | Yes | Yes | Not applicable