# Methods

## Criteria for Inclusion/Exclusion of Studies in the Review

This report is based on a systematic search for randomized placebo-controlled trials, head-to-head trials, or quasi-randomized trials that reported results for individuals whose average age was 65 or older; that assessed the effects of HA on function, quality of life, delay of TKR, prevention of the need for TKR, and adverse events (as well as factors that might affect these outcomes, such as age, disease severity, or comorbidities); and were powered to see a clinically important difference. If no randomized controlled trials were identified that assessed an outcome of interest, we included observational studies that assessed the outcome in question. Studies were included that enrolled individuals with other comorbidities and that enrolled community dwelling or institutionalized participants. The populations, interventions, comparators, outcomes, timeframes, and settings (PICOTs) of included studies are outlined below.

The efficacy of HA for pain relief has been reviewed in a large number of systematic reviews within the past two years, including a comprehensive 2012 systematic review and a 2015 network meta-analysis. Therefore, we addressed the outcome of pain, which is considered the primary outcome of HA treatment, by describing the findings of these two reviews in some detail, and reviewing any original studies published concurrently or subsequently and not included in those reviews.

To broaden our search for reports of rare adverse events, we included individual case reports and observational studies (prospective cohort studies and case series) that enrolled or followed more than 500 individuals' data.

### PICOTs

- Population(s):
  - Individuals with severe OA of the knee (e.g., as characterized by a Kellgren-Lawrence grade of III, or a failure to respond to oral analgesics and anti-inflammatories) and no prior arthroplasty on the affected limb;
  - Comorbidities: studies that do not explicitly exclude individuals with any comorbidities that significantly and independently affect quality of life and activities of daily living (including involvement of the contralateral knee or of other joints) would be excluded or considered separately
  - Age 65 and over, male or female, community-dwelling or institutionalized (if studies enrolling only individuals 65 and over were not identified, we would broaden our inclusion criteria to include studies enrolling populations with mean age 65 and over)
- Interventions:
  - Intraarticular Hyaluronan
- Comparators:
  - Placebo (sham treatment)
  - Non-steroidal anti-inflammatory drugs
  - Corticosteroids
  - Other forms/brands of hyaluronic acid
- Outcome measures:
  - Receipt of total arthroplasty surgery within follow-up time, length of time before undergoing surgery
  - Function and range of motion
    - WOMAC Index
    - Lequesne Functional Index
    - KOOS
    - Other validated functional scales
    - Range-of-motion assessment
  - Pain
    - WOMAC
    - VAS
    - Other tests included in prior systematic reviews
  - Activities of daily living/Instrumental activities of daily living
  - (Health-related) quality of life
    - Standard Form (SF)-36
    - EuroQol (EQ-5D)
  - Adverse effects of HA injection: physical effects, progression of disease (including flare ups)
- Timing:
  - Surgical postponement outcomes: 12 months or longer
  - Other efficacy outcomes: 3 months or longer
- Settings:
  - All settings

## Literature Search Strategies for Identification of Relevant Studies to Answer the Key Questions

The search strategy was based on one used for a 2012 evidence review on HA,17 with the addition of search terms for the additional outcomes of interest: arthroplasty/total knee replacement, ADLs, IADLs (including terms for the tools commonly used to assess ADLs and IADLs, e.g., Lawton IADL scale, Katz Index), and quality of life (Appendix A). To test the search strategy, we checked for the inclusion of a set of 84 articles provided to us by the CMS.

PubMed, EMBASE, Web of Science, SCOPUS, and the Cochrane Collection were searched from January 1, 1990 to late November, 2013 to identify original studies of HA. An update search was conducted on December 12, 2014 dating back to six months prior to the initial searches, while the draft report underwent peer review. Any new articles identified by the update search or suggested by peer reviewers were screened using the methods applied initially. To capture unpublished or not-yet-published efficacy and adverse event findings, we searched the NY Academy of Sciences database of grey literature; Grey Matters, a grey literature tool from the Canadian Agency for Drugs and Technologies in Health; clinicaltrials.gov; and the FDA Pre-Market Approval (PMA) database. The AHRQ SRC contacted the manufacturers of HA devices approved for use in the United States to obtain scientific information packets (SIPS) on their products. Information obtained from the latter sources was checked against published data to ensure no duplicate data were included.

Systematic reviews of potential relevance were identified by searching the Cochrane Database. For the outcomes of function, ADLs/IADLs, quality of life, and prevention or delay of total knee replacement, systematic reviews were assessed for any original studies not already identified among the results of the searches. For the outcome of pain, we identified several recent comprehensive systematic reviews.

Only English-language studies were accepted for data abstraction. However, to ensure we were not systematically excluding studies that might report important outcomes, we screened the titles and English-language abstracts of a random selection of 30 non-English-language articles. Descriptions of these articles appear in Appendix E; none qualified for inclusion.

The output of the literature searches was transferred to DistillerSR™ for screening. Article titles and abstracts were independently screened by two reviewers with all selected articles obtained. A second round of screening was then conducted with full text to exclude articles that provided no usable data, reported duplicate data, enrolled participants whose mean age was less than 65 years of age, or reported no outcomes of interest. We searched accepted studies for additional references and screened any articles of apparent interest. For studies of potential interest reported in meeting abstracts (conference proceedings), we searched for peer-reviewed articles that reported the data; abstracts were not included as a source of original data.

## Data Abstraction and Data Management

Articles accepted for inclusion were dually abstracted in DistillerSR, and any disagreements reconciled with the input of the project manager, SCEPC director, or local subject matter expert.

Study-level data (PICOTs) included the population demographics (average age, age range, sex, body mass index), comorbidities, disease stage, methods of ascertainment, intervention protocols, comparators, outcomes assessed in the study, and time course of interventions and follow-up.

Outcomes data were abstracted from original research studies for the following outcomes if reported: receipt of arthroplasty, time elapsed between HA therapy and surgery, change or improvement in ADLs/IADLs and other measures of function, QoL/Health-related QoL, and harms (adverse effects).

## Assessment of Methodological Quality of Individual Studies

The quality/risk of bias (ROB) of trials that reported on efficacy outcomes was assessed using the Cochrane Risk of Bias tool31 with the addition of several questions to assess elements of importance to this review. ROB was assessed in duplicate, with reconciliation of differences. A copy of the questions appears in Appendix D.

The quality of observational studies that reported on delay or avoidance of total knee replacement surgery was assessed using a modification of the Newcastle-Ottawa scale.32 A copy of the criteria is included in Appendix D.

To assess the quality of included systematic reviews and meta-analyses, we used AMSTAR, a measurement tool for the assessment of multiple systematic reviews.33 This tool contains eleven yes/ no items, such as whether the literature search was comprehensive, dual abstraction was used, and individual study characteristics are displayed. The tool has strong face and content validity, inter-rater reliability, and construct validity.34 A copy is included in Appendix D.

We rated the quality of RCTs included in the assessment of adverse events (AEs) using the McHarms assessment tool.35

## Data Synthesis

Studies Reporting on Efficacy. For the assessment of functional outcomes, we considered randomized placebo-controlled or head-to-head trials with blinded outcome assessment that reported changes in the score on a functional assessment scale (such as ADL/IADLS, WOMAC or Lequesne) or changes in a measure of quality of life. Trials might report more than one outcome.

For RCTs that compared the effects of interventions with HA with placebo for functional outcomes (WOMAC, Lequesne, or KOOS scales), most trials reported the WOMAC as the measure of function; followup times ranged from 4 to 52 weeks (all but three studies reported outcomes at 6 months). A standardized effect size was calculated for trials that reported a mean change from baseline by treatment group for a continuous outcome. In some cases, a mean change from baseline was not reported, but the mean outcome at baseline and at follow-up was reported. Using this information, we could estimate the mean change from baseline. Because various scales (or various ranges of the same scale) were reported, we calculated a standardized effect size. This provides a unit-less measure. For trials that did not report the standard deviation of the mean change, one was estimated using the standard deviations of the baseline and follow-up means. If a follow-up standard deviation was not reported, then we assumed that the standard deviation was one-fourth the theoretical range for the specific measure in the trial.

For each comparison of interest, an unbiased estimate of Hedges’ g effect size36 and its standard deviation were calculated. A negative effect size indicates that the treatment group is doing better than its comparator group (i.e. placebo group or other active comparator). For trials that reported the number of patients having total arthroplasty, a Peto’s odds-ratio (OR) was estimated. An OR less than 1 indicates that the treatment group has fewer arthroplasty patients then the comparison group.

Three or more trials similar in outcome and treatment comparison were considered for meta-analytic pooling. Since some trials reported only the Lequesne score, we looked at trials that reported both the WOMAC and the Lequesne score to see if conclusions were the same. If so, then we felt justified in pooling the WOMAC and Lequesne score together. For trials that reported more than one follow-up time, the time closest to 26 weeks was used. Sensitivity analyses were conducted by excluding trials with follow-up times not close to 26 weeks. For comparisons that had at least three trials, we derived a pooled estimate of the overall effect size using the Hartung-Knapp-Sidik-Jonkman (HKSJ) method for our random effects meta-analysis.37 This method has been preferred when the number of pooled studies is small. It has been shown that the error rates are more acceptable than the previously used DerSimonian and Laird method.38 Publication bias was assessed for all pooled outcomes using the Begg adjusted rank correlation test39 and Egger regression asymmetry test.40 Heterogeneity was assessed using the I^2^ test.41 An effect-size or odds ratio was calculated for trials that reported data but did not contribute to a pooled analysis. All efficacy analyses were conducted with Stata statistical software, version 12.0 (Stata Corp., College Station, Texas).

To obtain an estimate of the clinical importance of the pooled effect size for function (which represented a standardized mean difference), we compared it to the minimum clinically important difference (MCID) or minimum clinically important improvement (MCII) derived for large groups of patients with OA of the knee undergoing similar treatments and used in the two most recent comprehensive systematic reviews (including the OMERACT-OARSI recommendations) as well as the MCII derived by Tubach and colleagues and used in a recent trial included in the report.17,42–46

In addition to obtaining the standardized effect size for each trial, we attempted to abstract the proportion of participants who reported improvement in function; a subset of studies reported on global improvement only.

The RCTs that compared active treatments head to head were not pooled, as the numbers of studies comparing the same interventions were insufficient. Similarly, the numbers of studies that reported on ADLs or quality of life were insufficient to allow pooling. The results are reported narratively. RCTs reporting on total knee replacement/arthroplasty were also small in number and are described narratively. Because only three RCTs reported on arthroplasty (and only one considered it as a treatment outcome), we included observational studies that assessed arthroplasty. The results of these studies are described narratively.

The effect of HA treatment on pain has been assessed in a number of recent systematic reviews, including one relatively high quality review published in 2012. This review pooled 71 RCTs that met their inclusion criteria of a minimum of 3 months follow up (without regard to type of control or mean age of participants); in addition, they pooled only the 18 trials that had both placebo (sham) controls and enrolled more than 100 participants per study arm. They also conducted stratified analysis on a number of potential effect modifiers, including use of a sham control intervention. We describe the findings of this review and subsequent studies that reported on pain as an outcome narratively.

Studies Reporting on Adverse Events. Trials of any length were considered for the safety analysis. The AHRQ EPC Scientific Resource Center (SRC) contacted manufacturers of all HA devices approved for use in the US; citations for published studies received from manufacturers were deduplicated with published studies already identified in the literature searches. No unpublished data were provided. We also accessed the Food and Drug Administration (FDA) PostMarketing Assessment (PMA) database for information posted about HA products (code MOZ) this database includes information for six products approved for use in the US. Finally, we accessed the FDA Manufacturer and User Device Experience (MAUDE) database; however, we did not include MAUDE data in the report because the ages of the individuals about which the reports were filed could not be determined and because we did not include single case reports of adverse events.

Adverse event data extracted from RCTs included the name of each trial group, the description of the adverse event from the original article, the number of subjects in each group, and the number of subjects with each adverse event. Each event was counted as if it represented a unique individual. Because a single individual might have experienced more than one event, this assumption may have overestimated the number of people having an adverse event. Events described as adverse events or harms (and reported as part of a safety assessment) were extracted regardless of whether the study authors described them as being unrelated or related to the interventions.

Adverse events reported in RCTs were grouped using clinical expertise into three categories: local, joint, and other. Within those categories, events were further categorized as serious or not serious. For groups of events that occurred in three or more trials, we performed a meta-analysis to estimate the pooled odds ratio and its associated 95% confidence interval. Given that many of the events were rare, we used exact conditional inference to perform the pooling rather than applying the usual asymptotic methods that assume normality. We conducted the meta-analyses using the statistical software package StatXact Procs v9.0 (Cytel Software, Cambridge, MA).

Any significant pooled odds ratio greater than one indicates the odds of the adverse event associated with HA are larger than the odds associated with the comparison (placebo or active control) group.

Adverse events were also abstracted from prospective cohort studies and case series of 500 or more patients, and case reports of individuals age 65 or older.

### Grading the Evidence for Each Key Question

The overall strength of evidence (SOE) was assessed for each conclusion within each key question using the EPC modification of the GRADE system.47 Domains included were study limitations (risk of bias), directness, consistency, precision, and reporting bias (definitions and criteria for these domains are provided in Appendix G).48 This method classifies the evidence according to the following criteria:

- High = High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Evidence either is unavailable or does not permit a conclusion.

The applicability of the findings was assessed based on age, community residence, comorbidities, weight status, and study size.

## Peer Review and Public Commentary

A draft version of the report was posted for peer and public comment on December 9, 2014. The report was revised in response to those comments.