# Introduction

## Background

### Condition

Degenerative joint disease (usually called osteoarthritis [OA]) of the knee is a condition characterized by the progressive destruction of the articular cartilage that lines the knee joints, the subchondral bone surfaces, and synovium, accompanied by pain, immobility, and reduction in function and the ability to complete activities of daily living (ADL).

In 2005, the estimated prevalence of osteoarthritis among adults in the United States, the number of individuals who had ever been told by a doctor that they had the condition, was approximately 27 million cases.1 Prevalence rates vary by the joint involved and the method of ascertainment (clinical vs. radiographic): symptomatically, the knee is the most frequently affected joint.2 The prevalence of osteoarthritis of the knee is increasing rapidly because of shifting population demographics: The primary risk factors for osteoarthritis of the knee are aging, obesity, prior injury, repetitive use,3 and female gender. The US Centers for Disease Control and Prevention have estimated that the prevalence of symptomatic knee osteoarthritis may reach 50 percent by the age of 85.^4^ In the first decade of the 21^st^ century, the number of individuals in the US with a total knee replacement doubled (from some 2 million to approximately 4 million).5 The increase in obesity has translated not only into an increase in incidence of osteoarthritis of the knee but also into a younger age of onset and need for treatment; as a result, by the time individuals with osteoarthritis of the knee reach the age of Medicare eligibility, the length of time they have had the condition has grown, their cases are more advanced,6 and the risk that surgery will be needed has increased. Thus, the aging of the baby boomer population, along with the increased incidence and prevalence of obesity have created a perfect storm for an increase in the number of cases and the proportion of the population at risk for this condition, all representing an increasing strain on Medicare resources.

### Diagnosis Strategies

The clinical diagnosis of OA of the knee is typically based on presentation, including insidious onset of weight-bearing knee pain that is exacerbated by use of the joint and relieved by rest, and that tends to worsen over the course of the day. Radiographic evidence of osteoarthritis may precede symptomatic osteoarthritis but may not correlate with symptom severity. Radiologic severity can be estimated using the Kellgren and Lawrence criteria; however, a number of versions of the criteria exist: At low cutoff scores, correlation with symptoms is poor,7 whereas at higher cutoff scores, agreement tends to be higher. The primary impact of these different versions of the criteria may be the challenge that they create in trying to use the different versions to assess, compare, and pool the findings of research studies:7 Some longitudinal studies have even used different criteria at different time points within the same study. Because of the variation in scores for radiographic finding under various versions of the criteria (especially for individuals with less-advanced disease), stratification is important.

Some evidence suggests that among individuals with knee pain, MRI demonstrates physical signs of osteoarthritic changes in the knee before they are visible radiographically.8

### Treatment Strategies

The goals of treatment for osteoarthritis of the knee include relief of pain and inflammation, slowing of progression, and improvement in or maintenance of mobility, function, and quality of life. Measures used to assess the achievement of these outcomes are described below.

Treatment options for osteoarthritis of the knee include analgesics (e.g., oral acetaminophen) and anti-inflammatory agents (non-steroidal anti-inflammatory agents [NSAIDs], intraarticular corticosteroids), , physical therapy and exercise (both to strengthen muscles that support the affected joints and to increase range of motion), weight loss to reduce stress on the joints, bracing to reduce lateral motion and friction, and if patients fail to obtain satisfactory relief from pain and improved function from the aforementioned treatments, partial or total arthroplasty (throughout this report, the terms arthroplasty and knee replacement are used interchangeably) may be recommended for advanced cases. More recent therapies include intraarticular viscosupplementation, involving local injections of the natural joint lubricant, hyaluronic acid, among other treatments.9

Hyaluronic acid (HA, hyaluronate or hyaluronan) , a high molecular weight glycosaminoglycan that is naturally synthesized in plasma membranes of connective tissues and secreted into the synovial fluid surrounding joints, where it forms part of the extracellular matrix.10 Intra-articular injection of HA was approved by the US Food and Drug Administration in 1997 as a medical device for the relief of pain due to osteoarthritis of the knee. Progressive osteoarthritis of the knee includes a decrease in, the concentration of hyaluronic acid by one half to two thirds of the normal value and a reduction the molecular size of the hyaluronic acid, lowering the viscoelastic properties of the synovial fluid.11 Injecting hyaluronic acid intraarticularly was posited as a means to restore the viscosity of the synovial fluid; thus approval was sought for HA as a device rather than as a drug12 (the distinction being that a device does not exert its effect via a chemical interaction with the body. A large number of trials have examined the efficacy and safety of supplemental intra-articular injections of HA, usually to relieve pain, but sometimes also to improve function in patients with OA of the knee, with varying efficacy results. A number of systematic reviews have attempted to resolve these conflicting findings. Some reviews have reported positive outcomes13–15 whereas some have reported mixed effects.12,16,17 A 2010 update of an earlier systematic review actually found a decrease in the effect size for HA on knee osteoarthritis from the previous review.18 The discrepancies in outcomes may be due to study heterogeneity both within and among reviews (and original studies, themselves) with respect to population characteristics (such as average age or body mass index), intervention modalities (the particular HA employed), treatment and followup duration (the number of treatments as well as how long after treatment initiation outcomes are measured), and the actual outcomes measured (e.g., pain, functionality, HRQoL), as well as the measures employed. Heterogeneity may also be attributable to how efficacy is expressed, i.e., the proportion of each treatment group that responds positively to treatment vs. the mean change in that efficacy measure from baseline in the active treatment group vs. the comparison group. Finally, whether or not a study reports a positive effect of HA has been shown to depend, at least in part, on study design: whether participants are credibly blinded to treatment allocation and the outcomes of active treatment are compared to that of a placebo control.17

Commercial preparations of HA differ in three respects: source, molecular size, and dosing. Whereas the older HA were all avian in origin (purified from chicken comb), some newer products are bioengineered in yeast cell cultures. The newer products also tend to be higher in molecular weight, the result of greater cross-linking. Products may be packed to be delivered as a single dose or in multiple doses. The products included in this report are shown in Table 1, along with their indications and recommended dosages (HA devices not approved for use in the United States are described in Appendix F).

Table 1 Hyaluronic Acid Devices Approved for Use in the United States

Device Source Approval Date Avian/Non-Avian Molecular Weight | Trade name(s) | Labeled indications | Dosing | Dose adjustments for special populations
Sodium hyaluronate FIDIA Pharmaceutical Corp. May 1997 Avian 500–730 kD | Hyalgan® | Indicated for treatment of pain in osteoarthritis of the knee in patients who have failed to respond adequately to conservative non-pharmacologic therapy and simple analgesics, (e.g., acetaminophen) | Five* weekly injections into knee joint (20 mg/2 mL) | Safety/effectiveness not known in pregnant/lactating women or children
Hylan GF-20 Genzyme Corp. (Biomatrix, Inc.) August 1997 Avian 6,000 kD | Synvisc® | Indicated for treatment of pain in osteoarthritis of the knee in patients who have failed to respond adequately to conservative non-pharmacologic therapy and to simple analgesics (e.g., acetaminophen) | Three weekly injections into knee joint (16 mg/2 mL) | Safety/effectiveness not known in pregnant/lactating women or children
Sodium Hyaluronate Seikagaku Corp. January 2001 Avian 620–1170 kD | Supartz® Marketed as Artz® or Artzal® outside U.S. | Indicated for the treatment of pain in osteoarthritis of the knee in patient show have failed to respond adequately to conservative non-pharmacologic therapy and simple analgesics (e.g., acetaminophen) | Five weekly injections into knee joint (25 mg/2.5 mL) | Safety/effectiveness not known in pregnant/lactating women or children
Hyaluronan Anika Therapeutics, Inc. February 2004 Non-Avian 1000–2900 kD | Orthovisc® | Indicated for treatment of pain in osteoarthritis of the knee in patients who have failed to respond adequately to conservative non-pharmacologic therapy and to simple analgesics (e.g., acetaminophen) | Three or four weekly injections into knee joint (30 mg/2 mL) | Safety/effectiveness not known in pregnant/lactating women or children
Hylan GF-20 Genzyme Corp. February 2009 Avian 6,000 kD | Synvisc-One® | Indicated for treatment of pain in osteoarthritis of the knee in patients who have failed to respond adequately to conservative non-pharmacologic therapy and to simple analgesics (e.g., acetaminophen) | Single injection into knee joint (48 mg/6 mL) | Safety/effectiveness not known in pregnant/lactating women or children
Sodium hyaluronate Seikagaku Corp. March 2011 Avian Unknown MW (“high”) | Gel-One® | Indicated for the treatment of pain in osteoarthritis of the knee in patients who have failed to respond adequately to non-pharmacologic therapy, NSAIDs, or analgesics (e.g., acetaminophen). | Single injection into knee joint (30 mg/3 mL) | Safety/effectiveness not known in pregnant/lactating women or children
1% sodium hyaluronate Ferring Pharmaceuticals, Inc. October 2011 Non-Avian 2400–3600 kD | Euflexxa® Formerly Nuflexxa®, (Savient) approved December 2004 | Indicated for treatment of pain in osteoarthritis of the knee in patients who have failed to respond adequately to conservative non-pharmacologic therapy and to simple analgesics (e.g., acetaminophen) | Three weekly injections into knee joint (20mg/2 mL) | Safety/effectiveness not known in pregnant/lactating women or children
Hyaluronan Anika Therapeutics, Inc. February 2014 Non-Avian Unknown MW (“high”) | Monovisc™ | Indicated for treatment of pain in osteoarthritis of the knee in patients who have failed to respond adequately to conservative non-pharmacologic therapy (e.g., acetaminophen) | Single injection into knee joint (88 mg/4 mL) | Safety/effectiveness not known in pregnant/lactating women or children

#### Treatment Guidelines

In the 2012 update to their 2000 guidelines for the treatment of osteoarthritis of the knee, hip, and hand, the American College of Rheumatology conditionally recommended hyaluronic acid injections for patients who had an inadequate response to initial (standard or more conservative) therapy.9 The 2013 American Academy of Orthopedic Surgeons guidelines for the treatment of osteoarthritis of the knee recommend against the use of hyaluronic acid to treat patients with symptomatic conditions.19

#### Assessment of Outcomes of Treatment

A number of assessment tools are used to assess pain, quality of life, and physical functioning in patients with osteoarthritis of the knee. These tools can be divided into those specifically developed for knee osteoarthritis and those that are used for a variety of conditions.

Tools specifically developed and validated to assess pain and functioning associated with osteoarthritis of the knee as well as treatment outcomes include the Western Ontario-McMaster Universities Arthritis Index (WOMAC20), the Lequesne Index21, the Knee Injury and Osteoarthritis Outcomes Score (KOOS22), and the Animated Activity Questionnaire.23 The Visual Analog Scale, which rates patient-reported responses on a scale from 0 to 100, is often used to quantify patient-reported outcomes for these scales as well as being used on its own. The WOMAC, probably the most widely used tool for assessing knee osteoarthritis, comprises three scales: pain, function, and stiffness; the function scale comprises 17 items that can be rated using a 5-item Likert scale (where 0=no difficulty and 4=extreme difficulty) or a 10 or 100-point Visual Analog Scale (VAS).20 In 2004, the Osteoarthritis Research Society International (OARSI) developed a consensus set of guidelines to assess the outcomes of research trials on products intended to treat osteoarthritis; and under the International League of Rheumatologists, OMERACT (Outcome Measures in Rheumatology) has developed guidelines on outcome measures.24

Several tools have been adapted for use in assessing osteoarthritis of the knee. One such tool, the Short form (SF)-36, developed at RAND for the Medical Outcomes Study,25 is generally used to measure quality of life. Assessment of health-related quality of life is an attempt to measure the impact of a health condition and its treatment on a patient’s life; the Euroqol has been validated for use in patients with osteoarthritis of the knee.26 The Activities of Daily Living scale (ADLs)27 measures the ability to perform basic daily tasks such as dressing/bathing, eating, ambulating, toileting, and hygiene. The Instrumental Activities of Daily Living (IADLs) scale allows the assessment28 of activities that are not needed for basic functioning but allow independent living.

The Kinemax Outcomes Group has used a combination of the WOMAC, the SF-36, and a series of questions addressing demographic characteristics to predict patient outcomes of total knee arthroplasty.29

Appendix H provides the WOMAC, Lequesne, and SF-36 instruments.

## Scope and Key Questions

### Scope of the Review

The purpose of this review is to assess, primarily, the evidence on the effects of intra-articular injections of HA in preventing or delaying the need for TKR among individuals 65 and over, and on functional outcomes and quality of life/health-related quality of life. The Centers for Medicaid and Medicare Services (CMS) currently covers HA injections for elderly Medicare recipients under certain conditions.30 Arthroplasty and the postoperative rehabilitation it requires can be life-disrupting. If HA can relieve pain and improve function with minimal adverse effects, it may prevent or delay the need for this surgery. However, if the treatment delays arthroplasty but fails to halt progressive degeneration, patients could potentially experience worse outcomes, although thus far, evidence for such outcomes has been weak. In addition to assessing the evidence for a role of HA in delaying or preventing the need for TKR, and affecting the outcomes of function, ADLs/IADS, and quality of life, this report aims to assess the evidence to date on the safety of intra-articular injections of HA when used as indicated and to scan the literature on the evidence for a role of HA in controlling pain. The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Southern CA Evidence-based Practice Center (HHSA290201200006I). A protocol for the review was provided to, and approved by, the AHRQ TAP.

### Key Questions

The key questions were provided by the CMS Coverage Analysis Group. Their inter-relationship and association with the topic are described in the analytic framework below (Figure 1).

Key Question 1. Does intra-articular injection of hyaluronic acid eliminate the need for knee replacement surgery? Is this outcome affected by the type of hyaluronic acid, the type of presentation, severity at study entry, or age at study entry?

Key Question 2. Does intra-articular injection of hyaluronic acid significantly postpone the need for knee replacement surgery?

Key Question 3. Does intra-articular injection of hyaluronic acid improve the ability to successfully perform activities of daily living (ADLs) or instrumental activities of daily living (IADLs)?

Key Question 4. Does intra-articular injection of hyaluronic acid improve quality of life? PICOTs are the same as for KQ1-3 with the exception of outcomes.

The effects of HA injection on pain and adverse events associated with HA injection were not included in the key questions posed by CMS. However because pain is regarded as an important component of effectiveness for treatments for OA of the knee and because safety is also an important treatment consideration, we volunteered to appraise this literature.

Figure 1 Analytic Framework

Figure notes: The framework shows potential outcomes of treatment with intraarticular HA (and placebo) the review sought to assess. These outcomes include a change in function, ADLs/IADLs (KQ3), a change in overall quality of life (KQ4), a change in pain, possible adverse events, and perhaps ultimately, a delay in TKR or decision not to undergo TKR, based potentially in part on some effect of treatment on pain, function, or quality of life.

ADL: Activities of Daily Living; DJD=Degenerative Joint Disease; HA=Hyaluronic Acid; IADLs=Instrumental Activities of Daily Living

Figure 1. Analytic framework of the effects of hyaluronic acid (HA) (vs. placebo or active comparator) on function, pain, adverse events, and delay/avoidance of total knee replacement (arthroplasty) This figure depicts the key questions within the context of the PICOTS described in the previous section. In general, the figure illustrates the possibilities that compared with placebo and alternate treatments, hyaluronic acid (HA) could prevent the need for surgery (KQ1), delay surgery (KQ2), affect activities of daily living (ADLs) or instrumental activities of daily living (IADLs) (KQ3), or affect quality of life (KQ4). The figure also shows that we will assess whether the treatment, compared with placebo and alternate treatments, may result in adverse events, to which delayed surgery could potentially contribute.

## Organization of this report

The remainder of this report presents the methods used to conduct the literature searches, data abstraction, and analysis for this review; the results of the literature searches; the conclusions; and a discussion of the limitations as well as suggestions for future research.