# Discussion

## Key Findings and Strength of Evidence

### Intra-articular HA and TKR

Three randomized trials and 13 observational studies reported on total knee replacement (TKR).

Of the three trials, two did not regard receipt of TKR as an outcome (and therefore were not designed specifically to test the hypothesis), the participants in one study had a mean age under 65, and the trials were not powered to compare the rates of TKR between HA and comparison groups.

A number of observational studies reported rates of TKR among HA recipients as approximately 20%. One large observational study that assessed the rates of TKR by age group, pain at baseline, and various other factors among stage IV patients considered TKR candidates reported that age was the only factor associated with the likelihood of undergoing TKR: OA patients in the 60–69 year old age group were significantly more likely than patients under 50, patients 70–79, and those over 80 to undergo TKR.56 This study also assessed the time interval between entering care in their practice and undergoing TKR in 1,342 patients over a 12-year follow-up period. Mean time to TKR for HA recipients was 2.8 years (patients who did not undergo TKR were followed for a mean of 8.7 years); the overall incidence of TKR in this group was 25%. The authors stated that for patients not treated with HA, the average interval between entering care in their practice and undergoing TKR was 3 months. Survival analysis demonstrated that HA treatment delayed the need for TKR in 75% of patients by 7.3 years. As in the original analysis, age was the only factor associated with tendency to undergo TKR. Given the designs of the studies, the strength of evidence is insufficient to draw conclusions regarding the effect of TKR treatment on delay or avoidance of TKR (see Table 2).

### Intra-articular HA and Function

Eighteen randomized trials reported on the effects of HA compared to sham-injected placebo control, another HA, or some other active treatment on function, as measured by the WOMAC, Lequesne index, KOOS, or ADLs, among patients whose average age was 65 or older. Pooling of ten placebo-controlled studies that reported outcomes for the WOMAC or Lequesne, all assessor blinded, revealed a small increase in function in favor of HA (−0.23, 95%CI −0.34, −0.02); this difference did not achieve the MCID of −0.37 applied by Rutjes and colleagues but did exceed the MCID of −0.15 recommended by the OMERACT-OARSI guidelines and the MCII of −0.12 derived by Tubach and colleagues (based on the pooled effect size, about 11 percent would have exceeded the MCID of 0.37 in improvement); eight of the ten studies measured outcomes at 6 months. One study reported placebo to be more effective and one found no difference.

One trial reported on the effects of HA on ADLs. This study found no change from baseline in the HA or placebo group.

One head-to-head study reported the proportion of patients who experienced improvement in function alone that exceeded the MCII: This study, which compared the intermediate molecular weight Go-On with the lower molecular weight Hyalgan, found that 69% of patients who received Go-On and 56% of patients given Hyalgan experienced improvement that met or exceeded the MCII. Four double-blind placebo-controlled trials that reported on function reported the proportion of patients who achieved a prespecified level of overall improvement; of these four, three reported a higher proportion of HA-treated patients than placebo-treated patients who achieved either patient- or investigator-reported improvement.

The duration of effect on function could not be ascertained: few studies followed patients long enough to truly measure durability of effect.

Too few head-to-head trials were identified to be able to draw any conclusions about the superiority of any one product over another.

None of the identified studies stratified findings by age, sex, or any other outcome of interest.

The strength of evidence for the conclusion that HA, on average, modestly improves function in patients with knee OA based on placebo-controlled trials is low (trials were not all well designed and two found no effect). The strength of evidence for the conclusion that one HA is better than another, head-to-head comparisons, is insufficient(Table 2).

### Intra-articular HA and QoL

Three trials reported on the effects of HA treatment on quality of life. One trial, which compared Hyalgan to treatment with two different volumes of saline, found no change in quality of life from baseline using the KOOS quality-of-life component.81 Two head-to-head trials that compared Synvisc with Hyalgan assessed quality of life, one using the SF-36 mental component summary to assess QoL77 and one using the EuroQol-5D index to assess HRQoL.80 The trial that used the SF-36 reported no increase in quality of life for either group, but the trial that used the EuroQol-5D reported a slight increase in QoL for Synvisc from 3 through 12 months but only an increase in HRQoL for patients on Hyalgan at 3 months.

As only three trials reported both QoL and functional outcomes, no conclusions can be drawn about the relationship between these two parameters.

The strength of evidence for any conclusions regarding an effect of HA on quality of life is insufficient.

### Intra-articular HA and Pain

Two large, comprehensive, recent good to high quality systematic reviews compared the effects of HA with sham or non- intervention controls or with placebo and all pharmacologic agents on pain reduction.

A 2012 systematic review reported that HA injections significantly reduced pain, both statistically and clinically (that is, reaching the MCID) when measured at 3 months; however, this effect was lessened to non-significance when only studies with blinded outcome assessment and at least 100 participants per study arm were included in the analysis. Stratified analysis that compared 54 studies with sham controls with 18 studies with non-blinded controls showed a statistically significant effect of HA on pain in the studies with sham controls that nearly met the MCID. They did not conduct a stratified analysis to assess the effect of age of participants. The authors reported evidence for publication bias, which we did not identify in our pooled analysis for effects on function.

A 2015 network meta-analysis compared the effects of oral and intraarticular pharmacologic agents, oral and intraarticular placebo, and HA on pain at 3 months among 129 RCTs (52 studies compared HA with intraarticular placebo).42 This study reported a significant effect size of HA compared with placebo (−0.34; 95% CI −0.42, −0.26), (similar to that of the Rutjes review) and exceeding the prespecified absolute MCID of −0.20, based on the OARSI-OMERACT responder criteria; sensitivity analysis showed that limiting study size to 50 or more did not change the effect size but limiting the analysis to studies of 100 or more did reduce the effect size to less than the MCID. This network meta-analysis found minimal evidence for reporting bias among the placebo-controlled HA studies.

Two new trials compared the effects of two different HAs on pain and were not included in prior SRs. One found that single injections of a high- and low-molecular weight were equally effective in reducing pain at 6 months, whereas another found that three injections of an intermediate molecular weight might be superior to low molecular weight HA over 6 months.

Based on the findings of the two prior systematic reviews, we believe that the strength of evidence is moderate that HA reduces pain, on average, by an amount about equivalent to the minimum clinically important difference.

### Intra-articular HA and AEs

We identified twenty four trials, three large cohort and case series studies, and 18 case reports that reported on the incidence of adverse events among individuals 65 years of age and over who were given HA to treat OA of the knee.

In placebo-controlled trials of HA, serious adverse events were small in number, and their precise frequency cannot be estimated from current data. The rate of non-serious AEs was higher but did not differ between the HA-treated and sham-control groups.

Among three large cohort studies and case series, representing nearly 6,000 recipients of HA (some more than one series), one serious adverse event was reported: severe swelling and synovial fluid accumulation.

Eighteen case reports provided reports of adverse events among 30 individuals 65 years of age or older, including five cases of sepsis (one case of staphylococcus scalded skin syndrome), and one case each of saphenous nerve injury, eosinophiluria, erythema, and new-onset herpes zoster.

These findings suggest that the adverse events associated with intra-articular injections of HA are nearly all at the site of injection or within the joint, largely confined to pain or swelling, and not different from those of patients who received sham injections. The FDA PMA database revealed no post-marketing reports of unexpected adverse events. Information provided by manufacturers about five products was limited to already published data.

The strength of evidence for the conclusion that serious adverse events are rare is moderate. The strength of evidence for a statistically significant difference in SAEs and non SAEs between intervention and placebo groups is low.

## Findings in Relation to What is Already Known

To our knowledge, this report represents the first systematic review to attempt to assess the effects of intra-articular HA injections on the combination of delay or avoidance of TKR, pain, function, quality of life, and adverse events.

No other systematic reviews have attempted to synthesize the effects of HA on TKR, and the present review found insufficient evidence to draw a conclusion about the effects of HA on those outcomes, identifying only three RCTs (two of which did not regard TKR as a study outcome) and a number of observational studies.

Regarding the effect of HA on function, we calculated an effect size of −0.23 (95% CI −0.45, −0.01), which was smaller than the MCID specified in the review by Rutjes but larger than the MCID used in the network meta-analysis by Bannuru (the Rutjes review reported an effect size of −0.33, [95% CI −0.43, −0.22]; the Bannuru review reported an effect size of −0.30 [95% CI −0.40, −0.20] for function. Also similar to the Bannuru network meta-analysis, our analysis of the effects of HA on function compared with intraarticular placebo showed no evidence of publication bias.

The moderate effect of HA on function that was identified in the review by Rutjes was no longer considered clinically significant when only large trials (100 or more participants per study arm, or at least 200 per trial) with assessor blinding were considered (−0.09, 95% CI −0.17, 0.00, based on 15 trials).17 The review by Bannuru, which included only double-blind placebo-controlled trials, found no significant difference in effect size when they included only studies enrolling 50 or more participants but did see a decrease in the effect size when they included only studies of 100 or more participants. However, study size is not typically a criterion in assessing study quality/risk of bias. Our meta-analysis on the outcome of function included only intraarticular placebo-controlled trials that incorporated assessor blinding; we did not find any studies that met our inclusion criteria that enrolled more than 100 participants per study arm.

The 2013 American Academy of Orthopedic Surgeons guidelines for the treatment of osteoarthritis of the knee also conducted a systematic review of the literature on the effects of HA on WOMAC-assessed pain, function, and stiffness. These guidelines recommend against the use of hyaluronic acid to treat patients with symptomatic conditions based on the finding that although statistically significant improvement was seen in pain and function with HA compared to placebo, the improvements did not meet the standard of exceeding the MCII ( the issue of considering MCID and MCII is discussed further below) (in contrast, the 2008 AAOS guidelines had found insufficient evidence to recommend for or against HA, based on an AHRQ review that found evidence of publication bias).19 The 2012 American College of Rheumatology Guidelines for the treatment of osteoarthritis of the knee also conducted a systematic review of the literature on the effects of HA and other modalities and issued a conditional recommendation for the use of HA for the initial management of patients with knee OA.9

The current review is the first to consider only studies of individuals of average age 65 or older. Approximately half of the trials included in the 2012 review by Rutjes and colleagues that assessed the outcome of pain enrolled populations of average age less than 65; and of the 52 trials they included in their analysis of the effects of HA on function, nearly all included participants of average age less than 65.^17^ Although patient age might affect the ability to experience (or realize) improved function from a treatment, no evidence exists that would suggest age would affect the ability to experience pain relief. Therefore, we believe the analyses in the reviews by Rutjes and Bannuru, given the much larger number of studies they included, were more adequately powered to assess the effects of HA on pain than would be an analysis limited to studies of individuals of average age 65 and over.

The current review found only a small number of serious AEs and in pooling placebo-controlled RCTs, found no statistical differences between serious AEs in treatment and placebo conditions. The 2012 review pooled data on serious AEs from14 trials that reported on AEs and found an increased risk for serious AEs in the HA-treated groups,17 whereas a 2013 review of 29 studies,90 as well as the 2015 network meta-analysis by Bannuru and colleagues found no difference between HA and placebo for any AE, in agreement with the present study. To derive a potential explanation for the disparity in the apparent risk for serious AEs between the review by Rutjes and colleagues and ours, we re-abstracted the data on serious AEs (both those reported by original study authors as being serious, those deemed serious by the criteria of the present study, and those deemed serious by the criteria of the 2012 review). We included only studies that would have met our inclusion criteria (making an exception for mean age); therefore we excluded studies in the Rutjes analysis that were not assessor blinded, studies in which patients served as their own controls, and conference abstracts. The reported increase in risk for serious AEs among patients who received HA compared with placebo in the 2012 review appears to be attributable to several factors. The methods use for the statistical analyses differed slightly between the two reviews. In addition, the criteria used to define serious AEs, the criteria for accepting original authors’ definitions of serious AEs, and the criteria for plausible associations differed between the two reviews; fewer than half of the trials included in the serious AE analysis of the review by Rutjes and colleagues17 actually described specific AEs, and a number of studies that did describe the specific AEs they observed had methodological limitations. The network meta-analysis by Bannuru and colleagues, as well as another recent (2014) meta-analysis by this group compared the efficacy and safety of intraarticular HA with NSAIDs for the treatment of knee OA: Although the small number of studies they were able to pool showed no differences in efficacy between HA and NSAIDs, NSAIDs were associated with a significantly increased risk for gastrointestinal AEs compared with HA We address the issue of adverse event reporting further below in our discussion of limitations.

Regarding non-serious AEs, the 2012 review limited its assessment to flare-ups (a joint reaction), finding no statistically significant difference between treated and placebo groups.14 This finding agrees with that of the present review, which found no statistically significant differences between actively treated and sham/placebo-treated groups for non-serious local, joint, and “other” AEs. It is not possible to assess whether the potentially high numbers of these non-serious AEs indicate that a large proportion of study participants experience these AEs because most studies do not report the total numbers of participants who experience at least one AE (so one participant could report many AEs). In addition, the observation that the number of “other” (not joint related and not local, e.g., “headache”) non-serious AEs is far higher than the numbers of local and joint-related non-serious AEs, supports a lack of association between these occurrences and the intervention and suggests knowledge of such events may not have much of an impact on the decision-making of an individual seeking the chance for relief.

## Applicability

To increase potential applicability, we limited studies included in the current review with functional outcomes to those with an average age of 65 or older. Nevertheless, no studies excluded patients younger than 65. Given that the only study that assessed factors that might influence the likelihood of undergoing TKR found that age was the only influential factor, age of study participants is likely to be an important consideration for this outcome.

The larger trials included in the assessment of functional outcomes were mostly conducted in academic settings; this typical characteristic of randomized trials tends to limit their applicability to community settings. However a number of the observational studies that addressed the outcome of TKR were conducted in private medical practices.

## Implications for Clinical and Policy Decision Making

The evidence identified for the current study is insufficient to support a decision either way about the efficacy of intra-articular HA injection based on the delay or avoidance of TKR. In addition, the strength of evidence is insufficient regarding the efficacy of HA for improving quality of life or function in a population 65 years of age or older.

## Limitations of the Comparative Effectiveness Review Process

Given the key questions specified by the partner and specified in our study protocol, we did not attempt to review studies of populations of average age less than 65 years to determine whether they found improvements in function or quality of life. However, removing the exclusion criterion of age for studies that assessed the outcome of TKR, we still identified only three randomized trials that reported TKR, and it was considered a primary outcome in only one study. We also did not contact authors of original research studies to request raw data by patient age and did not attempt to do new pooling of the data on pain in the studies included in the review by Rutjes and colleagues, to include only studies of older populations for reasons explained above.

In addition, as we discuss in the next paragraph (Limitations of the Evidence Base), in choosing the 6-month time point for pooling of effects on function, rather than a shorter follow-up time, we may have underestimated the effect of HA.

## Limitations of the Evidence Base

The majority of trials identified for the current report were of relatively mediocre quality, with poor reporting. Few trials described their recruitment strategy or method for allocation concealment. A number of studies had dropout rates higher than 20% (no studies addressed differences between dropouts and completers), and although most excluded individuals who had recently received corticosteroids or other courses of an HA, most also did not bar participants from using other modes of pain relief, such as NSAIDs. Further, few or no studies attempted to determine whether response to HA differed between groups of patients stratified by characteristics such as baseline age, disease severity (stage) or type; or duration of treatment, few studies followed patients long enough to truly measure durability of effect, and adverse events were not measured using any standardized method.

Specific to the outcome of function, no trials measured the duration of effect. A 2011 meta-analysis by Bannuru and colleagues assessed the therapeutic trajectory of intraarticular HA in placebo-controlled trials among patients with knee OA.116 The review identified 54 studies and computed effect sizes for changes from baseline in pain from 4 to 24 weeks. A significant effect size was seen for HA by 4 weeks and this effect peaked at 8 weeks, decreasing thereafter so that only a small effect remained by 6 months. The studies we identified that reported on function at multiple time points were insufficient in number to estimate a trajectory of effect for function.

Also specific to function, only one trial reported the percentage of participants whose function improved (seven studies reported on the percent who achieved a prespecified level of global improvement, of which four were double-blind placebo-controlled trials).

Specific to the outcome of TKR, only one small RCT measured knee replacement as a primary outcome. A number of observational studies, including several large retrospective data analyses, reported delays in TKR among patients who received IA HA, compared with patients who did not receive HA. However observational studies cannot control for the selection effect whereby patients who are more or less inclined to TKR are selected by their physicians for getting—or not getting—IA HR. Therefore without randomized trials designed and adequately powered to assess the effect of HA on TKR, it is not possible to draw conclusions at this time regarding the effect of HA treatment on delay or avoidance of TKR

Another challenging issue for studies of HA is that of the potential placebo effect inherent in the kinds of studies we reviewed. Although we limited our assessment to double-blind placebo-controlled trials (using only intraarticular placebos), the main analysis in the systematic review by Rutjes and colleagues included studies with various types of control groups, including both intraarticular and oral placebo. A 2012 meta-analysis by Colen and colleagues that included 74 studies specifically noted the large effect size for placebo alone (approximately 30%).16 The network meta-analysis by Bannuru and colleagues found that the effect size for intraarticular placebo exceeded that of all active oral treatments for pain42, prompting a commentary on the role of placebo controls in studies of the treatment of knee OA.117 Identifying the proper control for studies of interventions such as the injection of hyaluronic acid can be challenging, but at the same time, the existing trials, with intraarticular saline controls, are capable of assessing whether HA has any specific active effect over and above the injection of inexpensive saline.

A related but slightly different issue is that a number of studies allowed the use of rescue medications (acetaminophen, NSAIDs, and less often, CS or opioids) between treatments, which could have eliminated any observable difference between active treatment and placebo.

The use of statistical significance vs. clinical significance in studies such as the ones included in this review (as well as the review itself) also needs to be mentioned. The attainment of both statistical significance and MCID or MCII is critical for demonstrating effectiveness of any clinical treatment. However the threshold chosen for the MCID and how it is applied is controversial.118 The evidence is limited as to what the MCID should be for an effect of HA on function, whether it should be the same as for pain, and whether it should be limited to the use of only certain outcome measures. In trying to interpret our results regarding HA and function, we used three levels of MCID/MCII that have been proposed and used by others: our observed effect size exceeded the lower MCIIs of 0.12 and 0.20 but did not meet the MCID used in the review by Rutjes, 0.37 (an effect size of 0.2–0.4 is normally considered small to moderate according to Cohen's classification). But we acknowledge as a limitation that additional research could improve estimates of the MCID/MCII. Perhaps more importantly, we identified almost no studies that reported the proportion of patients who achieved either a statistical or clinical improvement.

Finally an issue of possible concern is that many studies of HA show potential financial conflict of interest (FCOI), either direct industry funding of the research or employment of authors by manufacturers of the agents being tested.90,91 A 2013 systematic review examined 48 trials of intraarticular HA for the treatment of knee OA to determine whether industry sponsorship was associated with the likelihood of a positive finding. Of 33 trials that identified a sponsor, 30 were industry sponsored; therefore, determining whether industry sponsorship affected outcomes was impossible. However the study also assessed the association between industry authorship (compared with academic authorship) and outcomes. Of the 17 studies with industry authors, none reported unfavorable conclusions (all reported favorable or neutral conclusions); 11 of the 31 academic authored studies reported unfavorable conclusions and 9 reported neutral conclusions. Another 2013 systematic review assessed only studies of HA that employed US-approved HA products; this review, which identified 29 studies and was funded by a trade group representing the pharm industry, reported statistically and clinically significant pooled effects sizes for the outcomes of pain and function compared with saline controls and no difference in serious AEs.90 However, the 2015 network meta-analysis by Bannuru and colleagues reported comparable effect sizes and was funded by the Agency for Healthcare Research and Quality.

## Research Gaps

Many of the research gaps we identified were discussed in the previous section on the limitations of the evidence base. This section presents several specific research needs based on the outcomes of greatest interest.

Clear research gaps exist regarding studies of the effectiveness of HA among individuals 65 years of age and older and the effect of HA, if any, on delay or avoidance of TKR. Two searches for ongoing studies of HA and OA of the knee on Clinicaltrials.gov and review of entries provided by manufacturers revealed no completed, ongoing, or recruiting studies on older individuals with knee OA or with outcomes of TKR. The observational studies identified for this review could not definitively answer the question of whether HA delays or prevents the need for TKR. However, data from any of the large administrative databases maintained by commercial payers offer an alternate possibility. Preliminary findings of three such studies have been presented at two recent meetings. An abstract presented at the 2013 meeting of the American College of Rheumatology reported using the Truven Marketscan database to match 7,000 HA recipients (66% female) with 19,627 non-recipients with OA of the knee (propensity score matching with the non-HA cohort was 98%).119 With one episode of HA treatment, the median times from the initial specialist visit to TKR were 199 and 443 days for the non-HA cohort and HA cohort, respectively. Additional treatment episodes increased the median gap by an average 202 days, suggesting true dose-response.

Dasa and colleagues presented the findings of a similar audit of IMS Health’s PharMetrics Plus Health Plan Claims at the 2014 annual meeting of the Academy of Managed Care Pharmacy.120 In an industry-sponsored study, they identified 18,217 patients who initiated treatment with Supartz/Hyalgan between 2007 and 2010 and were followed for 3 years: 13,561 patients received a single course of treatment, 2,999 received 2 courses, 1,012 received 3 courses, 404 received 4 courses, and 241 received 5 or more courses. Successive courses of HA led to greater proportions of patients without TKR at 3 years: 96.3% of those who received 5 or more courses avoided TKR compared with 72.7% who received 1 course (HR 0.113, p<0.0001). In a study funded by Horizon Blue Cross Blue Shield of New Jersey, Khan and colleagues conducted a retrospective analysis of claims from beneficiaries who had been plan participants for 5 or more years and had a confirmed diagnosis of IA: of 2,728 patients who received a first dose of HA, 35% underwent knee surgery within the first year and another 34.2% underwent surgery the second year. However the study did not specify the type of surgery and included patients who had undergone prior knee surgery; thus the authors concluded that although 69% of patients underwent surgery (of some type) within two years of treatment, further research is needed that enrolls patients with appropriate eligibility criteria.121

The decision to undergo TKR is difficult to predict, as it is affected by a number of factors beside severity of osteoarthritis, such as age, comorbidities, pain tolerance, activity level, aversion to surgical intervention, and expectations about one’s life expectancy; OMERACT has considered this issue and has suggested considering two alternative outcomes for assessing the effect of treatments for knee OA: “time to physician’s decision to recommend surgery” and “time to fulfilling criterial for total joint replacement.”122 However, if the primary question of interest is whether or not intraarticular HA can delay joint replacement, a double-blind placebo controlled trial could be conducted that enrolls a group of people who have already been deemed “appropriate for surgery” and randomizes them to receive intraarticular HA or an intra-articular placebo. Comparison of the time to TKR could then be appropriately compared. We did identify one small pilot study that employed this design, the study conducted by Blanco and colleagues, which reported a delay in time to TKR in the HA group that did not achieve statistical significance.51

Research is also needed to confirm the suggestion that higher molecular weight, more cross-linked HA products are more effective than lower molecular weight products: a subgroup analysis in the review by Rutjes suggested a trend toward greater pain relief for very high molecular weight products but studies are needed to assess whether this observation generalizes to function and also to compare the newer, larger products with the smaller ones.

Another issue of concern is the effectiveness (and safety) of HA over time and with repeated treatment cycles. Given that most studies of HA have been 6 months or less in duration and that OA of the knee is a chronic condition, studies are needed to assess both the safety and effectiveness of repeated cycles of HA over time and whether HA decreases the need for pharmacotherapy (NSAIDS, corticosteroids, and opioids), which has its own safety concerns.

Finally, as discussed above, the way that AEs are recorded and reported merits concern. Although issues such as potential underreporting affect active interventions as well as placebo-treated controls within the same study, the disparity in that of Bannuru) reinforces the need for standardization in the way that adverse events are documented. Based on a systematic review conducted in 2013, a group of researchers has developed an ACTTION (Analgesic, Anesthetic, and Addiction Clinical Trial Translations, Innovations, Opportunities, and Networks) AE checklist to improve the accuracy and completeness of AE data abstracted from reports of trials.123

## Conclusions

Trials enrolling older participants show a small, statistically significant effect of HA on function. Whether this effect is clinically meaningful is less clear: The research literature varies on its definition of minimum clinically important improvement. Based on our analyses, HA demonstrated clinically important improvements using two out of three of these definitions for this assessment. HA shows relatively few serious adverse events; however no studies limited participation to those 65 years or older. No conclusions can be drawn from the available literature on delay or avoidance of TKR through the use of HA. Studies that can compare large numbers of treated and untreated individuals, preferably with a randomized design, are needed to answer this question.