# Tools to Measure Function

Metrics and Tools Used to Assess Progression and Response to Treatment for Osteoarthritis of the Knee and Health-related Quality of Life

Figure H1 The Womac Osteorthritis Index

Figure H2 Lequesne Index

Figure H3 The RAND Medical Outcomes Study Short Form (SF)-36

Figure H4 EURO-QUOL (EQ)-5D-3L™