# Non-US Approved HA Devices

Table F1 Hyaluronic Acid Products Indicated for Treatment of OA of the Knee but Not Approved in the US

Product Name | Molecular Weight | Source | US Equivalent | Manufacturer
Adant | 900 kD | Synthetic^*^ | None | Meiji Seika Pharma Co., Ltd. Japan
Artz | 620–1170kD | Avian | Supartz | Seikagaku Corporation Japan
BioHy | 600–3000kD | Synthetic | Euflexxa | Biotechnology General Corp./Savient
Durolane | 1000kD | Avian | None | Q-Med
Go-on | 800–1500kD | Synthetic | None | Rottapharm\|Madaus, Monza, Italy
Hyaject | 1500kD | Synthetic | Unclear | Ormed Gmbh Germany
Hyalart | 750kD | Avian | Hyalgan? | MEDA Manufacturing GmbH
Hyalubrix | 1500–3200kD | Synthetic | None | Fidia
Hylan GF-20 | 600kD | Avian | Synvisc
Hyruan | 3000kD | n/a | None | LG Life Science
Ostenil | 1200–1400kD | Synthetic | None | TRB Chemedica Ltd. UK
Sinovial | 800–1200kD | Avian | None | IBSA Gulf Kingdom of Saudi Arabia
Suplasyn | 500–730kD | Synthetic | Hyalgan | Alveda/Mylan

* Purified from a cultured strain of Streptococcus via fermentation