# Non-English Language Article Abstracts Reviewed

Table E1 Non-English Language Articles with English Abstracts: Assessment of a Random Selection

ID/ Author, year, language | Design | Intervention | N, participant demographics | Outcomes
161/Not reported, 2012, Finnish | Care guidelines | Multiple | Not applicable (NA) | NA
180/Alhoff, 1998, German | CCT | HA vs. std care, 6 months | 179 gonarthrosis patients | Cost-effectiveness in terms of treatment cost and productivity, Lequesne and Euroquol for pain and mobility 92.4% of all patients under HYA achieved optimum values of Euroquol for general satisfaction vs. 42.9% in the reference group
254/Borras-Verdera, 2012, Spanish | Open uncontrolled trial | 1 injection HA + mannitol, periodic followup (FU) for 6 months | 79 pts. with painful knee OA | VAS WOMAC for pain and joint function, safety, need for rescue medication: % of patients who improved + effect A significant reduction in joint pain, stiffness and functional disability compared with baseline was observed at every follow-up visit (P<.001). Joint function improved by 38.7% on Day 30, reaching 47.5% on Day 180
296/Chen, 2002, Chinese | Open uncontrolled trial | 3 weekly HA injections, 1–6 month FU | 96 pts | Lysholm scoring, clinical signs, mobility, safety: % of patients who improved + outcome obvious improvements in the signs and function of knee in 39 patients (40.6%), only some improvements in 48 patients (50.0%), and no obvious improvements in other 9 patients (9.4%). The total effectiveness rate was 74.0%
335/Dai, 2002, Chinese | controlled trial | Weekly HA injections, variable number | 310 postop pts (arthroscopy or open) | Average VAS score for pain, time to maximum painless ROM after arthroscopy + effect: The VAS score of patients in the treatment group was significant lower than that of the control group. The period to the maximal painless ROM of the joint was 6 days in the treatment group after open operation, while 9 days in the control group
342/Diehl, 2013, German | review | Knee OA: Multiple treatmentmodalities | NA | NA (no real conclusions except that HA is safe and provide shortterm symptom relief)
348/Dougados, 1994/ French | Evaluation of arthroscopy to assess cartilage lesions and changes due to treatment (chondroscopy) | Preliminary study of repeated HA injections to test applicability, sensitivity of chondroscopy to visualize changes in cartilage | Not reported | Not relevant
379/Fukuda, 2004, Japanese | Non-systematic review | HA injection | Findings suggest HA effective for joint cellular and immune function but insufficient evidence on its effect on progression
380/Gadek, 2011, Polish | No study details | HA injection (Suplasyn) | Not reported | Study “reconfirmed effectiveness and safety…” No data in abstract
381/Galus, 2006, Polish | Non-systematic review on uses of HA | | | No mention of efficacy
409/Gu, 2011, Chinese | Non-systematic review on use of HA | | | Mentions evidence from insurers
422/He, 2012 | Case control study (really a trial) of HA + exercise vs. HA | | | No useful findings for this report, as HA was control
431/Heybeli 2008 | Post arthroscopic HA vs. no treatment | Post-surgical Orthovisc injection | 67 patients 40–65 years of age | Improvement in pain scores at 6 weeks did not differ between the two groups (HA 21%, control 16%; p=0.478), whereas improvement in function scores was significantly higher in the HA group (23% vs 9.2%; p=0.018)
443/ Hu 2006 | RCT | HA vs. ligustrazine, 5 tx, 63 month followup | 71 cases (82 knees) | There was significant decrease in Lequesneos index in SH group after the treatment (P<0.01), but not in LI group (P>0.05). Three weeks later, there was significant decrease in Lequesneos index in both groups after the treatment (P<0.01), with no significant difference between SH and LI group (P>0.05). After the 5-week treatment, the efficacy rate of the LI group was 82.1%, and that of the SH group was 87.2%
466/ Ishikawa 2002 japanese | NSR on HA for knee and shoulder | | | NR
517/Krocker 2006 German | Uncontrolled trial | Single injection of Durolane, synthetic HA, 24 weeks followup | 50 patients with primary OA | KOOS, VAS, and EQ-5D, as well as motion of the knee. At 2 wks: the subjective function of knee and quality of life had increased significantly. At 24 wks, all parameters increased significantly (quality of life and activity +19%; range of motion active 109 vs. 115 degrees ; pain, 55 vs. 41 mm (VAS); all p<0.01)
520/Kuiper-Geertsma 2000 Dutch | NSR | | | NR
542/Li 2011 Chinese | RCT | Comparison of PRP and HA: 3 injections at 3-week intervals, 6-month followup | 30 patients | International Knee Documentation Committee (IKDC) score, WOMAC score, and Lequesne index significant differences in IKDC score, WOMAC score, and Lequesne index between pre- and post-injection in 2 groups (P < 0.05); no significant difference was found between different time points (3, 4, and 6 months) in test group (P > 0.05), while significant differences were found between the postoperative 6th month and the postoperative 3rd and 4th months in control group (P < 0.05). There was no significant difference in IKDC score, WOMAC score, and Lequesne index between 2 groups within 4 months (P > 0.05), but the effectiveness of test group was significantly better than that of control group at 6 months after injection (P < 0.05)
544/ Li 2009, Chinese | Uncontrolled trial of acupuncture effect on HA | | | NR
545/Liang 2010 | Double blind placebo controlled RCT | HA vs. CS?, duration not reported | Sample size unknown | Findings unclear: HA better than CS?
ID #546 Ling 2002, | NSR | | | NA
IDs #563, 568, | NSRs
ID#578 Mar 2013 Spanish | Dataset analysis and modeling of 10-year budget impact | HA injection | Patients awaiting knee replacement | Modeling estimates that HA can delay TKR by 2.67 years. Leading to significant cost saving
ID# 587 Marson 2007 Italian | NSR
ID# 602 Menshikova 2007 Russian | Uncontrolled trial | ostenil (HA) | 60 OA patients, mean age 65 | Significant improvement was seen in 60% patients. Pain and stiffness in the knee joint relieved 2-fold. The function improved less. OA severity by Leken's index decreased by two degrees. 20% patients stopped intake of NAD, 32% had no need in taking NAD regularly. Subjective and objective assessment (by the patient and by the doctor) of the symptoms severity improved twice. Twelve months later the
ID# 616 Mitner 2001 German | Controlled trial (patients were own controls: blinding unclear) | HA, 5 weekly injections | 43 patients with bilateral knee OA | In knees treated with hyaluronic acid the mean peak torque of the knee extensor was 57 +/− 26.15/32 +/− 19.63 Nm vs. 77.17 +/− 32.54/47.83 +/− 21.43 Nm after (p < 0.01), the mean peak torque of the knee flexor was 40.44 +/− 21.58/22.89 +/− 16.64 Nm vs. 53.55 +/− 24.26/34.05 +/− 17.37 Nm after treatment (p < 0.01) at the angular velocities of 60 degrees/s and 180 degrees/s. Significant differences (p > 0.01) between treated and untreated knee were found for total work of the extensor and flexor of the knee. The pain at rest decreased from 3.83 +/− 1.72 cm to 1.36 +/− 1.42 cm and the pain under load decreased from 7.57 +/− 1.34 cm to 3.75 +/− 1.32 cm in the treated knee group (p < 0.01)
634/Navarro 2006 Spanish | Uncontrolled trial | HA, 5 weekly injections | 111 patients | Significant improvement in all efficacy variables
642/Noain 2002 Spanish | Case reports | | | 2 reports of acute local reactions
644/Nozaki 2002 Japanese | NSR
647/Okuda 1994 Japanese | Not OA, not study of HA