# Data Abstraction Tools

1 DJD Data Abstraction Tool

2 Cochrane Risk of Bias Tool for Randomized Controlled Trials, Adapted

3 Ottawa-Newcastle Risk of Bias Assessment for Observational Studies, Adapted

4 Adverse Events (Questions from McHarms)

5 AMSTAR Assessment of Reporting Quality for Systematic Reviews