# Evidence Table

Appendix Table C1 Evidence Table of all included studies